# Appendix B: Information Technology in Health Search Strategies

SEARCH METHODOLOGY - INFORMATION TECHNOLOGY + EFFECTS/OUTCOMES

DATABASE SEARCHED: PUBMED

YEARS OF COVERAGE: 1995-2003

OTHER LIMITERS:

English

SEARCH STRATEGY:

automatic data processing[majr] OR medical informatics[majr] OR medical informatics applications[majr] OR public health informatics[majr] OR electronics, medical[majr] OR information technolog* OR information infrastructure* OR ehealth OR e-health

AND

adverse effects[sh] OR outcome and process assessment health care[mh] OR costs and cost analysis OR efficiency, organizational OR risk assessment OR outcome*[ti] OR outcome*[ab] OR cost[ti] OR cost[ab] OR costs[ti] OR costs[ab] OR efficien*[ti] OR efficien*[ab] OR risk*[ti] OR risk*[ab] OR adverse[ti] OR adverse[ab]

AND

systematic[sb] - NOTE: This is the pre-formulated search developed by Medline to include systematic reviews, meta analyses, etc.

NUMBER OF ITEMS RETRIEVED: 516

================================================================

SEARCH METHODOLOGY - INFORMATION TECHNOLOGY + IMPROVEMENT

DATABASE SEARCHED: PUBMED

YEARS OF COVERAGE: 2002-2004

OTHER LIMITERS:

English

SEARCH STRATEGY:

automatic data processing[majr] OR medical informatics[majr] OR medical informatics applications[majr] OR public health informatics[majr] OR electronics, medical[majr] OR information technolog* OR information infrastructure* OR ehealth OR e-health

AND

outcome assessment health care OR process assessment health care OR workplace OR workflow* OR work flow* OR quality indicators, health care

AND

improve*[tiab] OR chang*[tiab]

NUMBER OF ITEMS RETRIEVED: 244

==================================================================

SEARCH METHODOLOGY - PRELIMINARY PUBMED SEARCH ON INFORMATION TECHNOLOGY BARRIERS

Database Searched and Time Period Covered:

PubMed - 2000-2003

Other Limiters:

English only

Search Strategy:

automatic data processing[majr] OR medical informatics[majr] OR medical informatics applications[majr] OR public health informatics[majr] OR electronics, medical[majr] OR attitude to computers OR information technolog*

AND

barrier* OR challeng* OR difficult* OR resist OR resisting OR resistance

NUMBER OF ITEMS RETRIEVED: 1662

===================================================================

INFORMATION TECHNOLOGY & HEALTH - POPULAR LITERATURE

Database: Periodical Abstracts

Query: ((de: information and de: technology) or (de: information and de: systems) or de: computer+ or de: digital or de: electronic or de: internet) and (de: health or de: healthcare or de: medical or de: medicine or de: physician+ or de: doctor+ or de: hospital+) and yr: 2002-2003

NUMBER OF ITEMS RETRIEVED: 433

==================================================================

SEARCH METHODOLOGY

Health Affairs Journal

SEARCH #1 (PERFORMED 12/23/04)

DATABASE SEARCHED AND TIME PERIOD COVERED:

PUBMED 1966-2004

SEARCH STRATEGY:

information technology

AND

information systems

NUMBER OF ITEMS RETRIEVED: 98

==================================================================

SEARCH METHODOLOGY

COMPUTERIZED MEDICAL RECORDS - COST BENEFITS

SEARCH #1 (PERFORMED 1/6/04)

DATABASE SEARCHED AND TIME PERIOD COVERED:

PUBMED 1995-2004

SEARCH STRATEGY:

medical records systems, computerized[majr]

AND

costs and cost analysis OR economics OR financ* OR economics(subheading)

AND

Review

NUMBER OF ITEMS RETRIEVED: 26

==================================================================

SEARCH #2 (PERFORMED 1/6/04)

DATABASE SEARCHED AND TIME PERIOD COVERED:

PUBMED 1995-2004

SEARCH STRATEGY:

medical records systems, computerized[majr]

AND

costs and cost analysis OR economics OR financ* OR economics(subheading)

NOT

Review

NUMBER OF ITEMS RETRIEVED: 871

NUMBER OF ITEMS SENT TO RESEARCHER (after deleting irrelevant items): 186 (COVERING 2000-2003)