# Appendix A: Technical Expert Panel

David Bates, MD, MSc | John Byrnes, MD
Chief, General Medicine | Chief Medical Officer
Brigham and Women's Hospital | Spectrum Health
620 Tremont Street, Room BC3-002M | 100 Michigan Ave. NE
Boston, MA 02120-1613 | Grand Rapids, MI 49503
617-732-5650 | 616-391-2774
617-732-7072 (fax) | john.byrnes@spectrum-health.org
dbates@partners.org
David Classen, MD | Simon Cohn, MD, MPH
Vice President | National Director for Health Information Policy
First Consulting Group | Kaiser Permanente Medical Care Program
561 East Northmont Way | One Kaiser Plaza, 27L
Salt Lake City, UT 84103 | Oakland, CA 94612
801-532-3633 | 510-271-6461
801-596-3443 (fax) | 510-267-2194 (fax)
dclassen@fcg.com | simon.cohn@kp.org
Mary Jo Deering, PhD | Jennie Harvell
Director | Senior Policy Analyst
Health Communication and Telehealth Office of Disease Prevention and Health Promotion | U.S. Department of Health and Human Services
U.S. Department of Health and Human Services | Humphrey Building
200 Independence Avenue SW | 200 Independence Avenue SW
Room 738-G | Washington, DC 20201
Washington, DC 20201 | 202-690-6443
202-260-2652 | 202-401-7733 (fax)
202-205-0463 (fax) | jennie.harvell@hhs.gov
mdeering@osophs.dhhs.gov
[underlined: Mary Jo Deering, Ph.D.] *
Director for Informatics Dissemination
NCI Center for Bioinformatics
National Cancer Institute
National Institutes of Health, USDHHS
6116 Executive Blvd. - #400
Rockville, MD 20852
Phone: 301-594-1273
Fax: 301-480-3441
E-mail: deeringm@mail.nih.gov
Robert Kolodner, MD | David Lansky, Ph.D.
Acting Deputy CIO for Healthcare Department of Veterans Affairs | Foundation for Accountability
810 Vermont Avenue NW | 1200 NW Naito Parkway, Suite 470
Washington, DC 20420 | Portland, OR 97209
202-273-8663 | 503-223-2228
robkolodner@hq.med.va.gov | 503-223-4336 (fax)
| dlansky@facct.org
Janet M. Marchibroda | Blackford Middleton, MD, MPH, MSc
Chief Executive Officer eHealth Initiative | Clinical Informatics R&D Partners Healthcare
1500 K Street, N.W., Suite 900 | 93 Worcester St., Box 81905
Washington, D.C. 20005 | Wellesley, MA 02481
202-624-3270 | 781-416-8528
202-624-3263 (direct) | 781-416-2286 (fax)
Arnold Milstein, MD, MPH | Elliott Sternberg, MD
Principal and Consultant | Senior Vice President and Chief Medical Officer
William M. Mercer, Inc. | St. Joseph Health System
3 Embarcadero Center | 500 S. Main Street, Suite 900
Suite 1500 | Orange, CA 92868
San Francisco, CA 94111 | 714-347-7841
415-743-8803 | esternbe@corp.stjoe.org
415-743-8950 (fax)
arnold.milstein@mercer.com
Paul C. Tang, MD | Scott Weingarten, MD, MPH
Chief Medical Officer | Chief Medical Officer Zynx Health, Inc.
Palo Alto Medical Foundation | 9100 Wilshire Blvd., Suite 655-E
795 El Camino Real | Beverly Hills, CA 90210
Palo Alto, CA 94301 | 310-247-7700
650-853-5775 | 310-247-710 (fax)
650-853-6050 (fax) | weingarten@zynx.com
tang@smi.stanford.edu
Scott Young, M.D. | David Cutler, PhD
Director, Health Information Technology Programs and Research | Economist,
Agency for Healthcare Research and Quality | Department of Economics
540 Gaither Road | Littauer Center
Rockville, MD 20850 | 1875 Cambridge Street
301-427-1580 | Harvard University
301-427-1595 (fax) | Cambridge, MA 02138
syoung@ahrq.gov
Marc Berg | Margaret Coopey RN, MGA, MPS
Prof. Dr. Marc Berg, MA, MD, PhD | Senior Health Policy Analyst Agency for Healthcare Research and Quality
Chair of Dept. of Social Medical Sciences Institute of Health Policy and Management | 540 Gaither Road
Erasmus University Rotterdam | Rockville, Maryland 20850
P.O. Box 1738 | 301-427-1618
3000 DR Rotterdam | 301-427-1520 (fax)
The Netherlands | mcoopey@ahrq.gov
Phone: ++31-10-4088531 / 4088525
Fax: ++31-10-4089094
M.Berg@bmg.eur.nl
David Atkins
Agency for Healthcare Research and Quality
540 Gaither Road
Rockville, Maryland 20850
301-427-1618
301-427-1520 (fax)
datkins@ahrq.gov