# References

1 Kohn LT, Corrigan JM, Donaldson M. To Err is Human: Building a Safer Health System. Washington, DC: National Academy Press. 2000.
2 Office of the Coordination of National Health Information, Department of Health and Human Services. The decade of health information technology: delivering consumer-centric and information-rich health care: framework for strategic action. Federal Register 2004;Sec. 411.357 (u):16142.
3 Ash JS, Gorman PN, Seshadri V, et al. (2004). Computerized physician order entry in U.S. hospitals: results of a 2002 survey. J Am Med Inform Assoc.
4 Miller RH, Hillman JM, Given RS. (2004). Physician use of IT: results from the Deloitte Research Survey. J Healthc Inf Manag.
5 Terry K. Doctors and EHRs. Med Econ 2005;82(2):72–4, 77–8, 80–4.
6 Dexter PR, Perkins S, Overhage JM, et al. (2001). A computerized reminder system to increase the use of preventive care for hospitalized patients. N Engl J Med.
7 Sisk JE, Moskowitz AJ, Whang W, et al. (1997). Cost-effectiveness of vaccination against pneumococcal bacteremia among elderly people. JAMA.
8 Leape LL, Berwick DM, Bates DW. (2002). What practices will most improve safety? Evidence-based medicine meets patient safety. JAMA.
9 Shojania KG, Duncan BW, McDonald KM, et al. (2002). Safe but sound. Patient safety meets evidence-based medicine. JAMA.
10 Kaushal R, Shojania KG, Bates DW. (2003). Effects of computerized physician order entry and clinical decision support systems on medication safety: a systematic review. Arch Intern Med.
11 Johnston ME, Langton KB, Haynes RB, et al. (1994). Effects of computer-based clinical decision support systems on clinician performance and patient outcome. A critical appraisal of research. Ann Intern Med.
12 Corley ST. (2003). Electronic prescribing: a review of costs and benefits. Top Health Inf Manage.
13 Garg AX, Adhikari NK, McDonald H, et al. (2005). Effects of computerized clinical decision support systems on practitioner performance and patient outcomes: a systematic review. JAMA.
14 Shiffman RN, Liaw Y, Brandt CA, et al. (1999). Computer-based guideline implementation systems: a systematic review of functionality and effectiveness. J Am Med Inform Assoc.
15 American Academy of Pediatrics: Task Force on Medical Informatics. (2001). Special requirements for electronic medical record systems in pediatrics. Pediatrics.
16 Kaushal R, Bates DW, Landrigan C, et al. (2001). Medication errors and adverse drug events in pediatric inpatients. JAMA.
17 Folli HL, Poole RL, Benitz WE, et al. (1987). Medication error prevention by clinical pharmacists in two children's hospitals. Pediatrics.
18 Jonville AP, Autret E, Bavoux F, et al. (1991). Characteristics of medication errors in pediatrics. DICP.
19 Holdsworth MT, Fichtl RE, Behta M, et al. (2003). Incidence and impact of adverse drug events in pediatric inpatients. Arch Pediatr Adolesc Med.
20 Koren G, Barzilay Z, Greenwald M. (1986). Tenfold errors in administration of drug doses: a neglected iatrogenic disease in pediatrics. Pediatrics.
21 Diav-Citrin O, Ratnapalan S, Grouhi M, et al. (2000). Medication errors in paediatrics: a case report and systematic review of risk factors. Paediatr Drugs.
22 Crossing The Quality Chasm: A New Health System for the 21st Century. Washington, D.C.: National Academy Press; 2001.
23 Mullett CJ, Evans RS, Christenson JC, et al. (2001). Development and impact of a computerized pediatric antiinfective decision support program. Pediatrics.
24 Fortescue EB, Kaushal R, Landrigan CP, et al. (2003). Prioritizing strategies for preventing medication errors and adverse drug events in pediatric inpatients. Pediatrics.
25 Potts AL, Barr FE, Gregory DF, et al. (2004). Computerized Physician Order Entry and Medication Errors in a Pediatric Critical Care Unit. Pediatrics.
26 Cordero L, Kuehn L, Kumar RR, et al. (2004). Impact of computerized physician order entry on clinical practice in a newborn intensive care unit. J Perinatol.
27 Ornstein SM, Garr DR, Jenkins RG, et al. (1995). Implementation and evaluation of a computer-based preventive services system. Fam Med.
28 Szilagyi PG, Rodewald LE, Savageau J, et al. (1992). Improving influenza vaccination rates in children with asthma: a test of a computerized reminder system and an analysis of factors predicting vaccination compliance. Pediatrics.
29 Chiarelli F, Tumini S, Morgese G, et al. (1990). Controlled study in diabetic children comparing insulin-dosage adjustment by manual and computer algorithms. Diabetes Care.
30 Schriger DL, Baraff LJ, Buller K, et al. (2000). Implementation of clinical guidelines via a computer charting system: effect on the care of febrile children less than three years of age. J Am Med Inform Assoc.
31 Christakis DA, Zimmerman FJ, Wright JA, et al. (2001). A randomized controlled trial of point-of-care evidence to improve the antibiotic prescribing practices for otitis media in children. Pediatrics.
32 Margolis CZ, Warshawsky SS, Goldman L, et al. (1992). Computerized algorithms and pediatricians' management of common problems in a community clinic. Acad Med.
33 Carroll AE, Tarczy-Hornoch P, O'Reilly E, et al. (2004). The effect of point-of-care personal digital assistant use on resident documentation discrepancies. Pediatrics.
34 Quattlebaum TG, Darden PM, Sperry JB. (1991). Effectiveness of computer-generated appointment reminders. Pediatrics.
35 McGlynn EA, Asch SM, Adams J, et al. (2003). The quality of health care delivered to adults in the United States. N Engl J Med.
36 Chassin MR, Galvin RW. (1998). The urgent need to improve health care quality. Institute of Medicine National Roundtable on Health Care Quality. JAMA.
37 Eisele CW, Slee VN, Hoffmann RG. (1956). Can the practice of internal medicine be evaluated?. Ann Intern Med.
38 Brook RH, Appel FA. (1973). Quality-of-care assessment: choosing a method for peer review. N Engl J Med.
39 Knaus WA, Draper EA, Wagner DP, et al. (1986). An evaluation of outcome from intensive care in major medical centers. Ann Intern Med.
40 Dubois RW, Brook RH, Rogers WH. (1987). Adjusted hospital death rates: a potential screen for quality of medical care. Am J Public Health.
41 Hussey PS, Anderson GF, Osborn R, et al. (2004). How does the quality of care compare in five countries?. Health Aff (Millwood).
42 Hippisley-Cox J, O'Hanlon S, Coupland C. (2004). Association of deprivation, ethnicity, and sex with quality indicators for diabetes: population based survey of 53,000 patients in primary care. BMJ.
43 Barros FC, Vaughan JP, Victoria CG. (1986). Why so many caesarean sections? The need for a further policy change in Brazil. Health Policy Plan.
44 Donabedian A. Explorations in Quality Assessment and Monitoring. Vol I. The Definition of Quality and Approaches to its Assessment. Ann Arbor, MI: Health Administration Press; 1980.
45 Tierney WM, Miller ME, McDonald CJ. (1990). The effect on test ordering of informing physicians of the charges for outpatient diagnostic tests. N Engl J Med.
46 Tierney WM, McDonald CJ, Hui SL, et al. (1988). Computer predictions of abnormal test results. Effects on outpatient testing. JAMA.
47 Tierney WM, McDonald CJ, Martin DK, et al. (1987). Computerized display of past test results. Effect on outpatient testing. Ann Intern Med.
48 Kucher N, Koo S, Quiroz R, et al. (2005). Electronic alerts to prevent venous thromboembolism among hospitalized patients. N Engl J Med.
49 Chin HL, Wallace P. Embedding guidelines into direct physician order entry: simple methods, powerful results. Proc AMIA Symp 1999;221–5.
50 van Wijk MA, van der Lei J, Mosseveld M, et al. (2001). Assessment of decision support for blood test ordering in primary care. a randomized trial. Ann Intern Med.
51 Safran C, Rind DM, Davis RB, et al. (1995). Guidelines for management of HIV infection with computer-based patient's record. Lancet.
52 Wang SJ, Middleton B, Prosser LA, et al. (2003). A cost-benefit analysis of electronic medical records in primary care. Am J Med.
53 Khoury AT. (1998). Support of quality and business goals by an ambulatory automated medical record system in Kaiser Permanente of Ohio. Eff Clin Pract.
54 Khoury A. (1997). Finding value in EMRs (electronic medical records). Health Manag Technol.
55 Kian LA, Stewart MW, Bagb C, et al. Justifying the cost of a computer-based patient record. Healthc Financ Manage 1995;49(7):58–60, 62, 64–7.
56 McDowell I, Newell C, Rosser W. (1989). A randomized trial of computerized reminders for blood pressure screening in primary care. Med Care.
57 McDowell I, Newell C, Rosser W. (1989). Computerized reminders to encourage cervical screening in family practice. J Fam Pract.
58 Rosser WW, Hutchison BG, McDowell I, et al. (1992). Use of reminders to increase compliance with tetanus booster vaccination. CMAJ.
59 McDowell I, Newell C, Rosser W. (1986). Comparison of three methods of recalling patients for influenza vaccination. CMAJ.
60 Rosser WW, McDowell I, Newell C. (1991). Use of reminders for preventive procedures in family medicine. CMAJ.
61 Simon GE, VonKorff M, Rutter C, et al. (2000). Randomised trial of monitoring, feedback, and management of care by telephone to improve treatment of depression in primary care. BMJ.
62 Cameron S, Regalado M, Quitoles M, et al. (1999). Harnessing technology: the creation of an electronic care management record in a social health maintenance organization. Manag Care Q.
63 Daly JM, Buckwalter K, Maas M. (2002). Written and computerized care plans. Organizational processes and effect on patient outcomes. J Gerontol Nurs.
64 Krall MA. Acceptance and performance by clinicians using an ambulatory electronic medical record in an HMO. Proc Annu Symp Comput Appl Med Care 1995;708–11.
65 Bulpitt CJ, Beilin LJ, Coles EC, et al. (1976). Randomised controlled trial of computer-held medical records in hypertensive patients. Br Med J.
66 Burkle T, Michel A, Horch W, et al. (1998). Computer based nursing documentation means to achieve the goal. Int J Med Inf.
67 Kilgore ML, Flint D, Pearce R. (1998). The varying impact of two clinical information systems in a cardiovascular intensive care unit. J Cardiovasc Manag.
68 Evans RS, Pestotnik SL, Classen DC, et al. Prevention of adverse drug events through computerized surveillance. Proc Annu Symp Comput Appl Med Care 1992;437–441.
69 Classen DC, Pestotnik SL, Evans RS, et al. (1997). Adverse drug events in hospitalized patients. Excess length of stay, extra costs, and attributable mortality. JAMA.
70 Evans RS, Classen DC, Stevens LE, et al. Using a hospital information system to assess the effects of adverse drug events. Proc Annu Symp Comput Appl Med Care 1993;161–165.
71 Tierney WM, Murray MD, Gaskins DL, et al. (1997). Using computer-based medical records to predict mortality risk for inner-city patients with reactive airways disease. J Am Med Inform Assoc.
72 Bates DW, Kuperman GJ, Rittenberg E, et al. (1999). A randomized trial of a computer-based intervention to reduce utilization of redundant laboratory tests. Am J Med.
73 Ornstein SM, MacFarlane LL, Jenkins RG, et al. (1999). Medication cost information in a computer-based patient record system. Impact on prescribing in a family medicine clinical practice. Arch Fam Med.
74 Wells BJ, Lobel KD, Dickerson LM. (2003). Using the electronic medical record to enhance the use of combination drugs. Am J Med Qual.
75 Mc Donald CJ. (1976). Use of a computer to detect and respond to clinical events: its effect on clinician behavior. Ann Intern Med.
76 Jones DL, Kroenke K, Landry FJ, et al. (1996). Cost savings using a stepped-care prescribing protocol for nonsteroidal anti-inflammatory drugs. JAMA.
77 Wilson GA, McDonald CJ, McCabe GP. (1982). The effect of immediate access to a computerized medical record on physician test ordering: a controlled clinical trial in the emergency room. Am J Public Health.
78 Tierney WM, Miller ME, Overhage JM, et al. (1993). Physician inpatient order writing on microcomputer workstations. Effects on resource utilization. JAMA.
79 Evans RS, Pestotnik SL, Classen DC, et al. (1998). A computer-assisted management program for antibiotics and other antiinfective agents. N Engl J Med.
80 Arias-Vimarlund V, Ljunggren M, Timpka T. Implementation of computer-based patient records in primary care: the societal health economic effects. Proc AMIA Annu Fall Symp 1996;503–7.
81 Schmitt KF, Wofford DA. (2002). Financial analysis projects clear returns from electronic medical records. Healthc Financ Manage.
82 Walker J, Pan E, Johnston D, et al. The value of health care information exchange and interoperability. Health Affairs 2005;w5.10.
83 Agrawal A. (2002). Return on investment analysis for a computer-based patient record in the outpatient clinic setting. J Assoc Acad Minor Phys.
84 Valancy J. (2002). How much will that EMR system really cost?. Fam Pract Manag.
85 Chambers CV, Balaban DJ, Carlson BL, et al. (1989). Microcomputer-generated reminders. Improving the compliance of primary care physicians with mammography screening guidelines. J Fam Pract.
86 Becker DM, Gomez EB, Kaiser DL, et al. (1989). Improving preventive care at a medical clinic: how can the patient help?. Am J Prev Med.
87 Moran WP, Nelson K, Wofford JL, et al. (1992). Computer-generated mailed reminders for influenza immunization: a clinical trial. J Gen Intern Med.
88 Frame PS, Zimmer JG, Werth PL, et al. (1994). Computer-based vs manual health maintenance tracking. A controlled trial. Arch Fam Med.
89 Barton MB, Schoenbaum SC. (1990). Improving influenza vaccination performance in an HMO setting: the use of computer-generated reminders and peer comparison feedback. Am J Public Health.
90 McDowell I, Newell C, Rosser W. (1990). A follow-up study of patients advised to obtain influenza immunizations. Fam Med.
91 Baird TK, Broekemeier RL, Anderson MW. (1984). Effectiveness of a computer-supported refill reminder system. Am J Hosp Pharm.
92 Simkins CV, Wenzloff NJ. (1986). Evaluation of a computerized reminder system in the enhancement of patient medication refill compliance. Drug Intell Clin Pharm.
93 Raynor DK, Booth TG, Blenkinsopp A. (1993). Effects of computer generated reminder charts on patients' compliance with drug regimens. BMJ.
94 Eadie LH, Seifalian AM, Davidson BR. (2003). Telemedicine in surgery. Br J Surg.
95 Rosenfeld BA, Dorman T, Breslow MJ, et al. (2000). Intensive care unit telemedicine: alternate paradigm for providing continuous intensivist care. Crit Care Med.
96 Rogers MA, Small D, Buchan DA, et al. (2001). Home monitoring service improves mean arterial pressure in patients with essential hypertension. A randomized, controlled trial. Ann Intern Med.
97 Pacht ER, Turner JW, Gailiun M, et al. (1998). Effectiveness of telemedicine in the outpatient pulmonary clinic. Telemed J.
98 Johnson KB, Davison CL. (2004). Information technology: its importance to child safety. Ambul Pediatr.
99 Johnston B, Wheeler L, Deuser J, et al. (2000). Outcomes of the Kaiser Permanente Tele-Home Health Research Project. Arch Fam Med.
100 Bass DM, McClendon MJ, Brennan PF, et al. (1998). The buffering effect of a computer support network on caregiver strain. J Aging Health.
101 Rethans JJ, Hoppener P, Wolfs G, et al. (1988). Do personal computers make doctors less personal?. Br Med J (Clin Res Ed).
102 Threet E, Fargues MP. (1999). Economic evaluation of voice recognition for the clinicians' desktop at the Naval Hospital Roosevelt Roads. Mil Med.
103 Nahm R, Poston I. (2000). Measurement of the effects of an integrated, point-of-care computer system on quality of nursing documentation and patient satisfaction. Comput Nurs.
104 O'Connell RT, Cho C, Shah N, et al. (2004). Take note(s): differential EHR satisfaction with two implementations under one roof. J Am Med Inform Assoc.
105 van den Nieuwenhuyzen MC, Engbers FH, Burm AG, et al. (1995). Computer-controlled infusion of alfentanil versus patient-controlled administration of morphine for postoperative analgesia: a double-blind randomized trial. Anesth Analg.
106 Greist JH, Marks IM, Baer L, et al. (2002). Behavior therapy for obsessive-compulsive disorder guided by a computer or by a clinician compared with relaxation as a control. J Clin Psychiatry.
107 Krishna S, Balas EA, Spencer DC, et al. (1997). Clinical trials of interactive computerized patient education: implications for family practice. J Fam Pract.
108 Strecher VJ, Kreuter M, Den Boer DJ, et al. (1994). The effects of computer-tailored smoking cessation messages in family practice settings. J Fam Pract.
109 Liaw T, Lawrence M, Rendell J. (1996). The effect of a computer-generated patient-held medical record summary and/or a written personal health record on patients' attitudes, knowledge and behaviour concerning health promotion. Fam Pract.
110 Lewis G, Sharp D, Bartholomew J, et al. (1996). Computerized assessment of common mental disorders in primary care: effect on clinical outcome. Fam Pract.
111 Revere D, Dunbar PJ. (2001). Review of computer-generated outpatient health behavior interventions: clinical encounters “in absentia”. J Am Med Inform Assoc.
112 Bessell TL, McDonald S, Silagy CA, et al. (2002). Do Internet interventions for consumers cause more harm than good? A systematic review. Health Expect.
113 Eysenbach G, Powell J, Englesakis M, et al. (2004). Health related virtual communities and electronic support groups: systematic review of the effects of online peer to peer interactions. BMJ.
114 Car J, Sheikh A. (2004). Email consultations in health care: 1--scope and effectiveness. BMJ.
115 Balas EA, Jaffrey F, Kuperman GJ, et al. (1997). Electronic communication with patients. Evaluation of distance medicine technology. JAMA.
116 Overhage JM, Suico J, McDonald CJ. (2001). Electronic laboratory reporting: barriers, solutions and findings. J Public Health Manag Pract.
117 Murff HJ, Kannry J. (2001). Physician satisfaction with two order entry systems. J Am Med Inform Assoc.
118 Overhage JM, Perkins S, Tierney WM, et al. (2001). Controlled trial of direct physician order entry: effects on physicians' time utilization in ambulatory primary care internal medicine practices. J Am Med Inform Assoc.
119 Wong DH, Gallegos Y, Weinger MB, et al. (2003). Changes in intensive care unit nurse task activity after installation of a third-generation intensive care unit information system. Crit Care Med.
120 Abookire SA, Teich JM, Sandige H, et al. Improving allergy alerting in a computerized physician order entry system. Proc AMIA Symp 2000;2–6.
121 Ammenwerth E, Mansmann U, Iller C, et al. (2003). Factors affecting and affected by user acceptance of computer-based nursing documentation: results of a two-year study. J Am Med Inform Assoc.
122 Gamm LD, Barsukiewicz CK, Dansky KH, et al. (1998). Investigating changes in end-user satisfaction with installation of an electronic medical record in ambulatory care settings. J Healthc Inf Manag.
123 Burkle T, Kuch R, Prokosch HU, et al. (1999). Stepwise evaluation of information systems in an university hospital. Methods Inf Med.
124 Elbourne D, Richardson M, Chalmers I, et al. (1987). The Newbury Maternity Care Study: a randomized controlled trial to assess a policy of women holding their own obstetric records. Br J Obstet Gynaecol.
125 Lazarus SS. (1999). Physicians' use of electronic medical records--identifying and crossing the barriers. Med Group Manage J.
126 Berkowitz LL. (1997). Breaking down the barriers. Improving physician buy-in of CPR systems. Healthc Inform.
127 Bates DW, Boyle DL, Teich JM. Impact of computerized physician order entry on physician time. Proc Annu Symp Comput Appl Med Care 1994;996.
128 Pizziferri L, Kittler AF, Volk LA, et al. (2005). Primary care physician time utilization before and after implementation of an electronic health record: a time-motion study. J Biomed Inform.
129 Hersh WR, Hickam DH. (1998). How well do physicians use electronic information retrieval systems? A framework for investigation and systematic review. JAMA.
130 Johnson KB. (2001). Barriers that impede the adoption of pediatric information technology. Arch Pediatr Adolesc Med.
131 Miller RH, Sim I. (2004). Physicians' use of electronic medical records: barriers and solutions. Health Aff (Millwood).
132 Poon EG, Blumenthal D, Jaggi T, et al. (2004). Overcoming barriers to adopting and implementing computerized physician order entry systems in U.S. hospitals. Health Aff (Millwood).
133 Hersh W. (2004). Health care information technology: progress and barriers. JAMA.
134 Wears RL, Berg M. (2005). Computer technology and clinical work: still waiting for Godot. JAMA.