# 3 Results

We screened 855 articles, of which 599 were rejected: 124 did not have HIT as the subject; 4 did note report relevant outcomes; 288 were descriptive qualitative studies; and 183 were categorized as descriptive quantitative studies. A total of 256 articles was included in the HIT interactive database. (Figure 1 presents this information pictorially.)

Figure 1. HIT Literature Flow

## Description of the Studies

Of the 256 studies included in the database, 156 pertained to decision support, 84 assessed the electronic medical record, and 30 were about CPOE (categories are not mutually exclusive). One hundred twenty four of the studies assessed the effect of the HIT system in the outpatient or ambulatory setting, while 82 assessed its use in the hospital or inpatient setting. Ninety-seven studies used a randomized design; 11 were other controlled clinical trials, 33 used a pre-post design, 20 used a time series, and another 17 were case studies with a concurrent control. Among the 211 hypothesis-testing studies, 82 contained at least some cost data (or data on utilization or efficiency, that could be converted to costs).

Many of the studies concerned HIT systems developed and evaluated by academic and institutional leaders in HIT: the Regenstrief Institute, Partners/Brigham and Women's Hospital, Intermountain Health, Kaiser, Vanderbilt, and the VA health care system. The HIT systems at the Regenstrief Institute and Partners were each assessed in 18 and 19 separate studies, respectively; 15 assessed the VA health information system; 11 studied Intermountain Health; 5 studied Kaiser; and 2 assessed the HIT system at Vanderbilt. Studies from these institutions have contributed greatly to our knowledge about the usefulness of particular HIT functionalities (such as CPOE or computerized electronic alerts) and are examples of what can be realized by the implementation of broadly functional HIT at these specific institutions. But these studies also have limitations in terms of their usefulness to inform decisions about the adoption of HIT in other locations. The primary concern is that these HIT systems were developed over the course of many years by champions at these institutions, and, in a process of coevolution, were specially adapted to the working environment and culture of their respective institutions. Consequently, the “intervention” consists of not only the HIT system but also its local champions, who were often also the evaluators in published studies. Furthermore, it is challenging to calculate the cost of the development of the HIT system as a whole, since this process has occurred over many years. Finally, these systems are not commercially available from vendors, whereas most HIT systems in the United States are commercial systems.

We were able to identify only 15 studies that used a randomized or controlled clinical design, included cost data, and assessed HIT systems that were not located at one of the leading academic and institutional HIT institutions or in the United Kingdom (UK), another setting that has limited generalizability to U.S. health care institutions. When these 15 studies were examined for their HIT functionality using the classification system developed by the Institute of Medicine, ^4^ four of them concerned only decision support; four assessed HIT systems with decision support and administrative processes; and one study each assessed HIT systems with health information and data storage; health information and data storage with decision support; order entry management alone; order entry management with reporting and population health management; decision support with patient support and administrative processes; and health information with data storage decision support and administrative processes. In other words, we were unable to find a single study that used a randomized or controlled clinical trial design, reported data from a site other than one of the leading academic or institutional HIT systems or the UK, reported cost outcomes, and assessed a HIT system that included at least four of the eight IOM categories of functionality.

4 The eight functionalities are documentation (health information and data storage); results management; order entry management; decision support; electronic communication and connectivity; patient support; administrative processes; and reporting and population health management.

Of 103 hypothesis-testing studies that used a design other than a randomized or controlled clinical trial, 45 reported cost data. Of the 45 studies that reported cost data, 23 assessed systems that were not one of the leading academic or institutional HIT systems or UK systems. An examination of these 23 studies for their functionalities showed, as in the studies using an RCT or CCT design, that most did not evaluate systems with a broad level of functionality. Five studies assessed only decision support, and three studies each assessed only administrative processes or order entry management. Three studies assessed HIT systems with two functionalities: order entry management and decision support. The remaining nine studies assessed various combinations of two or three functionalities. No study evaluated a HIT system with at least four of the eight categories of functionality.

Regarding information about the organizational context of a HIT implementation, the literature is even more sparse. Of the hypothesis-testing studies, we identified only three studies that provided information about the financial context of the organization, such as the degree of managed care/capitation penetration; six studies with information about system penetration; one study about facilitators to implementation; one studies explicitly discussing sustainability of the HIT intervention; twelve studies reporting extrinsic factors in valuing costs and benefits, such as the healthcare market competitiveness; and six studies and nine studies, respectively, reporting on the initial costs of the HIT system and costs of implementation. No studies explicitly discussed sustainability of the HIT intervention.

In summary, we identified no study or collection of studies, outside of those from a handful of HIT leaders, that would allow a reader to make a determination about the generalizable knowledge of the system's reported benefit. Besides these studies from HIT leaders, no other research assessed HIT systems with comprehensive functionality while also including data on costs, relevant information on organizational context and process change, and data on implementation. This limitation in generalizable knowledge is not simply a matter of study design and internal validity: Even if more randomized controlled trials are performed, the generalizability of evidence will remain low unless more systematic, comprehensive, and relevant descriptions and measurements are made regarding how the technology is utilized, the individuals using it, and the environment it is used in.

As is apparent from the preceding discussion, the interpretation of studies of HIT is highly context-specific and is not amenable to the techniques of meta-analysis frequently used in other evidence reports to summarize results across studies. Certain functionalities of HIT systems have been the subject of recent reviews, such as CPOE, ^10^ computer-based clinical decision support systems, ^11^–^13^ and the use of computer-based guideline implementation systems.^14^ We will not summarize these reviews here. Readers are referred to the interactive database of HIT studies to select those studies that are most relevant to their own situation in terms of functionalities, clinical settings, outcomes reported, and other factors. The remainder of this chapter presents four examples of syntheses of the literature for specific situations: the effect of HIT in the field of pediatrics; evidence regarding the effect of the electronic health record on quality of ambulatory care; studies that report and predict the potential benefits and costs of implementation of the electronic health record; and health information technology and patient-centered care.

## The Costs and Benefits of Health Information Technology in Pediatrics

### Introduction

A decision to implement health information technology should carefully weigh the costs and benefits of incorporating it into the clinical environment. This is especially true in settings involved in the healthcare of infants and children, where patterns of practice and the needs of clinicians are unique. A recent report issued by the medical informatics taskforce of the American Academy of Pediatrics (AAP) cited a number of special requirements for the effective use of electronic medical record (EMR) systems in pediatrics. ^15^ The practice of primary care and subspecialty pediatrics requires specialized collection of growth data, immunization history, longitudinal developmental inventories, parent education, age- and weight-based norms and dosing of therapeutics, specialized terminologies, and unique school-based forms and reports.

In the area of pediatric patient-safety, a growing number of studies have described the frequency of medication errors and adverse drug events (ADEs) in both the inpatient and ambulatory settings. ^16^ – ^19^ For a number of reasons—including weight- and age-based medication dosing, medication unit-doses designed for adult patients, and the limited ability of children to communicate or self-check medications before they are administered, ^20,^ ^21^ —infants and children are at higher risk for serious medication errors and resultant ADEs than are adults. HIT is believed to be a vital component in the quest to improve medication safety in pediatrics.

These special requirements, combined with a small commercial market for pediatric HIT systems relative to the adult population, make the implementation of HIT in the pediatric setting challenging and perhaps costly. Clearly, more must be known about the relative costs and benefits of HIT implementation and use in pediatrics and evidence of its impact on the six quality aims identified in the IOM report, Crossing the Quality Chasm, ^22^ to deliver safe, effective, efficient, patient-centered, timely, and equitable healthcare.

### Literature

Of the 256 articles included in the database, 14 articles were determined to contain quantitative data on the costs and/or benefits of HIT use in the pediatric healthcare setting. Because of a paucity of evidence, we also included descriptive quantitative studies in this section.

### Summary of Evidence

Medication Use and Patient Safety. Given recent insight into the prevalence of medication errors in the pediatric population, health information technology is believed by most to be an important tool in reducing the rate of medication errors that occur in the care of infants and children.

Mullett et al. ^23^ enhanced an existing adult antiinfective computerized decision-support system for use in an academic pediatric intensive care unit (PICU) and measured its impact on medication-related outcomes. The study reported a 59-percent decrease in pharmacist interventions for erroneous drug doses and a decreased number of patient days of subtherapeutic (p<0.001) or excessive (p<0.001) antiinfective doses. In addition, the surveyed physicians reported that the use of the system improved their antiinfective choices and perhaps reduced the likelihood of ADEs. The authors also reported a decreased number of orders per patient-antiinfective course as well as decreased robust estimated costs of antiinfective use by 9 percent in the intervention group vs. control ($86.60 vs. 78.43).

A study by Fortescue and colleagues ^24^ examined and characterized 616 medication errors occurring in the pediatric inpatient units of two academic tertiary referral medical centers. In a hypothetical experiment, physician experts determined what percentage of these errors could potentially have been prevented by the implementation of safety systems. Specifically, this hypothetical experiment determined that basic CPOE would avert 60 percent of potentially harmful errors, while CPOE with clinical decision-support systems (CPOE +CDSS) would increase the prevention of harmful errors to 75.8 percent. Other HIT systems identified by the report as being important for averting medication errors in pediatrics settings included computerized/electronic medication administration record (e-MAR) (19.2 percent of potentially harmful errors), robots in pharmacy (2.5 percent), smart intravenous infusion devices (4.2 percent), medication and patient and staff bar-coding (4.2 percent), and an automated bedside medication dispensing device (5.8 percent).

A number of studies have directly measured the benefit of CPOE using a variety of error-capture methodologies and study designs in different pediatric clinical environments. In a prospective cohort study, the authors documented medication prescribing errors (MPEs) and potential adverse drug events (PADEs) in a pediatric intensive care unit before and after implementation of a “home-grown” CPOE system. ^25^ The data showed a significant reduction of both MPEs (30.1 to 90.2 percent, p< 0.001) and PADEs (2.2 to 1.3 percent, p<0.001). A study by Cordero and colleagues in the neonatal intensive care setting (NICU) showed that CPOE could eliminate gentamicin prescribing errors as well. ^26^ The sum of this early evidence indicates that CPOE +CDSS has significant potential to reduce harmful medication errors, but the relative costs and complexities of achieving these beneficial outcomes need to be examined further.

Immunizations. Although a growing body of literature suggests that the use of HIT in pediatrics may be an important ingredient in reducing medication errors, a key challenge for pediatric providers lies in the area of maximizing adherence to vaccination recommendations. Paper-based immunization records do not allow for rigorous population-based monitoring or quality control. Therefore, computerized immunization registries, as separate or integrated systems and with clinical decision-support or reporting capabilities, offer tremendous potential in tracking and improving the rates of adherence to recommended immunization guidelines.

Ornstein et al. ^27^ evaluated a computer-based preventive services alerting system integrated into an electronic medical record system in an academically affiliated family practice clinic. In addition to surveying patient and physicians regarding their perceptions of the reminder system, the researchers performed before-and-after audits of adherence to recommended preventative services including childhood immunizations. Of the five immunization services tracked, only the administration of diphtheria and tetanus booster showed a small but significant improvement (48.8 to 50.6 percent, p=0.02). Adherence to the other recommended vaccinations did not show a significant improvement.

Szilagyi, and colleagues, ^28^ in an academically affiliated pediatric urban clinic, used a computerized database system to generate reminder letter for influenza vaccination to patients identified with moderate to severe asthma. Eligible patients were randomized into an intervention group, which received the reminders, and a control group. After four months, a review of the medical chart revealed a significant difference in influenza vaccination rates (30 percent intervention vs. 7 percent control, p<0.01). This study demonstrated that computerized disease registry systems could serve as an important tool in improving vaccination rates in pediatrics.

Effective Disease Management. In addition to providing a potential means to influence prescribing and immunization practices in pediatrics, HIT systems also hold tremendous promise in improving clinical decisionmaking and disease management.

Medication Dosage and Delivery. Chiarelli et al. ^29^ evaluated a microprocessor device with computerized algorithms for insulin dose adjustment for pediatric patients with insulin-dependent diabetes mellitus, based on self-monitored blood glucose (SMBG) levels. This prospective randomized on-off-on study revealed that although the mean glycosylated hemoglobin levels and pre-meal SMBG levels did not improve, control patients were more likely to experience episodes of hypoglycemia than were patients using the device, and patients using the device used less insulin than during their corresponding baseline phase (p<0.0001) and less insulin than the control group.

Disease-Based Clinical Decision Support. Schriger and colleagues ^30^ implemented an electronic medical record in a university hospital emergency department that provided documentation advice and recommendations for laboratory testing and treatment. Using an on-off-on interrupted study design, the authors measured appropriateness of care for febrile children less than three years of age, when measured against an evidence-based guideline. No evidence was found for improvements (or worsening) in appropriateness of care during the intervention phase compared to the baseline phase. However, use of the system was found to increase documentation of essential elements of the history and physical examination by 13 percent (95% confidence interval, 10 to 15 percent) as well as documentation of after-care instructions by 33 percent (95% confidence interval, 28 to 38 percent).

The appropriate course of antibiotic treatment for acute otitis media (AOM) is an area of concern in pediatrics. A study by Christakis et al. ^31^ measure the impact of HIT on the antibiotic prescribing behavior of pediatric providers in an academic pediatric residency training clinic and compared cohorts during the pre-intervention and post-intervention phases. During the post-intervention phase, providers were randomized to receive point-of-care advice recommending a course of antibiotics of less than 10 days duration (primary outcome) or delayed initiation of antibiotics (secondary outcome) for the treatment of AOM. Measurement of adherence to this computerized alert showed that providers in the intervention group had a 34-percent increase compared to the control group in the proportion of antibiotic prescriptions that were for less than 10 days (p<0.01). However, during the intervention period, both the intervention and control groups became more likely to prescribe antibiotics, with the intervention group deteriorating less than the control group (p<0.095). The results demonstrate that the prescribing practices of pediatricians for treatment of a common pediatric illness can be affected by a computerized reminder system.

Using a similar study design, Margolis et al. ^32^ developed a computerized algorithm system that mandated structured input of data by providers for common pediatric problems. In return, the system provided recommendations for disease management and correct use of antibiotics. The investigators demonstrated decreased use of antibiotics for OM (p<0.001) and pharyngitis (p<0.01) as well as increased adherence to protocol recommendations for these two disease processes in the intervention group compared with the control group. However, the use of antibiotics for upper respiratory infections (URIs) did not change. The authors noted that the structured algorithms in the HIT system did improve the documentation of clinical elements important to ideal clinical care of pharyngitis, otitis media, and upper respiratory infections. It must be noted however, that this system's rigid requirements for physician documentation also made the HIT system unusable, and the physicians refused to use the system after five weeks.

Improved Documentation. Because many studies have reported an impact of HIT use on the quality and completeness of medical documentation, a study by Carroll and colleagues focused on the impact of a personal digital assistant (PDA) on documentation discrepancies in a NICU. ^33^ In this before-and-after study, all the NICU resident physicians used a PDA-based charting system during the intervention phase, comparing their progress notes against a predefined reference standard during both phases. The authors demonstrated that after adjustment for covariates, PDA-based charting did reduce discrepancies in patient weights in the charts but did not affect the number of medication or vascular line discrepancies.

Timeliness, Efficiency and Cost-Effectiveness of Care. Quattlebaum et al. ^34^ studied a scheduling/practice management system that automatically generated reminder postcards for appointment the following week. In this randomized controlled trial, the authors demonstrated a reduction of the no-show rate in their pediatric ambulatory practice from 19 to 10 percent. A cost-benefit analysis of the HIT system and its impact on missed appointments revealed that for each $1 spent on reminders, an additional $7.50 of revenue was captured.

In the inpatient setting, the previously discussed study of CPOE in the NICU by Cordero and colleagues ^26^ measured not only CPOE's effect on gentamicin dosing errors but also the time from medication prescription to administration for initial doses of a single medication and radiology tests during the pre- and post-CPOE phases. The authors documented significant reductions in the average turnaround time for both medications (10.5 to 2.8 hours, p<0.01) and radiology tests (42 to 32 minutes, p<0.001).

### Summary

Early evidence shows that stand-alone CDSS can reduce medication dosing errors, and CPOE + CDSS can reduce the incidence of harmful medication errors in the inpatient pediatric and neonatal intensive care settings. However, other HIT systems, such as electronic MAR, pharmacy-based robots, smart infusion pumps/devices, and medication bar coding, are predicted to reduce medication errors but need to be studied further.

HIT also has tremendous potential to improve vaccination rates and disease management in pediatric outpatients. CDSS and registries have been shown to be effective in increasing vaccination rates in targeted populations, but only a limited HIT impact on general pediatric immunization rates has been demonstrated. Similarly, a patient clinical decision-support device that assists insulin dosing in children with diabetes reduces episodes of hypoglycemia and overall insulin requirements, but does not affect traditional measurements of glycemic control. And the use of computerized documentation systems with integrated CDSS has been demonstrated, in separate studies, to 1) reduce the frequency or duration of antibiotic use for common pediatric illness such as pharyngitis and otitis media, and 2) improve completeness and somewhat reduce variation in clinical documentation.

In the ambulatory setting, a single study showed that an appointment reminder system is cost-effective and significantly reduces missed appointments. Another study showed that CPOE in the NICU can reduce medication and radiology turnaround times. Therefore, the evidence for HIT cost-savings in pediatrics is limited but deserving of optimism.

### Conclusion

A small body of literature supports the assertion that HIT use in pediatrics is beneficial in the areas of medication safety, adherence to immunization and disease-based guidelines, patient decision-support in diabetes management, clinical documentation, patient appointments, and in-hospital order processing. No data on the costs or cost-effectiveness of implementing these systems were found, except in one case. In addition, because many of these HIT systems were tested and/or developed in academic settings, the ability to generalize these findings to other organizations is uncertain.

## Electronic Health Records and Quality of Ambulatory Care

### Introduction

Despite rapid advances in the biomedical sciences, a growing body of evidence shows serious shortfalls in the quality of care Americans receive, ^35,^ ^36^ and significant longstanding shortfalls in performance have persisted despite recent increases in attention to quality. ^37^ – ^40^ International comparisons have demonstrated similar problems in quality. ^41^ – ^43^ If the United States is to realize the full value of biomedical knowledge and of financial investments made in healthcare, the mechanisms through which that knowledge is operationalized and care is delivered must be radically redesigned.

Although the content of healthcare continues to change dramatically, the methods of health care delivery have not. In particular, a vast majority of the healthcare industry continues to deliver care, manage information, and conduct clinical transactions through the use of paper records.

Although the use of electronic health records (EHRs) is limited in healthcare, there is a renewed conviction by the government, provider groups, and healthcare purchasers that widespread adoption is critical to the delivery of consistent, high-quality care. However, EHR implementation, without other important changes in the way healthcare services are provided, is unlikely to improve quality. Such process redesign and reengineering is difficult and resource-intensive and is also hampered by the complexity and fragmentation of our current healthcare system. Therefore, despite the potential benefits of widespread EHR use, better empirical evidence is needed to confirm that EHR use does in fact improve quality and—perhaps more fundamentally—to understand what capabilities EHRs need to have for quality to be improved. At present, the depth and breadth of the empirical evidence regarding EHR use and its attributable impact on the quality of care remains unclear.

The purpose of this review is to examine and synthesize the available research evidence for the impact of EHR on quality of care in the outpatient setting. The review will also attempt to differentiate the direct impact of EHRs as point-of-care and workflow tools from how EHRs have been used to indirectly achieve those results, by measuring clinical and process outcomes. We elected to focus on ambulatory care because of the large volume of health services delivered in this arena. In addition, because the vast majority of outpatient practices comprise fewer than ten providers—many of whom lack technical infrastructure and resources—it is unclear whether widespread implementation of EHRs will be feasible in this environment.

### Research Study Inclusion Criteria

From our database of 256 articles, we selected all 84 papers that related to EHRs. We then screened these articles against the following inclusion criteria: (1) the study reported quality-of-care data as study outcomes, (2) the EHR was documented to have the following minimal functionality—electronic documentation (viewing, entry, or both), results management, CPOE, and some form of decision support, (3) the study was conducted in the ambulatory setting. The criteria for functionality were chosen based on the IOM's “White Paper on Key Capabilities of an Electronic Health Record.” Given the rapid technical advances in EHR systems, we reviewed additional functional criteria to provide decisionmakers with the most relevant and forward-looking information available.

### Analytic Framework

The Donabedian “Structure—Process—Outcome” model for quality was used as a framework for this review. ^44^ In this model, structure is defined as the resources and factors involved in producing care and the manner in which those resources and factors are organized. Examples of structural quality include the number of beds in a hospital, the number of physicians in an emergency room per shift, the budget for a clinic, and the presence of disease management program for diabetes. Process of care is defined as the activities that constitute health care. Examples include screening for breast cancer, ordering laboratory tests, and prescribing a medication. Outcomes are the end results of healthcare delivery processes. They are the consequences of health services or can be logically attributed to the act of providing those services. Whereas structure relates to the environment in which healthcare is delivered and process relates to the provisions of care, outcomes are events that occur with patients and consumers—as individuals, groups, or populations.

Two aspects of this model are particularly relevant to EHRs. First, to fully assess quality of care, there need to be links from structure to process to outcomes. The technical and functional capabilities of EHRs form a structure for care. In order to derive value from the EHR structure, new clinical processes need to be designed to utilize the EHR functional structure. These EHR-mediated processes should in turn lead to a specific set of better outcomes. Second, the distinctions among structure, process, and outcome are somewhat arbitrary in the model. Health care delivery is viewed as an interconnected series of structure—process—outcome relationships. For example, in a primary care clinic of three physicians (structure 1), a patient may have an electrocardiogram performed (process 1), which shows an abnormality (outcome 1). This abnormal result necessitates a referral to a cardiologist (structure 1) who orders a stress test (process 2), which comes back suggestive of coronary artery disease (outcome 2) and so forth. This structure—process—outcome chain is central to the role of EHRs in quality, because an EHR is a tool that explicitly links the three. An EHR with decision support for diabetes management (structure) allows a physician to order a hemoglobin A1C (process) and check the results (outcome). Because this outcome is stored in the EHR database, it in turn becomes part of the structure of care. The EHR can allow or even remind the physicians to act on that result (process 2), e.g., modify the patient's insulin dose, which will, in turn, lead to a lowering of the patient's blood sugar (outcome 3) or a reduction in the likelihood of a long-term diabetic complication.

In addition to imposing the Donabedian Structure—Process—Outcome model, we organized deficits in quality by means of a conceptual framework that divides quality problems into three types: (1) the underuse of appropriate health services, (2) the misuse or inappropriate use of health services, and (3) the overuse of health services. ^36^

### Analysis

Seven research studies were identified using the search criteria outlined earlier. ^45^ – ^51^ Four of the seven were conducted at academic medical centers, ^45^ – ^47,^ ^51^ and three of those four were conducted at a single institution, Regenstrief Institute (the fourth was conducted at Beth Israel Hospital in Boston). ^45^ – ^47^ Two studies were conducted at a large, integrated healthcare delivery network, Kaiser, ^48,^ ^49^ and one was conducted in the Netherlands. ^50^ All four studies from the academic medical centers assessed internally developed HIT systems, rather than a commercially available system. One study ^48^ assessed two different systems at two sites, one of which was internally developed by the organization and the other a commercially developed product.

All studies included data on structural quality. These varied highly and were largely qualitative in nature. In particular, reporting on the organizational and workflow changes needed to implement an EHR or a new EHR functionality was limited. All seven studies analyzed quality with respect to process of care. Six of the seven ^45^ – ^49,^ ^51^ assessed quality with respect to some type of outcome.

In terms of the types of problems the interventions were trying to address, six of the seven ^45^ – ^50^ included data on the effects of EHRs on decreasing overused or redundantly used healthcare services. Two ^48,^ ^51^ included measures of the effects of EHRs on appropriate but underused care. None used explicit methods to evaluate the impact of EHRs on inappropriate use of care.

#### EHR Systems in Use at Regenstrief

Structure. Three studies that met our criteria were conducted at the Regenstrief Institute, which includes a research institute and an ambulatory care practice affiliated with both a university medical school and a large public hospital. ^45^ – ^47^

The development of the EHR at the Institute began in the mid-1970s. Subsequent system enhancement and implementation broadened its functionality and scope of use. In 1984, CPOE was added to the EHR capabilities and became uniformly used in the outpatient setting. In the three studies covered in this analysis, the system included electronic documentation, results management, CPOE, and decision support.

All three studies examined the effects of incorporating new information elements into the process used by physicians to order diagnostic tests. Each involved the integration of EHR-stored data into physician decisionmaking at the point of care.

The first paper ^45^ reported on the effect of a structural change in care delivery: the addition of diagnostic test cost data to the EHR order function. Thus, physician workflow was altered through the inclusion of cost data in the order entry process, to be shown at the point of care. After physicians ordered tests, the charges for each test and the total charges for all tests were provided automatically in a new window. Physicians were then offered the option to cancel any or all tests.

This study used a complex randomized design to test the effect of the intervention. First, baseline utilization data were collected during a 14-week observation period. Second, physicians were randomized either to receive the cost data during order entry or to use the usual EHR functional interface where no cost data were provided. Finally, data collection continued for a 19-week post-intervention period.

The second paper reported on the effect of an intervention ^47^ in which the investigators created statistical models to predict the likelihood of abnormal results for commonly ordered diagnostic tests. These pretest probabilities were displayed to physicians immediately prior to test ordering. Data needed for the models were obtained through EHR mediated prompts to physicians and from patient-specific data already electronically stored. Physician workflow was altered by the need to enter data during the test-ordering process and by the incorporation of the pretest probability into their decisionmaking process. The number of data prompts given to physicians was not reported.

The study used a randomized design in which patients were the unit of randomization. The EHR sorted patients automatically by the predetermined allocation. When physicians cared for intervention patients, the pretest probability function was activated during the electronic ordering process. When physicians ordered tests for the control patients, no additional decision support was provided.

The third paper reported on an intervention ^47^ in which care delivery was modified through an intervention in which past diagnostic test results were automatically displayed as physicians ordered new tests. The last three results for a test, the time interval between tests, and the total number of times the test had been ordered for the patient were displayed at the point of care. No additional data entry was required of physicians. Physician workflow was altered by the need to incorporate past test results during decisionmaking.

The study used a complex multiphased, randomized design. First, during a 13-week pre-intervention period, baseline data were collected regarding physician test ordering patterns. During the 16-week intervention period, patients were the unit of randomization. Finally, test ordering was monitored during an 8-week post-intervention period.

Process. Each of these studies examined the impact of the EHR-related structural improvements described previously on physician diagnostic test ordering practices. In each study, the EHR-based intervention decreased the number of diagnostic tests ordered by physicians, suggesting that quality of care was improved through the decrease in overused health services.

The first study, ^45^ in which test charge data was displayed, showed an overall 14-percent decrease in the number of tests ordered by physicians per visit in the intervention group. Decreases were observed for both scheduled and for unscheduled visits. The multiphase design allowed additional conclusions to be made regarding the importance of maintaining the decision-support element as part of the structure of care. In the pre-intervention period, no differences in test ordering were noted. During the intervention period, physicians randomized to the decision support tool ordered 17 percent fewer tests. In the post-intervention period, after the decision support was removed from the EHR, physicians who had been in the intervention group ordered only 7 percent fewer tests than during baseline. This effect decrement suggests that the knowledge of costs the test physicians gained during the intervention was not sufficient to alter practice over time. Instead, it was the presence of the additional cost information within the structure of care that most affected performance.

The second study, ^46^ in which abnormal test result probabilities were displayed to providers, showed a 9 percent overall decrease in the number of tests ordered by physicians. Two tests, urinalysis and urine culture, which had been underused prior to the intervention, showed increases in ordering frequency (+14 percent and +27). However, for the other six, overused tests examined, decreases ranged from 4 percent (electrocardiogram) to 14 percent (chest x-ray). These findings suggest that providing point-of-care pretest probabilities via an EHR improves the quality of care processes by decreasing overused testing and by increasing the use of previously underused care.

The third study, ^47^ in which past abnormal test results were displayed, showed an overall 9-decrease in the number of tests ordered by physicians. As in the first study, data were analyzed in the post-intervention period to assess the persistence of the effect. After the EHR intervention was discontinued, the researchers observed a non-statistically significant 11-percent increase in the number of tests ordered (the post-intervention period time frame was not long enough for this trend to reach statistical significance).

Outcomes. In the first study, ^45^ the primary outcome was diagnostic test-related charges. Charges were 13 percent ($6.68 in 1988 dollars) lower per visit for the intervention group physicians than for the control group. Decreases in charges were directly due to the decrease in the number of tests ordered, i.e., the improvements in quality of care processes. Given the likelihood that the intervention reduced overused care, this outcome increases the efficiency of care delivery.

In the second study, ^46^ which used statistical models to predict whether any of eight commonly ordered diagnostic tests were likely to be abnormal, the primary outcome was financial charges for tests. Overall, charges decreased 9 percent ($1.09 in 1986 dollars). A technical outcome of the study was the operating characteristics of the statistical models used to predict lab test abnormalities, which were based on data collected and stored in the EHR. All predictive models for the study tests performed well, with receiver operating curve areas generally over 0.75 (range 0.66 to 0.92).

In the third study, ^47^ efficiency outcomes were also observed due to the decrease in the number of tests ordered. Charges for tests in the intervention group were 13 percent lower per visit (approximately $1.82 per visit in 1986 dollars).

#### EHR Systems in Use at Kaiser Permanente

Structure. Two studies came from regional medical centers in the Kaiser Permanente network, an integrated, not-for-profit, nonacademic healthcare delivery system.

In the first of these two studies, ^48^ comprehensive EHRs were implemented in two regions (Northwest and Colorado) of the enterprise. One EHR was internally developed (Colorado) and the other externally developed by a commercial vendor (Northwest). Although the EHR systems were different, both were reported to have comparable functionality, including the following: documentation, clinical results management, CPOE for both diagnostics and medications, administrative data management, and decision support. Specific decision support functions varied between the two sites in both content and scope.

The second of these two studies provided a brief qualitative description of structural changes associated with and supporting EHR implementation. Implementation was carried out gradually, in phases, beginning in discrete areas of the ambulatory care clinics. The majority of system implementation was completed within one year of initiation. The authors note that because of phased implementation, it was “some time” before changes in health care delivery were noted. (Data related to time course of impact will be discussed in the Outcomes section of this analysis.) No data on the specific organizational drivers for adoption were included.

Structural reorganization and improvements in workflow were described briefly. Prior to the implementation of EHR in each region, the presence of multiple ambulatory sites required paper records to be physically delivered. Paper charts were warehoused and had to be delivered “several miles.” For same-day and unscheduled ambulatory visits, availability of paper records was “unreliable.” After EHR implementation, use of paper charts was “essentially eliminated” and electronic patient charts became available for emergency room visits, unscheduled visits, and same-day appointments. Charts also became available for telephone contacts, and the resulting improvement in clinical workflow led to more effective utilization of telephone-based care, with physicians reporting that they were better able to address patient health issues over the phone when provided with access to electronic records. The authors cite this outcome as a primary reason for decreased office visits, one of the primary outcomes of the study.

In terms of time frame of impacts, little difference in services was noted during the first year of implementation (the authors reported system implementation was mostly completed one year after implementation began).

Evaluating the effects of EHR adoption was itself a form of structural change in this study. In order to determine appropriate utilization measures to assess the effect of EHR implementation, interviews were conducted with 100 individuals with a broad array of organizational roles. Interviews led the investigators to hypothesize that ambulatory care delivery had become more efficient by making needed information available during the initial episode of care, thus decreasing the need for follow-up visits and redundant services. Interviews also suggested that quality had improved. These hypotheses formed the basis for the selection of metrics and the quantitative evaluation done in the study (discussed in the Process and Outcome section of this analysis). No further details were provided regarding the data acquired from these interviews or the methodology used to conduct them.

The study design was a retrospective time-series analysis with data analyzed at one-year intervals before and after implementation. Baseline data were used from the three years prior to implementation. For the Kaiser Northwest site, four years of post-implementation data were available, whereas for Colorado, only two years of post-implementation data were available because of later implementation.

The second of the two studies, conducted in the Kaiser Northwest system, ^49^ examined the incorporation of guidelines through the EHR to support the decisionmaking process for ordering radiology tests and medications. The two-phase implementation process was described briefly. In the first, a read-only results reporting system that integrated data from departmental systems was implemented. In the second phase, the commercially developed EHR described above for the first Kaiser study was implemented. Together, both phases took approximately three years to complete. Per the authors, attempts were made to present guidelines to providers as efficiency aids that would streamline their workflow; the electronic guidelines were kept simple and integrated smoothly into existing procedures. Provider adherence to guidelines was not mandated; however, the electronic ordering system was designed to make adherence simple, and the guidelines were presented in text form without requiring explicit interaction. No further specific implementation-related information was provided in the paper for either the EHR or the guideline tools.

The study design was a time-series analysis that examined utilization patterns at multiple time points before and after guideline implementation.

Process. The first Kaiser study, ^48^ which examined the effects of EHR implementation at two sites in the Kaiser network, examined multiple processes of care.

Three quality indicators from the Health Plan Employer and Data Information Set (HEDIS) were chosen to assess quality. These items were chosen in part because their definitions remained consistent over the time period of the analysis. Each was a process-of-care measure: advice on smoking cessation, cervical cancer screening, and retinal eye examination. No statistically significant differences were found in performance on these process measures from the pre- to the post-implementation period.

However, multiple utilization-related processes were examined and showed considerable change after EHR implementation. In general, they suggest improvements in quality of care through a decrease in redundant health services. Age-adjusted rates of radiology test utilization decreased overall by 4 percent after EHR implementation. The authors note that over this same period, radiology service use increased within the Kaiser system as a whole and nationally as well (quantitative data not provided for either increase). Laboratory test utilization in one site decreased 18 percent four years post-implementation. However, utilization rates subsequently increased 5 to 7 percent annually. In the other site, the rate of laboratory test utilization had risen 14 percent prior to EHR implementation, but decreased by 3 percent over the two post-implementation years included in this study. Comparisons of laboratory utilization with other non-EHR sites in the network were not included in the analysis. The number of telephone encounters physicians scheduled with patients increased substantially after EHR implementation, rising from 1.3 telephone encounters per member per year to 2.1 telephone encounters per year. Per the authors, physicians qualitatively reported that telephone encounters were more effective because their capacity to resolve patient issues was enhanced by accessing the EHR.

The second Kaiser study ^49^ focused on processes of care-related adherence for two radiology tests and on formulary adherence for one medication, after guidelines were incorporated into the EHR.

Use of upper gastro intestinal (UGI) radiology testing decreased from 11 UGI per thousand members to 6 UGI per thousand members after guideline implementation (40-percent relative decrease). The number of chest x-rays ordered also decreased 20 percent. Prescription of a nonformulary medication for depression decreased from 4.7 percent of all selective serotonin reuptake inhibitors (SSRIs) to 2.4 percent (SSRIs are the most widely used class of medications for depression and multiple agents are available for prescription in this class). Noted effects were sustained over time. The analysis made no attempt to control for other factors that may have affected utilization of radiology testing or formulary adherence.

Outcome. Outcomes in the first Kaiser study related to efficiency and utilization. ^48^ The age-adjusted total office visits decreased by 9 percent in year 2 after initial implementation. Primary care visits decreased by 11 percent and specialty care visits decreased by approximately 5 percent, both of which were statistically significant. Reductions in visits held across patient cohorts, including those with the greatest baseline rates of visits. The number of patients making three or more visits decreased by approximately 10 percent between year 1 and year 2 post-implementation in the Northwest region and by 11 percent in Colorado. In year 4, a further decrease of 2 percent was noted in the Northwest region. No comment was made on whether these decreases in the high-volume use category were statistically significant. Direct comparisons with utilization at non-EHR sites were not possible because of inconsistent definitions of office visits. However, in three other network regions (all of which used independent definitions of a visit) for which visit utilization data were available for the same time period, no similar decreases were noted.

In terms of the statistical analysis, no strict control variables were included in the analysis. The following structural measures were reviewed separately to examine possible confounding: rates of ER visits, ratio of primary care providers to members, ratio of referrals to outside providers. Per the authors report, none changed significantly over the study time frame.

Appointments made for patients after doctor-managed telephone encounters decreased by 7 percent after the EHRs were implemented. However, when telephone contacts reverted to nurses, these appointments “rose” (no quantitative data provided).

#### EHR Systems in Use in the Netherlands

Structure. A single report details a large multisite study in the Netherlands in which the effects of two different types of EHR laboratory test order interfaces were examined. ^50^ Both sought to decrease the number of laboratory tests ordered by providers by presenting a limited set of tests on the primary laboratory order screen in the EHR. While all available tests in a laboratory system cannot usually be presented at once on a computer screen, these interventions did not allow screen size or human factor constraints to dictate which test options were initially made available to providers. Instead, they presented considerably smaller sets of choices. Thus, both interfaces changed provider workflow considerably when compared to paper or to nonrestrictive EHR order interfaces. Although providers could order any tests they wanted, any test not explicitly present on the EHR laboratory screen required additional search time to find and call up.

In one experimental condition, statistical probability was used to select the fifteen most commonly ordered tests overall to present to a provider on the initial order interface. In the other condition, the tests presented to providers depended on the patient's specific diagnosis. Diagnosis-specific tests were presented electronically, based on recommendations from existing guidelines. This intervention altered provider workflow to a greater extent than did the first intervention. First, a menu of guidelines/indications was presented, from which the provider had to select those most relevant to the patient's conditions. Based on the indications for testing entered by the provider, the EHR picked the most relevant to present as possible options for ordering. The guideline set was not comprehensive for all possible tests, and all possible indications for a test were not included in the electronic guidelines. Physicians could override recommended tests and order nonrecommended tests at their discretion by entering, “other indication.”

All physician practices in the sample were already using EHRs at the time of the proposed laboratory-ordering intervention. However, prior to the intervention, lab tests were ordered through structured paper-based order forms. All practices in the region using EHRs were offered the opportunity to participate in the experiment and add one of the electronic lab ordering functionalities to their systems. Of 64 practices, 46 (72 percent) agreed. Sixty-two general practitioners worked at those 46 sites. A three-month implementation period was included to familiarize the physicians with the software. Over the course of the study, four practitioners withdrew: one solo practitioner withdrew because the software decreased the performance of his computer, another withdrew because of dissatisfaction with the system, and two other physicians in the same practice withdrew for unspecified reasons. Thus, complete data were available for 44 practices, representing 60 physicians.

Physicians were still left with the option of using paper order forms during the study. In the non-guideline specified cohort, 88 percent of all orders were entered through the software. In the guideline-based electronic order cohort, 71 percent of all tests were ordered through the software. Final data analysis included total lab tests ordered both electronically and through paper forms.

Process. This study ^50^ focused primarily on process change: examining the effect of changes in information presentation on test ordering. Physicians randomized to the guideline-based interface ordered 1.4 percent fewer lab tests (5.5 vs. 6.9) than did physicians presented with the list of most commonly ordered tests. This difference translated into a relative decrease of 20 percent in tests ordered. The 20 most commonly ordered tests accounted for 80 percent of all tests. No data on human factors issues or usability were reported. Such data may have been informative, given the different workflows created by each intervention. Further supporting the potential utility of such data are the different rates of use for each software package (in the guideline cohort, 71 percent of all tests were ordered through the software and 29 percent through paper; in the other cohort, 88 percent of all tests were ordered through the software and the remaining 12 percent through paper).

Outcomes. No outcomes were reported for this study. ^50^

#### EHR Systems in Use at Beth Israel Deaconess Medical Center (Boston MA)

Structure. The last EHR study was conducted at the ambulatory care medicine practice at the Beth Israel Deaconess Medical Center in Boston, an academic medical center. ^51^ Development of their clinical computing system began in the 1970s and was internal. System functionality at the time of the study included documentation, results management, order entry, decision support administrative data management, and electronic communication through email. Electronic documentation and results management capabilities were available through the Internet.

The goal of the study, which began in 1990, was to improve quality of outpatient HIV care by incorporating guideline-based alerts and alarms into the system. At the time of the study, no national consensus guideline on HIV care existed. Thus, as a first step, a set of guidelines was developed internally by a panel of local experts. The guidelines were then automated and incorporated into the EHR.

The alerts and alarms created new provider workflows when compared to a paper-based system. Decision support was given to providers on-line and without provider prompting. Clinicians were given the opportunity to act on the alerts and reminders as they appeared, by sending electronic messages for orders to be executed. The system also allowed providers to decline recommendations; and space was included in the EHR to document the reason. The workflow for each of those options differed. Alerts popped up each time a provider logged on, regardless of the patient being seen or reason for accessing the system. Reminders were shown only at the time of the patient visit. This study, which was conducted over 18 months (from 1992 to 1993), used a controlled clinical trial design. Five practice sites were involved. Coin flips were used to assign practices to the intervention or the control condition. All clinicians at a site were assigned to the same condition over the course of the study. The total sample included 22 providers.

Process. The purpose of this study ^51^ was to assess the effects on processes of care of incorporating electronic guidelines for outpatient HIV care into the EHR. One year after implementation of the EHR guidelines, the number of eligible patients receiving recommended HIV care in the alerts intervention group was 85 percent vs. 64 percent in the control group. At three months post-implementation enhanced utilization of appropriate services was noted for all measures, including ordering CD4 counts (82 percent vs. 60 percent), starting AZT or DDI when appropriate (86 percent vs. 65 percent), modifying AZT dose (76 percent vs. 62 percent), PCP prophylaxis (88 percent vs. 42 percent), and complete blood counts (89 percent vs. 65 percent). All findings were statistically significant to a p value of 0.05 except for starting AZT/DDI or changing the AZT dose. The median response time for a provider to order appropriate services in response to new clinical information was 11 days in the intervention group and 52 days in the control group.

At one year, the number of eligible patients receiving recommended HIV care in the reminders intervention group was significantly greater than in the control group (68 percent versus 46 percent). Processes of care examined included pneumovax receipt (82 percent vs. 38 percent), TB skin testing (78 percent vs. 62 percent), H. influenza vaccination (41 percent vs. 25 percent), tetanus vaccination (31 percent vs. 17 percent), and referrals to ophthalmology (75 percent vs. 46 percent) (p values were less than 0.05 for all results except TB testing, for which p=0.07 and tetanus vaccination, for which p=0.1). At one year, toxoplasmosis titers were drawn on an equivalent percent of patients (82 percent vs. 81 percent). However, the median response time in the intervention group was 8 days vs. 168 days for the control group. No differences in cervical cancer screening were noted. In the intervention group, the median time for a provider to act on clinical information to order appropriate services was 114 days vs. more than 500 days in the control group.

In the intervention patient cohort, 303 alerts and 432 reminders were generated and sent to clinicians. In the control group, 388 alerts and 360 reminders would have been sent to providers.

Outcome. This study ^51^ examined rates of visits to primary care, rates of hospitalizations, visits to emergency rooms or walk-in clinics. No statistically significant differences were observed. Rates of pneumocystic disease and one-year mortality also showed no differences.

### Conclusions

The studies reviewed in this analysis illustrate a range of ways in which ambulatory EHRs can serve to improve quality of care. In particular, they demonstrate how provider performance can be improved when the clinical information management and decision support tools are available within an EHR system. A recurrent theme in these studies was the capacity of EHRs to store data with high fidelity, to make those data readily accessible, and to help translate them into context-specific information that can empower providers in their work.

This analysis is limited by a number of factors. The small number of studies included in the sample was largely a function of the search criteria. In particular, few systems with the core EHR functionalities of documentation, results management, provider order entry, and decision support have been examined, particularly for commercially developed products. These functional criteria were chosen to make the analysis more pertinent to decisionmakers currently considering EHR adoption. Because of the rapid technical advances in EHR, many of the studies of EHR systems are out of date. This review has focused on EHRs with these core functionalities in order to provide decisionmakers with an overview of the evidence that is most likely to be pertinent to the choices they are making now. Another major limitation is the lack of description (and data) pertaining to the workflow reengineering and organizational change that were required for EHR use. As discussed earlier, the “intervention” in these studies is not only the EHR system but also the manner in which these systems change the way healthcare professionals work, organizations function, and consumers receive care. This information is highly context-specific, and for the findings of research on EHRs to be more widely generalizable, this part of the “intervention” needs to be characterized, described, and measured more accurately and comprehensibly. Without such process implementation data, the applicability of findings from one context to another will be a barrier to informed decisionmaking.

## Economic Value of an Electronic Health Record Systems and Health Information Technology Applications

Consumers of the healthcare system, including government in the United States, employers, and patients, are demanding higher quality, safety, consistency, efficiency, and value. In order to meet these demands, interoperable computerized health information technology, especially an EHR system that documents patient care processes and outcomes across the continuum of care, is widely believed to be a critical tool. Ideal use of an EHR system enables improved capture and integration of patient information from diverse sources and allows clinicians to access longitudinal patient-specific information for clinical decisionmaking and disease management. Other commonly used terms referring to aspects of an EHR system include personal health record and electronic medical records. In this review, EHR refers to a HIT element that performs the functions of electronic recording, storage, accessing, and viewing of patient medical information.^52^–^55^ An EHR system is a computer application with EHR functionality at minimum. Often, financial data are also included in such a system. Since the system is designed to be used institution-wide to replace paper-based medical records and to aid the efficiency of healthcare processes, many EHR applications also contain other system functions, including prescription and test ordering, care management reminders, and other clinical decision-support capabilities. While the EHR is considered essential technology for improving efficiency and quality of health care, implementation of an EHR system requires substantial capital investments and organizational change. Consequently, many health care organizations are seeking evidence and lessons learned about the costs and benefits of EHR adoption in order to better inform decisions about the timing and strategy for implementation.

EHR is the second most common HIT element among the articles identified that contain economic data. Our literature search identified 92 hypothesis-testing or predictive analysis articles containing information on costs, utilization, or efficiency. Of these, 32 studies assessed a HIT system in which EHR was one of the major system elements. However, only nine articles quantitatively assessed the economic value of an EHR system as a whole. We discuss these articles in further detail below. Most of the remaining studies were tests of certain nonfinancial hypotheses or examination of a subset of functionality, such as decision support, instead of the entire EHR system. Although these studies do not assess the costs and benefits of the entire system, they provide indirect, often empirical, evidence that can support the economic appraisal of the value of an EHR system. Before we begin the review of the nine articles, we first summarize the main findings of the remaining studies. Interested readers are referred to our interactive evidence database to learn more about these studies (http://healthit.ahrq.gov/tools/rand).

### Summary of Key Findings from Non-Financially Focused Studies

Among its other functions, an EHR system can facilitate automatic generation of patient reminders for preventive services, screening, and disease management. Five Canadian studies used the same EHR system to generate patient reminders and compared the effectiveness and cost-effectiveness of three strategies—physician reminders, telephone reminders, or letter reminders—to remind patients to get preventive services. ^56^ – ^60^ All forms of reminders were effective, with reminders delivered directly to patients being somewhat more effective than reminders to physicians. Another study used computerized pharmacy records to generate patient feedback and compared the effectiveness and cost-effectiveness of two depression care programs. ^61^ Feedback with care management was significantly better than feedback alone.

Electronic charting is a feature of EHR that has been reported to affect provider productivity. ^62^ – ^65^ These studies found that the time needed for development of care plans and documentation initially increased, but preparation time decreased subsequently. The initial loss of productivity was associated with the baseline computer skills of the users (clinicians). Two studies assessed computerized documentation systems used for the ICU. ^66,^ ^67^ The authors of the first study asserted that addition of their computer-based nursing documentation required no specific ICU software or bedside workstations because it was implemented in a well-networked information technology environment. ^66^ Thus, they found that compared with paper charting, their electronic charting system was relatively inexpensive (although the figures were not provided). In addition, the documentation was more complete because of the presence of reminders for missing entries, and data quality remarkably improved. The other study used work sampling and cost analysis methodologies to show net savings of a vendor-developed bedside documentation system specifically designed for an ICU. ^67^

Another potential benefit of EHR systems is avoidance of morbidity because of improved patient safety. One study of ADEs found that building ADE detection and reporting capability into EHR can improve detection and potential reduction of ADE in hospital settings because of the ability of the EHR system to easily identify and confirm patients experiencing ADEs and thus enabled early intervention. ^68^ Several studies have shown that severe ADEs were associated with longer hospitalizations and higher hospitalization costs (over $2,000 in 2005 dollars). ^68^ – ^70^

Several studies investigated the impact of point-of-care alerts and reminders imbedded within an EHR system during the process of documentation or entry of orders into the system. ^45,^ ^47,^ ^71^ – ^76^ These decision-support functions within an EHR system, when accompanied by the required changes in process and communication, altered physicians' ordering behaviors by facilitating appropriate resource utilization and reducing unnecessary charges. ^45,^ ^47,^ ^71^ – ^76^ For example, one study estimated that reducing the ordering of redundant clinical laboratory tests could produce an annual savings of $35,000 in laboratory charges. ^72^ A randomized controlled trial that tested the effect of immediately printed summaries of a computerized medical record on physician test ordering rates in an emergency room setting ^77^ showed significant improvement in the cost-effectiveness of internists' ordering behaviors. The impact on surgeons' ordering patterns was positive but not significant.

Some EHR systems offer sophisticated CPOE and decision-support functionality. A randomized controlled trial found positive effects of an EHR with integrated CPOE on resource utilization, provider productivity, and care efficiency. ^78^ Two additional studies showed that an EHR with integrated decision support helped providers improve the quality of documentation, clinical decisionmaking, and guideline compliance, and resulted in reduced utilization of services and costs of care. ^76,^ ^79^ However, another study found that implementation of clinical guidelines via an EHR had no significant effect on clinical outcomes or healthcare costs. ^30^ The benefits of information technology seem to depend greatly on the quality of the implementation and the level and type of decision-support technology.

### Analytic Methods to Assess the Economic Value of an EHR System

This section provides a more detailed review of the nine articles that quantitatively assessed the economic value of an EHR system, including summaries of the analytic methods used in the studies. Two articles by the same author described the same ambulatory EHR system, although the economic estimates differ slightly between articles. ^53,^ ^54^ Therefore, we refer to them as one study described in two articles. Of the remaining seven articles, four report on evaluations of the economics of an EHR system: two in the ambulatory care setting ^52,^ ^80^ and two in an integrated delivery network (IDN) (an IDN comprises providers—both inpatient and outpatient—as well as payers and purchasers, in one connected managed care organization). ^81,^ ^55^ Another study concerns health care information exchange and interoperability, ^82^ and the remaining two are methodological papers. ^83,^ ^84^ A brief summary of the methods and findings of these studies is presented in Table 1.

To assess the value of EHR, one methodological paper described a return-on-investment framework to evaluate the costs and benefits of implementing an ambulatory EHR system, and another presented a spreadsheet tool to help family physicians estimate the costs of implementing an EHR system. Both reports provided illustrative examples. Of the remaining six studies, five used cost-benefit analysis ^52^ – ^55,^ ^81,^ ^82^ and one used cost-consequence analysis. ^80^ All the cost-benefit analyses adopted the ROI framework, which assesses the difference between the costs of an EHR investment and the benefits reaped from it. In these studies, both costs and benefits are quantified in monetary terms to the extent the authors determined was feasible. For example, one study aimed to justify the cost of EHR by first identifying the goals of the system in order to determine benefits. ^55^ To quantify benefits, the authors then performed an extensive literature review, surveyed other institutions that were implementing EHR, interviewed EHR vendors, and conducted process-mapping sessions to identify potential cost savings on work processes affected by EHR. However, cost estimation was based largely on vendor response to a request for information or on current information system costs in the healthcare organization. ^52,^ ^80^ The cost-consequence study showed costs in monetary terms but did not quantify the benefits of EHR except for time saved from chart pulling. ^80^ All studies except two used the perspective of an organization, either outpatient settings ^52^ – ^54,^ ^83,^ ^84^ or IDN. ^55,^ ^81^ Of the other two studies, one adopted a societal perspective, ^80^ and the other used multiple perspectives, from organization level to national level. ^82^

Six studies reported their data sources. ^52,^ ^55,^ ^80^ – ^83^ All used multiple data sources, including primary data collected from an existing EHR system, ^52^ published data, ^52,^ ^55,^ ^82,^ ^83^ workplace and demonstration site observations, ^80,^ ^81^ and surveys or interviews of key informants or EHR users. ^55,^ ^80^ Experts were a primary source of data for some studies, ^52,^ ^81,^ ^82^ as were vendors. ^55,^ ^81^ One study also used process-mapping sessions. ^55^

Cost and benefit variables used in each study are listed in Table 1. The cost variables included in most studies included hardware and network acquisition, software licensing, ongoing technical support and maintenance, and training and other implementation costs. Costs associated with temporary productivity loss due to the EHR implementation were captured by two studies, ^52,^ ^80^ but a third study assumed no cost associated with loss of productivity, given a long-term EHR implementation strategy. ^81^ Other cost variables include installation (which was not quantified in greater detail), ^83^ data entry, ^84^ printing, ^53,^ ^54^ system integration in IDN setting, ^55^ personnel, ^53,^ ^54^ and institutional and project management. ^55,^ ^80^ The health care information exchange and interoperability study also included interface development cost.

The benefit variables included the following: savings from chart pull and transcription; ^52,^ ^80^ – ^83^ time saved to document diagnostic codes; ^81,^ ^83^ prevention of ADEs; ^52^ reduction in drug ^52,^ ^81^ laboratory, ^52,^ ^81^ or radiology costs; ^52,^ ^81^ improvement of charge capture; ^52,^ ^81^ decreased billing errors; ^52^ personnel and space savings from reduced existing and future medical record storage requirements; ^53,^ ^54^ as well as automated generation of clinical forms, ^53,^ ^54^ pharmacy information, ^81^ and billing data generation. ^53,^ ^54^ One study provided a comprehensive list of potential benefits grouped into four categories: data capture and access, decision support, business management, and streamlining patient flow. ^55^ The health care information exchange and interoperability study reported quantifiable benefits from health information connectivity for providers, payers, and other stakeholders, including radiology centers, laboratories, pharmacies, and public health departments. ^82^ Three studies showed the net ROI. ^55,^ ^82^

Various analytic designs were used, although the reference strategy was always the traditional paper-based medical record. One study assessed the economic value of an EHR system concurrently with its implementation and reported the first-year economic consequences of the system. ^80^ Another study predicted a fixed annual savings and expenses based on seven years of EHR implementation experiences in a HMO. ^53,^ ^54^ Yet another study constructed a hypothetical primary care provider patient panel using average statistics from one of the nation's leading organizations in EHR implementation. ^52^ Both studies of EHR systems in IDN settings are analytic predictions because EHR had not been implemented in the studied organizations. ^55,^ ^81^ The health care information exchange and interoperability study for a fully standardized nationwide system is also an analytic prediction based on a conceptual framework describing how health care entities share information and a functional taxonomy reflecting the amount of human involvement required, the sophistication of IT, and the level of standardization. ^82^ Sensitivity analyses were performed in three studies. ^52,^ ^80,^ ^82^

### Evidence of Economic Costs and Benefits of an EHR System

Our interactive evidence database (http://healthit.ahrq.gov/tools/rand) provides a structured abstract for each of the nine identified studies regarding the costs and benefits of EHR. Main findings are highlighted in Table 1 and summarized below.

Costs of Implementing an EHR System. Five studies quantitatively assessed the costs of implementing an EHR system. ^52^ – ^55,^ ^80,^ ^81^ The costs can be divided into two categories: (1) cost of the system itself (hardware, software, license, maintenance, and support) and (2) implementation cost (training, temporary loss of productivity, etc.). The costs vary significantly by the scale of the healthcare organization and the functionality of the EHR system.

(1) Cost of an EHR System. One study estimated the system costs for an ambulatory EHR to be $9,700 per provider (in 2002 dollars), which included $1,600 for the annual software license, $1,500 for annual support and maintenance, and $6,600 for hardware (three computers and network, refreshed every three years). ^52^ The estimate was for a hypothetical primary care provider office and was modeled after a well-developed and widely used EHR system at a leading IDN health care system. The component parts of the EHR system include online patient charts, electronic prescribing, laboratory order entry, radiology order entry, and electronic charge capture.

In a Swedish primary health care setting with 50 staff, the system cost of a vendor-developed EHR system was estimated to be $240,000 in the first year (in 1995 U.S. dollars). ^80^ The EHR system supported full-text patient records and included a controlled medical terminology, a structured patient database, and tools for the analysis and reporting of patient data. The hardware at the sites comprised one server supporting approximately 40 workstations and 20 printers.

In a large HMO with 13 outpatient care locations in Ohio, a homegrown ambulatory EHR was estimated to have had a system development cost of $10 million (in 1996 dollars) and additional annual expenses of $630,000 (in 1996 dollars) for printing, network expenses, memory, and license renewals. ^53,^ ^54^ The EHR system was used routinely by 220 physicians and 110 allied health professionals. It implemented an encounter system that collected and presented such medical data elements as diagnoses, allergies, medications prescribed, immunizations, vital signs, and smoking status at the time of an encounter. The system also generated physician reminders for guideline compliance and patient reminders for preventive services and was linked to centralized clinical data on the mainframe, such as laboratory results, radiology reports, emergency department notes, and hospital discharge summaries.

An academic cancer center with a staff of about 8000 and facilities that included a hospital, outpatient clinics, and remote patient-care sites was interested in implementing an EHR for its IDN as both a clinical and financial information management tool in 1994. The cost estimates for vendor-developed EHR systems to meet the center's organizational needs ranged from $15.8 million to $21 million (in 1994 dollars), which included costs of hardware, software, interface development, network cost, data conversion, training, and annual maintenance. ^55^ Additionally, the annual support costs were estimated to range from $3.8 million to $5.3 million.

A 2002 study estimated the costs of implementing an EHR ^81^ for an IDN that included a medical center with a 280-bed acute care hospital, 16 hospital-based and satellite outpatient clinics, a research institute, and a network of about 400 employed physicians. A vendor-developed EHR was estimated to cost approximately $19 million (in 2001 dollars) for the seven-year implementation period. This included costs for the various software products, server hardware, professional services related to installation and training, as well as desktop devices, monitors, biometric security devices, imaging hardware and software, additional technical-support staff, and other associated costs.

(2) Cost of the Implementation Process. Only two studies provided an estimate of costs associated with the EHR implementation process. Both were for ambulatory settings. ^52,^ ^80^ One estimated an implementation cost of $3,400 per provider (in 2002 dollars) in the first year associated with workflow process redesign, training, and historical paper chart abstracting. ^52^ It also estimated a revenue loss of $11,200 in the first year due to temporary loss of productivity. The total implementation process cost, $14,600 per provider, is 1.5 times the estimated EHR system cost.

The Swedish study used a societal perspective and included costs of training and unexpected costs pertained to self-training during working hours, loss of normal activities in leisure hours, increase in administrative work load, extra service, and medical records summary. ^80^ These costs were estimated at $75,000 (in 1995 U.S. dollars), approximately 30 percent of the EHR system cost.

A third study projected the costs of implementing health care information exchange and interoperability where EHR is a requirement for Levels 3 and 4 implementation, ^82^ which, according to the authors' taxonomy, refers to the ability to handle machine-organizable data and machine-interpretable data, respectively. The authors projected costs for multiple stakeholders of the healthcare system for Levels 3 and 4 health care information exchange and interoperability. The national ten-year rollout cost of Levels 3 and 4 were estimated to be $320 billion and $276 billion, respectively. Additionally, the national ten-year annual costs were estimated at $20.2 billion and $16.5 billion, respectively.

Quantified Benefits from an EHR System. Benefits of an EHR system or health care information exchange and interoperability were also quantified in the six studies that assessed the cost of implementing such a system.

One study was based on the Partners HealthCare ambulatory EHR, which not only provided health information and data storage capability but also possessed results management, order entry management, point-of-care decision support, and administrative information management functionalities. Therefore, many benefits were expected. The study divided the benefits into three categories: (1) payer-independent benefits, including savings from chart pulls and transcription; (2) benefits under capitated reimbursement, including averted costs from ADEs, drug utilization, laboratory utilization, and radiology utilization; and (3) benefits under fee-for-service reimbursement, including improvement in charge capture and decreased billing errors. ^52^ The authors predicted that savings from chart pulls and transcription would be seen immediately after the EHR implementation, and costs associated with ADEs and drug utilization could be averted from second year on, but other potential savings would not be realized until the fourth year. Five-year total benefits of an EHR implementation were estimated to be $129,300 per provider (in 2002 dollars), or a net savings of $86,400 per provider (in 2002 dollars). Sensitivity analyses showed that the estimates were sensitive to the assumption of the proportion of patients whose care was capitated. The net financial value could range from a $2,300 net cost to a $330,900 net benefit per provider.

The Swedish study examined an EHR system with functionality limited only to health information and data storage. Therefore, the expected benefits were limited and included increase in knowledge capital for the primary health care team, easier and quicker communication for general practitioners during telephone consultations, clearer information to patients, and time saved in retrieving paper-based medical records. ^80^ Only the value of the last item was estimated, at a total of approximately $10,500 (in U.S. 1995 dollars) for the first year of EHR implementation.

Despite potential savings from ADE prevention and reduced resource utilization under capitated reimbursement, the study of the ambulatory EHR system in a HMO (13 outpatient clinics) did not quantify this aspect of benefits. Instead, it quantified only the averted costs associated with improved efficiency. ^53,^ ^54^ The study estimated an annual savings of $3,700,000 (in 1996 dollars) from reduced medical record room and support staff, elimination of clinical forms, and automatic collection of billing data.

The cancer center study projected the benefits of an EHR over ten years. ^55^ This projection made several key assumptions, including no benefit until the third year after implementation, benefits to phase-in as the EHR system became functional, physician acceptance and use of the system, a link between business management benefits and managed care, and productivity changes. The authors divided the benefits into capture and access, decision support, optimization of clinical practice, business management, and streamlining of patient flow. The estimated total quantified benefits were $129.69 million over ten years. Adjusted by the total implementation and system costs, the authors' assigned confidence factor, and 9.5-percent discount rate, the net value was predicted to be $24.9 million (in 1994 dollars).

The other IDN expected even greater benefits from an EHR implementation. The authors predicted approximately $68.5 million in gross quantifiable benefits over a seven-year period; subtracting the cost of the EHR system implementation, the net benefit would be $31.4 million (in 2001 dollars), using a 10-percent discount rate. ^81^ The authors predicted and quantified benefits from savings in laboratory and radiology order entry, pharmacy order entry, documentation availability of information, and charge capture.

Another study estimated that implementation of a standardized interoperable EHR system by all healthcare organizations in the United States would yield substantial financial benefits. The health care information exchange and interoperability study predicted that investment on a fully standardized, Level-4 nationwide system will have the most financial return, a net value of $77.8 billion per year once fully implemented. ^82^ Non-standardized health care information exchange and interoperability also can have positive financial returns, but the returns are smaller compared to the Level-4 implementation.

In summary, despite the heterogeneity in the analytic methods used, all five cost-benefit analyses predicted substantial savings from EHR (and health care information exchange and interoperability) implementation. ^52^ – ^55,^ ^81,^ ^82^ In other words, the quantifiable benefits are projected to outweigh the investment costs. However, the predicted time needed to break even varied from three ^52,^ ^81^ to six ^55^ to perhaps as long as 13 years. ^54^

Conclusion. Our evidence review found consistent predictions from five cost-benefit studies that implementation of an EHR system can be financially viable at the individual organization level or through a nationwide implementation with high levels of health care information exchange and interoperability. ^52^ – ^55,^ ^81,^ ^82^ However, there are several caveats.

1. All studies are predictive analyses that are based on many analytical assumptions and limited empirical data. The strength of evidence is considered weak.
2. In all studies, the EHR system was assumed to have multiple functionalities that include, at minimum, health information and data storage, administrative processes, decision support, and results management, as well as information exchange capabilities. The functional capability of an EHR system is critical to the benefit accrued.
3. The individual organizations that were the subjects of four studies were all large organizations. Large organizations involve many people, units, and subsystems and have complicated processes and interactions. They can benefit greatly from automated, transparent information processing through HIT, and substantial economies of scale. The literature review did not identify cost-benefit studies for EHR implementation in small organizations.
4. The costs of implementing an EHR system may be underestimated. Only one of the five cost-benefit analyses included the cost of the implementation process, ^52^ and it found that this cost was 1.5 times the cost of the EHR system. Implementing an EHR system requires extensive changes in the organizational processes, individual behaviors, and the interactions between the two. These resulting costs are often omitted or not reported from studies but can be substantial.
5. The financial benefits depend on the financing system. As shown in the sensitivity analysis of one study, ^52^ the benefit estimates are most sensitive to the assumption of the proportion of capitated patients. Realizing all quantifiable benefits of EHR implementation would require changes to the current health care financing system.
6. Both the cost and the benefit of attaining interoperability among EHR systems are directly proportional to the level of data exchange achieved. For example, the cost of achieving machine-organizable (Level 3) or machine-interpretable (Level 4) interoperability is greatest, but it offers the most potential for increased efficiency, improved healthcare utilization, and reduced costs.

In conclusion, there is some empirical evidence to support the positive economic value of an EHR system and the component parts of EHRs. However, realizing the projected benefits will require proper alignment of the healthcare financing system, strong leadership, effective implementation strategies, and focused efforts to successfully adapt the EHR system.

## Health Information Technology and Patient Centeredness

Many advocates of HIT believe that one of its primary goals is to increase the extent to which the patient is at the center of his or her health care. For this report, studies of HIT and “patient centeredness” were defined as those that assessed HIT systems that included the element of patient decision support/consumer health informatics, telemedicine, or data-exchange/community health information networks or that reported patient satisfaction as an outcome. From the database of 256 articles there were 34 unique studies or systematic reviews meeting these criteria.

Ten studies assessed computer-generated reminders. Of these, seven assessed the use of reminder programs to improve the delivery of preventive care such as mammography and immunizations.^27,^ ^85^–^90^ All studies reported greater use of preventive services by patients—or the physicians of patients—who received computer-generated reminders. Two other studies assessed the effect of computer-supported or -generated reminder systems for refilling medications, ^91,^ ^92^ neither of which reported statistically significant improvements in compliance. A third study assessed the effect of a computer-generated reminder chart on patients' compliance with drug regimens, which reported significant improvements in mean compliance score for patients receiving an automatically generated reminder chart.^93^

Seven original studies evaluated various aspects of telemedicine, and a review article assessed the role of telemedicine in surgery.^94^ In the context of surgery, telemedicine included tele-mentoring, tele-proctoring, tele-conferencing, and tele-presence surgery, all of which are designed to allow physicians to communicate and improve the technical delivery of remote surgical procedures. Thus, this article was not considered relevant to patient centeredness. Five studies assessed telemedicine in particular contexts, including the intensive care unit, ^95^ the control of essential hypertension, ^96^ the evaluation of patients in an outpatient pulmonary clinic, ^97^ the role of telemedicine as one component of HIT and its importance to child safety, ^98^ and the use of a remote video system that allowed nurses and patients to interact in real time for patients with a variety of health conditions.^99^ All of these articles reported benefits from the use of telemedicine technologies. The last article in this group was an assessment of ComputerLink, which was conceived as an alternative to traditional caregiver support services such as support groups and health education programs. It was tested in a 12-month randomized trial in family caregivers of people with Alzheimer's disease. Compared with the control group that did not have access to ComputerLink, caregivers in the experimental group reported more improvement in caregiver strain.^100^

Three studies assessed the effect on patient trust and satisfaction of some aspects of HIT that are used during a patient consultation. In a pre-post study of general surgical patients, 96 percent of patients stated that their contact with a doctor was as easy and as personal after installation of a computer in the office as before the installation.^101^ In a controlled trial, the use of an automatic voice recognition system for transcribing progress notes was not associated with any significant negative effect on patient satisfaction, and was associated with some positive effects in terms of preventive maintenance and patient education.^102^ We also identified a study that assessed the effects of a nursing module used at the point of care. In this time-series study, an integrated, menu-driven electronic health record was associated with marked increases in nursing documentation and no effect on patient satisfaction.^103^ One study assessed physician satisfaction, and was excluded.^104^

Two studies assessed the effect of computer-guided management of patients. The first study compared the effect of computer-controlled administration of analgesic for post-operative pain to that of patient-controlled administration. The computer-controlled infusion used custom-written software designed to rapidly attain and maintain a theoretical target plasma concentration of the analgesic. In a double-blind randomized trial, the study found that computer-controlled analgesia conferred a more rapid onset of pain relief and was as effective as patient-controlled administration in providing post-operative analgesia.^105^ Which of these interventions is more “patient-centric” may be debatable, however. In the other study, computer-guided behavioral therapy that allowed patients to progress through a self-paced workbook was compared with clinician-directed behavioral therapy and with relaxation therapy in a randomized trial of patients with obsessive-compulsive disorder. At ten weeks, the Yale-Brown obsessive-compulsive scale showed significantly greater improvement in the patients receiving clinician-guided behavior therapy than in the group receiving computer-guided behavior therapy, and both of these were significantly greater than the improvement attained with relaxation therapy, which was found to be essentially ineffective. This study concluded that computer-guided behavior therapy was effective and might be a helpful first step in treating patients with obsessive-compulsive disorder when clinical-guided behavior therapy was unavailable.^106^

Five studies assessed various aspects of consumer health informatics. The interventions included a clinical trial of an interactive computerized patient education system in family practice;^107^ and assessments of the effects of computer tailored smoking cessation in family practice, ^108^ the effectiveness of a computer-generated patient health summary in changing patients' knowledge, attitudes, and behavior concerning health promotion, ^109^ and the use of self-administered computerized assessments for psychiatric disorders in patients in primary care.^110^ All of these studies reported benefits of the computerized health informatics system. A review of 37 studies of computer-generated health behavior interventions intended to motivate individuals to adopt various treatment regimens concluded that such systems are effective.^111^

Two review articles assessed the effect of various HIT systems that are directly accessed by the consumer or patient. One of the reviews assessed ten comparative studies of consumers using the Internet to access health information and services. This review included controlled studies, before-and-after studies, and interrupted time-series analyses of Internet users versus nonusers, or of the use of the Internet versus other communication media. The authors concluded that rigorous research regarding the effects of consumer Internet use on health outcomes is lacking. In the ten studies they assessed, all showed some beneficial effects on health outcomes, although the authors note the methodological quality of many studies was poor.^112^ A second review article assessed comparative studies evaluating the health or social outcomes of virtual peer-to-peer communities, which they characterized as a type of electronic support group. Among 45 publications describing 38 studies (of which 20 were randomized trials), only six evaluated “pure” peer-to-peer communities without other interventions. The other studies assessed complex interventions, of which a peer-to-peer community was only one component. The authors concluded that no good evidence exists on the effects of consumer-led peer-to-peer communities, partly because most such interventions have been evaluated only as part of a complex intervention or interventions involving health professionals.^113^

One review article assessed what is known about email consultations in healthcare. The authors noted that a rapidly expanding proportion of the population has access to email and that, while email consultations have the potential to play an important role in the delivery of preventive health care and facilitation of self-management of chronic disorders, there is little evidence from controlled trials that this potential benefit can be translated to routine clinical care.^114^

Another review article assessed studies of “electronic communication with patients,” which was defined to include studies of computerized communication, telephone follow-up and counseling, telephone reminders, interactive telephone systems, telephone access, and telephone screening. This article concluded that distance medicine technology has benefits in the areas of preventive care, management of osteoarthritis, cardiac rehabilitation, and diabetes care and that “distance medicine technology enables greater continuity of care by improving access and supporting the coordination of activities by a clinician.”^115^

Last, two studies dealt with data exchange networks or community health information networks. One study described the experience of developers of an electronic laboratory reporting system.^116^ In the second study, researchers developed a cost-benefit model and used published evidence and expert opinion to assess the ten-year rollout and annual cost of healthcare information exchange and interoperability, a development that would allow providers to access patient health care information in any clinical setting. The researchers concluded that a fully standardized interoperable system could save $77.8 billion a year, once fully implemented.^82^

In summary, evidence for an effect of HIT on patient-centeredness in health care is sparse. The best evidence is the beneficial effect of using computerized patient reminders for preventive care. The evidence for benefits of telemedicine and consumer health informatics is also limited to specific contexts. Finally, the evidence is much more limited for effects of more general interactive HIT (such as the internet or email on health) or the effect of implementing HIT systems (such as the electronic health record) on patient trust and satisfaction.

## Barriers to HIT Implementation

All studies initially reviewed were screened for data on barriers to adoption and implementation. For this analysis, qualitative studies that were primarily focused on barriers and studies that collected quantitative data on barriers were included. Studies in which barriers were briefly discussed, but were not a primary focus, were excluded. A primary focus on barriers was identified through reviewer consensus.

We identified 20 publications that focused on the barriers to implementing HIT. Of these, 8 reported the actual or potential barriers encountered with specific HIT implementations, ^55,^ ^62,^ ^116^–^124^ usually as part of an article discussing the implementation. Two articles were short opinion pieces about potential barriers from the physician perspective.^125,^ ^126^ Two studies assessed the physician time for order entry using CPOE compared to paper methods;^118,^ ^127^ both demonstrated that CPOE took more physician time, although the study by Overhage and colleagues found this additional time to be modest. A third study assessed the effect on primary care physicians' time before and after implementation of an EHR system and reported that the time for a patient visit actually fell by half a minute with EHR use.^128^ Last, one study compared physician user satisfaction with two HIT systems: the VA CPRS system and the Mt. Sinai hospital physician order entry system. This study demonstrated CPRS users to be much more satisfied than Mt. Sinai hospital users on many dimensions and also demonstrated that satisfaction was correlated most strongly with the ability of the HIT system to perform tasks in a “straightforward” manner.^117^ Finally, one article was a systematic review of physician use of electronic retrieval systems such as Medline.^129^

The other five articles focused more broadly on barriers to HIT implementation. One systematic review^130^ summarized barriers mentioned in the medical and pediatric literature that are significant for pediatric practices. These barriers were divided into four categories. Situational barriers included time and financial pressures, unproven return on investment, insufficient access to the internet or to computer technology in the office setting, the prohibitive cost of information technology for small practices, and software not being supportive of pediatric practice needs. Cognitive and or physical barriers include physical disabilities and insufficient computer skills. Liability barriers included confidentiality concerns. Finally, knowledge and attitudinal barriers included insufficient research about information technology in pediatrics, insufficient knowledge about benefits afforded by information technology, apprehension about change, and philosophical opposition to information technology.

Two studies used surveys to identify barriers in the use of electronic medical records^131^ and barriers to implementing CPOE systems in U.S. hospitals.^132^ In the first of these studies, the authors conducted 90 interviews with electronic medical record managers and physician champions in 30 physicians' organizations between 2000 and 2002. Key barriers to electronic medical record use were high initial financial costs, slow and uncertain financial payoffs, and high initial costs in terms of physician time. Additional barriers included difficulties with technology, complementary changes in support, electronic data exchange, financial incentives, and physician attitudes. The authors note that these barriers were most acute for physicians in solo/small group practice, which account for a large proportion of U.S. physicians. The second article^132^ reported the results of 52 interviews at 26 hospitals in various stages of implementation of CPOE—from not considering implementation to fully implemented. Most respondents were Chief Information Officers; the remainder consisted of Chief Financial Officers, Chief Medical Officers, and other management officials. Three main barriers to CPOE adoption were identified. The first was physician and organizational resistance due to the perceived negative impact on the physician's workflow. The authors noted that resistance from physicians could escalate to the point of a “physician rebellion,” which could derail the entire implementation process. The second barrier identified was the high cost, with estimates from prior studies for the cost of CPOE ranging from $3 million to $10 million, depending on the hospital's size and the level of existing information technology infrastructure. The third major barrier identified was product/vendor immaturity. Survey respondents reported that many current vendor products did not fit the needs of their hospital, and extensive software modifications were required to accommodate established workflow in the hospital.

We also identified two recent prominent editorials about barriers to HIT implementation that summarized the issues succinctly.^133,^ ^134^ The first of these^133^ identified several challenges for adoption of electronic health records. These included cost, technical issues, system interoperability, concerns about privacy and confidentiality, and a lack of a well trained clinical informatics work force to lead the process. This author identified financing as the biggest impediment, which he attributed to a misalignment of costs and benefits. He noted that while some studies have suggested a substantially positive return on HIT investment for the health care system as a whole, those who are expected to pay for the systems (physicians and other practice organizations) see only about 11 percent of that return on investment. The rest of the savings go to those who typically do not pay directly for the electronic health record. Another major challenge he identified was system and data interoperability, noting that most health care data (whether on paper or electronic) are trapped in “silos.” A third concern was privacy and confidentiality: the author stated that physicians, other health care professionals, and healthcare organizations must be vigilant in protecting patient privacy. The last major barrier identified was the need for a workforce capable of leading the implementation of information technology.

The second editorial^134^ stated that, despite predictions of a “bright and near future” for the use of HIT, this future never seems to be realized. The authors attributed the lack of progress in HIT implementation to a lack of attention to the social component, citing the need to view the clinical workplace as a complex system in which technologies, people, and organizational routines dynamically interact, which leads to the following observations:

“(1) Organizations are simultaneously social (e.g. consisting of people, values, norms and culture) and technical (i.e., without tools, equipment, procedures, technology and facilities the people could not work and the organization would not exist). (2) These social and technical elements are deeply inter-dependent and inter-related—hence the term socio-technical systems. Every change in one element affects the other. (3) Accordingly, good design and implementation is not a technical problem but rather one of jointly optimizing the combined socio-technical system.”

The authors also note, “...an information technology in and of itself cannot do anything, and when the patterns of its use are not tailored to the workers and their environment to yield high quality care, the technological interventions will not be productive. This implies that any IT acquisitions or implementation trajectory should, first and foremost, be an organization change trajectory.”

In summary, studies have identified a large number of barriers to the implementation of HIT. These barriers can be classified as situational barriers (including time and financial concerns), cognitive and or physical barriers (include physical disabilities and insufficient computer skills), liability barriers (including confidentiality concerns), and knowledge and attitudinal barriers. Cutting across all these categories, however, may be the need for clinical medicine as it is now practiced in the majority of settings to undergo a major structural and ideological reorganization, so it can be integrated with and enjoy the benefits of HIT.

Table 1. Summary of studies assessing the economic impact of an EHR system

Reference | HIT elements | IOM categories | Organization | Known system | Sources of data | Cost variables | Benefit variables | Year(s) of study | Findings
Wang, 2003 ^52^ | EHR, Electronic prescribing | HIDS, RM, OEM, DS, AP | Outpatient | Part | Primary data from EMR, literature review, expert group consensus | Software license, implementation, support, hardware, productivity loss | Quantified: Chart pull, transcription, prevention of ADE, drug, lab, radiology, charge capture, billing, & net value of AEMR during a five-year period | 2002 | Predicted to reduce healthcare costs, improve efficiency and productivity, and outweigh the costs from year 2 of the EMR implementation
Arias-Vimarlund, 1996 ^80^ | EHR | HIDS | Outpatient | | Work place observations and key informant interviews | Direct: Training, hardware & software, project manager system supplier, maintenance; | Quantified: time saved from chart pulling; | 1996 | One-year comparative case studies showed improved quality of care but the quantifiable benefits were less than HIT costs from societal perspective
| | | | | | Unexpected: self-training at work, loss of leisure hours, increase in administrative workload, extra service, summarizing medical records; | Unquantified: increase in knowledge capital for care team, easier and quicker communication for GPs during telephone consultations, clearer information to patients
| | | | | | Indirect: unquantified
Agrawal, 2002 ^83^ | EHR | HIDS, AP | Outpatient | Part | Hypothetical scenario, published studies | Unquantified: hardware, software, network, maintenance, installation and training, opportunity cost | Quantified: chart pull, transcription, time to document diagnostic codes; | 2002 | Illustrated a framework for return-on-investment calculation for EHR systems
| | | | | | | Unquantified: charge capture, cash flow, prescribing, malpractice premium, health resource waste, ADE and injuries, delivery of preventive and health maintenance procedures, provider and patient satisfaction
Khaoury, 1998 ^53^ | EHR, Decision Support | HIDS, RM, DS, AP | Outpatient | KP | Not described | Personnel, printing, network, hardware, license | Quantified: Medical record room and support staff, automated clinical forms, automated billing data; | 1992-1997 | Expected substantial savings
| | | | | | | Unquantified: support of a quality program
Schmitt, 2002 ^81^ | EHR | HIDS, OEM, AP | IDN | | Opinion from clinical advisory team, vendor, site visit observation | Annual cost over a seven-year period, with no detail breakdowns and assuming no cost associated with the temporary reduction in physician productivity | ADE, capitated drug benefits, inpatient medication cost, laboratory, radiology, pharmacy, documentation, information at the point of care, charge capture, & net benefit over the 7 years period | 2000 | Predicted to reduce healthcare costs, improve efficiency and productivity, see benefit in Year 2, and outweigh the costs from year 3 of the EMR implementation
Valancy, 2002 ^84^ | EHR | N/A | Outpatient | | Illustrative | 5-year annual cost with detail on hardware, software, vendor support, and data entry cost | Not reported | 2002 | Presented a tool to estimate the costs of implementing an EMR system, no organizational adaptation cost
Khoury, 1997 ^54^ | EHR | HIDS, DS, AP | Outpatient | KP | Not described | Personnel, printing, network, hardware, license | Quantified: Medical record room and support staff, automated clinical forms, automated billing data; | 1997 | Predicted the system to pay for itself 13 years from its initiation
| | | | | | | Unquantified: patient communications, guideline compliance, disease management and prevention
Kian, 1995 ^55^ | EHR | HIDS, AP | IDN | | Literature review, surveying 10 institutions, interviewing vendors, process mapping sessions | 10 years annual cost including hard and software, integration, network infrastructure, vertical integration, I/S infrastructure, institutional issues | Quantified: Data capture and access, decision support, business management, streamlining patient flow; net impact over 10 years period | 1994 | Predicted to begin to see benefits in the 3^rd^ year after implementation and substantial savings over 10 years
| | | | | | | Unquantified: patient readmission, staff reduction
Walker, 2005 ^82^ | EHR and health care information exchange and interoperability | DS | Organizations, nationwide | | Literature review, published data, expert interviews, expert panel | Interface development, electronic health record acquisition, maintenance | Quantified: Lab, radiology, pharmacy, chart request and referral, reporting, provider-payer transaction, & net value of health care information exchange and interoperability | 2005 | Predicted fully standardized and implemented health care information exchange and interoperability could yield a net value of $77.8 billion per year; nonstandardized health care information exchange and interoperability is less but still positive

NOTE: HIDS = health information and data storage; RM = results management; OEM = order entry management; DS = decision support; electronic communication and connectivity; AP = administrative processes