# Preface

The Agency for Healthcare Research and Quality (AHRQ), through its Evidence-Based Practice Centers (EPCs), sponsors the development of evidence reports and technology assessments to assist public- and private-sector organizations in their efforts to improve the quality of health care in the United States. This report was requested and funded by the Office of the Assistant Secretary for Planning and Evaluation (ASPE) with additional funding from the Office of Disease Prevention and Health Promotion (ODPHP), U.S. Department of Health and Human Services. In addition, the report was requested by the Leap Frog Group and the Centers for Medicare & Medicaid Services (CMS). The reports and assessments provide organizations with comprehensive, science-based information on common, costly medical conditions and new health care technologies. The EPCs systematically review the relevant scientific literature on topics assigned to them by AHRQ and conduct additional analyses when appropriate prior to developing their reports and assessments.

To bring the broadest range of experts into the development of evidence reports and health technology assessments, AHRQ encourages the EPCs to form partnerships and enter into collaborations with other medical and research organizations. The EPCs work with these partner organizations to ensure that the evidence reports and technology assessments they produce will become building blocks for health care quality improvement projects throughout the nation. The reports undergo peer review prior to their release.

AHRQ expects that the EPC evidence reports and technology assessments will inform individual health plans, providers, and purchasers, as well as the health care system as a whole, by providing important information to help improve health care quality.

We welcome written comments on this evidence report. They may be sent by mail to the Task Order Officer named below at: Agency for Healthcare Research and Quality, 540 Gaither Road, Rockville, MD 20850, or by e-mail to epc@ahrq.gov.

- Carolyn M. Clancy, M.D.
- Director
- Agency for Healthcare Research and Quality

- Michael J. O'Grady, Ph.D.
- Assistant Secretary for Planning and Evaluation
- U.S. Department of Health and Human Services

- CAPT Penelope Royall, P.T., M.S.W.
- Director
- Office of Disease Prevention and Health Promotion
- Office of Public Health and Science
- Office of the Secretary

- Jean Slutsky, P.A., M.S.P.H.
- Director, Center for Outcomes and Evidence
- Agency for Healthcare Research and Quality

- Beth A. Collins Sharp, R.N., Ph.D.
- Acting Director, EPC Program
- Agency for Healthcare Research and Quality

- Margaret Coopey, R.N., M.G.A., M.P.S.
- EPC Program Task Order Officer
- Agency for Healthcare Research and Quality