# Listing of Included Studies in Evidence Tables

Ades PA, Pashkow FJ, Fletcher G, et al. A controlled trial of cardiac rehabilitation in the home setting using electrocardiographic and voice transtelephonic monitoring. American Heart Journal. 2000;139(3):543-8. [pmid: 10689271].
Artinian NT, Washington OG, Templin TN. Effects of home telemonitoring and community-based monitoring on blood pressure control in urban African Americans: a pilot study. Heart Lung. May–Jun. 2001;30(3):191-9. [pmid: 11343005].
Artinian NT, Harden JK, Kronenberg MW, et al. Pilot study of a Web-based compliance monitoring device for patients with congestive heart failure. Heart Lung. Jul–Aug. 2003;32(4):226-33. [pmid: 12891162].
Baker CF, Rudnisky CJ, Tennant MT, et al. JPEG compression of stereoscopic digital images for the diagnosis of diabetic retinopathy via teleophthalmology. Can J Ophthalmol. Dec. 2004;39(7):746-54. [pmid: 15696764].
Barnard CM, Goldyne ME. Evaluation of an asynchronous teleconsultation system for diagnosis of skin cancer and other skin diseases. Telemedicine Journal & E Health. 2000;6(4):379-84. [pmid: 11242545].
Barnason S, Zimmerman L, Nieveen J, et al. Impact of a home communication intervention for coronary artery bypass graft patients with ischemic heart failure on self-efficacy, coronary disease risk factor modification, and functioning. Heart Lung. May–Jun. 2003;32(3):147-58. [pmid: 12827099].
Bellazzi R, Arcelloni M, Bensa G, et al. Design, methods, and evaluation directions of a multi-access service for the management of diabetes mellitus patients. Diabetes Technol Ther. 2003;5(4):621-9. [pmid: 14511417].
Benatar D, Bondmass M, Ghitelman J, et al. Outcomes of chronic heart failure.[see comment]. Arch Intern Med. Feb 10. 2003;163(3):347-52. [pmid: 12578516].
Biermann E, Dietrich W, Rihl J, et al. Are there time and cost savings by using telemanagement for patients on intensified insulin therapy? A randomised, controlled trial. Comput Methods Programs Biomed. Aug. 2002;69(2):137-46. [pmid: 12100793].
Bondmass M, Bolger N, Castro G, et al. The Effect of Home Monitoring and Telemanagement on Blood Pressure Control Among African Americans. Telemedicine Journal. 2000;6(1):15-23.
Bouchard S, Paquin B, Payeur R, et al. Delivering cognitive-behavior therapy for panic disorder with agoraphobia in videoconference. Telemed J E Health. Spring. 2004;10(1):13-25. [pmid: 15104911].
Bowman RJ, Kennedy C, Kirwan JF, et al. Reliability of telemedicine for diagnosing and managing eye problems in accident and emergency departments. Eye. Aug. 2003;17(6):743-6. [pmid: 12928688].
Braun RP, Vecchietti JL, Thomas L, et al. Telemedical wound care using a new generation of mobile telephones: a feasibility study. Arch Dermatol. Feb. 2005;141(2):254-8. [pmid: 15724023].
Breslow MJ, Rosenfeld BA, Doerfler M, et al. Effect of a multiple-site intensive care unit telemedicine program on clinical and economic outcomes: an alternative paradigm for intensivist staffing.[see comment]. Crit Care Med. Jan. 2004;32(1):31-8. [pmid: 14707557].
Chua R, Craig J, Wootton R, et al. Randomised controlled trial of telemedicine for new neurological outpatient referrals. J Neurol Neurosurg Psychiatry. Jul. 2001;71(1):63-6. [pmid: 11413265]. [pmcid: 1737484].
Chua R, Craig J, Esmonde T, et al. Telemedicine for new neurological outpatients: putting a randomized controlled trial in the context of everyday practice. J Telemed Telecare. 2002;8(5):270-3. [pmid: 12396855].
Chumbler NR, Mann WC, Wu S, et al. The association of home-telehealth use and care coordination with improvement of functional and cognitive functioning in frail elderly men. Telemed J E Health. Summer. 2004;10(2):129-37. [pmid: 15319042].
Coras B, Glaessl A, Kinateder J, et al. Teledermatoscopy in daily routine—results of the first 100 cases. Aktuelle Probl Dermatol. 2003;32:207-12.
Craig J, Chua R, Wootton R, et al. A pilot study of telemedicine for new neurological outpatient referrals. J Telemed Telecare. 2000;6(4):225-8. [pmid: 11027124].
Craig J, Patterson V, Russell C, et al. Interactive videoconsultation is a feasible method for neurological in-patient assessment. European Journal of Neurology. 2000;7(6):699-702. [pmid: 11136358].
Crowston JG, Kirwan JF, Wells A, et al. Evaluating clinical signs in trabeculectomized eyes. Eye. Mar. 2004;18(3):299-303. [pmid: 15004581].
D'Souza R. Improving treatment adherence and longitudinal outcomes in patients with a serious mental illness by using telemedicine. J Telemed Telecare. 2002;8(Suppl 2):113-5. [pmid: 12217162].
Dawson E, Kennedy C, Bentley C, et al. The role of telemedicine in the assessment of strabismus. J Telemed Telecare. 2002;8(1):52-5. [pmid: 11809086].
de Lusignan S, Wells S, Johnson P, et al. Compliance and effectiveness of 1 year's home telemonitoring. The report of a pilot study of patients with chronic heart failure. Eur J Heart Fail. Dec. 2001;3(6):723-30. [pmid: 11738225].
Du Moulin MF, Bullens-Goessens YI, Henquet CJ, et al. The reliability of diagnosis using store-and-forward teledermatology. J Telemed Telecare. 2003;9(5):249-52. [pmid: 14599326].
Egner A, Phillips VL, Vora R, et al. Depression, fatigue, and health-related quality of life among people with advanced multiple sclerosis: results from an exploratory telerehabilitation study. NeuroRehabilitation. 2003;18(2):125-33. [pmid: 12867675].
Eminovic N, Witkamp L, Ravelli AC, et al. Potential effect of patient-assisted teledermatology on outpatient referral rates. J Telemed Telecare. 2003;9(6):321-7. [pmid: 14680515].
Endean ED, Mallon LI, Minion DJ. Telemedicine in vascular surgery: does it work?. Am Surg. Apr. 2001;67(4):334-40. discussion 340–1. [pmid: 11307999].
Etherington IJ. Telecolposcopy - a feasibility study in primary care. J Telemed Telecare. 2002;8(Suppl 2):22-4. [pmid: 12217121].
Ferris DG, Macfee MS, Miller JA, et al. The efficacy of telecolposcopy compared with traditional colposcopy. Obstet Gynecol. Feb. 2002;99(2):248-54. [pmid: 11814505].
Ferris DG, Litaker MS, Macfee MS, et al. Remote diagnosis of cervical neoplasia: 2 types of telecolposcopy compared with cervicography.[see comment]. J Fam Pract. Apr. 2003;52(4):298-304. [pmid: 12681091].
Gardner SE, Frantz RA, Specht JK, et al. How accurate are chronic wound assessments using interactive video technology?. J Gerontol Nurs. Jan. 2001;27(1):15-20. quiz 52–3. [pmid: 11915092].
Givens GD, Elangovan S. Internet application to tele-audiology—"nothin' but net". Am J Audiol. Dec. 2003;12(2):59-65. [pmid: 14964319].
Gomez-Ulla F, Fernandez MI, Gonzalez F, et al. Digital retinal images and teleophthalmology for detecting and grading diabetic retinopathy.[see comment]. Diabetes Care. Aug. 2002;25(8):1384-9. [pmid: 12145239].
Halstead LS, Dang T, Elrod M, et al. Teleassessment compared with live assessment of pressure ulcers in a wound clinic: a pilot study. Adv Skin Wound Care. Mar–Apr. 2003;16(2):91-6. [pmid: 12690232].
Handschu R, Littmann R, Reulbach U, et al. Telemedicine in emergency evaluation of acute stroke: interrater agreement in remote video examination with a novel multimedia system. Stroke. Dec. 2003;34(12):2842-6. [pmid: 14615620].
Harvey-Berino J, Pintauro SJ, Gold EC. The feasibility of using Internet support for the maintenance of weight loss. Behav Modif. Jan. 2002;26(1):103-16. [pmid: 11799651].
Haukipuro K, Ohinmaa A, Winblad I, et al. The feasibility of telemedicine for orthopaedic outpatient clinics—a randomized controlled trial. J Telemed Telecare. 2000;6(4):193-8. [pmid: 11027118].
Houghton PE, Kincaid CB, Campbell KE, et al. Photographic assessment of the appearance of chronic pressure and leg ulcers. Ostomy Wound Management. 2000;46(4):20-6.
Izquierdo RE, Knudson PE, Meyer S, et al. A comparison of diabetes education administered through telemedicine versus in person. Diabetes Care. Apr. 2003;26(4):1002-7. [pmid: 12663564].
Jaatinen PT, Aarnio P, Remes J, et al. Teleconsultation as a replacement for referral to an outpatient clinic. J Telemed Telecare. 2002;8(2):102-6. [pmid: 11972945].
Jenkins RL, McSweeney M. Assessing elderly patients with congestive heart failure via in-home interactive telecommunication. J Gerontol Nurs. Jan. 2001;27(1):21-7. [pmid: 11915093].
Jerant AF, Azari R, Martinez C, et al. A randomized trial of telenursing to reduce hospitalization for heart failure: patient-centered outcomes and nursing indicators. Home Health Care Serv Q. 2003;22(1):1-20. [pmid: 12749524].
Jolliffe VM, Harris DW, Morris R, et al. Can we use video images to triage pigmented lesions?. Br J Dermatol. Dec. 2001;145(6):904-10. [pmid: 11899143].
Jolliffe VM, Harris DW, Whittaker SJ. Can we safely diagnose pigmented lesions from stored video images? A diagnostic comparison between clinical examination and stored video images of pigmented lesions removed for histology. Clin Exp Dermatol. Jan. 2001;26(1):84-7. [pmid: 11260186].
Jones OC, Wilson DI, Andrews S. The reliability of digital images when used to assess burn wounds. J Telemed Telecare. 2003;9(Suppl 1):S22-4. [pmid: 12952710].
Jones SM, Milroy C, Pickford MA. Telemedicine in acute plastic surgical trauma and burns. Ann R Coll Surg Engl. Jul. 2004;86(4):239-42. [pmid: 15239862]. [pmcid: 1964211].
Kennedy C, Yellowlees P. The effectiveness of telepsychiatry measured using the Health of theNation Outcome Scale and the Mental Health Inventory. J Telemed Telecare. 2003;9(1):12-6. [pmid: 12641887].
Kim CY, Etemad B, Glenn TF, et al. Remote clinical assessment of gastrointestinal endoscopy (tele-endoscopy): an initial experience. Proceedings / AMIA ...Annual Symposium 2000
Kim HM, Lowery JC, Hamill JB, et al. Accuracy of a web-based system for monitoring chronic wounds. Telemed J E Health. Summer. 2003;9(2):129-40. [pmid: 12855036].
Kobb R, Hoffman N, Lodge R, et al. Enhancing elder chronic care through technology and care coordination: report from a pilot. Telemed J E Health. Summer. 2003;9(2):189-95. [pmid: 12855041].
LaFramboise LM, Todero CM, Zimmerman L, et al. Comparison of Health Buddy with traditional approaches to heart failure management. Fam Community Health. Oct–Dec. 2003;26(4):275-88. [pmid: 14528134].
LaMonte MP, Bahouth MN, Hu P, et al. Telemedicine for acute stroke: triumphs and pitfalls. Stroke. Mar. 2003;34(3):725-8. [pmid: 12624298].
Lee S, Broderick TJ, Haynes J, et al. The role of low-bandwidth telemedicine in surgical prescreening. J Pediatr Surg. Sep. 2003;38(9):1281-3. [pmid: 14523806].
Leggett P, Graham L, Steele K, et al. Telerheumatology—diagnostic accuracy and acceptability to patient, specialist, and general practitioner. Br J Gen Pract. Sep. 2001;51(470):746-8. [pmid: 11593837]. [pmcid: 1314104].
Lim AC, Egerton IB, See A, et al. Accuracy and reliability of store-and-forward teledermatology: preliminary results from the St George Teledermatology Project. Australas J Dermatol. Nov. 2001;42(4):247-51. [pmid: 11903155].
Maiolo C, Mohamed EI, Fiorani CM, et al. Home telemonitoring for patients with severe respiratory illness: the Italian experience. J Telemed Telecare. 2003;9(2):67-71. [pmid: 12699574].
Mallett RB. Teledermatology in practice. Clin Exp Dermatol. Jul. 2003;28(4):356-9. [pmid: 12823290].
Mashima PA, Birkmire-Peters DP, Syms MJ, et al. Telehealth: voice therapy using telecommunications technology. Am J Speech Lang Pathol. Nov. 2003;12(4):432-9. [pmid: 14658995].
Menon AS, Kondapavalru P, Krishna P, et al. Evaluation of a portable low cost videophone system in the assessment of depressive symptoms and cognitive function in elderly medically ill veterans. J Nerv Ment Dis. Jun. 2001;189(6):399-401. [pmid: 11434642].
Montori VM, Helgemoe PK, Guyatt GH, et al. Telecare for patients with type 1 diabetes and inadequate glycemic control: a randomized controlled trial and meta-analysis. Diabetes Care. May. 2004;27(5):1088-94. [pmid: 15111526].
Morlion B, Knoop C, Paiva M, et al. Internet-based home monitoring of pulmonary function after lung transplantation. Am J Respir Crit Care Med. Mar 1. 2002;165(5):694-7. [pmid: 11874816].
Mullan B, Snyder M, Lindgren B, et al. Home monitoring for lung transplant candidates. Prog Transplant. Sep. 2003;13(3):176-82. [pmid: 14558631].
Noel HC, Vogel DC, Erdos JJ, et al. Home telehealth reduces healthcare costs. Telemed J E Health. Summer. 2004;10(2):170-83. [pmid: 15319047].
Nordal EJ, Moseng D, Kvammen B, et al. A comparative study of teleconsultations versus face-to-face consultations. J Telemed Telecare. 2001;7(5):257-65. [pmid: 11571079].
Oztas MO, Calikoglu E, Baz K, et al. Reliability of Web-based teledermatology consultations. J Telemed Telecare. 2004;10(1):25-8. [pmid: 15006212].
Pak HS, Harden D, Cruess D, et al. Teledermatology: an intraobserver diagnostic correlation study, part I. Cutis. May. 2003;71(5):399-403. [pmid: 12769408].
Pak HS, Harden D, Cruess D, et al. Teledermatology: an intraobserver diagnostic correlation study, Part II. Cutis. Jun. 2003;71(6):476-80. [pmid: 12839260].
Patricoski C, Kokesh J, Ferguson AS, et al. A comparison of in-person examination and video otoscope imaging for tympanostomy tube follow-up. Telemed J E Health. Winter. 2003;9(4):331-44. [pmid: 14980090].
Phillips VL, Vesmarovich S, Hauber R, et al. Telehealth: reaching out to newly injured spinal cord patients. Public Health Rep. 2001;116(Suppl 1):94-102. [pmid: 11889278]. [pmcid: 1913671].
Piccolo D, Smolle J, Argenziano G, et al. Teledermoscopy—results of a multicentre study on 43 pigmented skin lesions. J Telemed Telecare. 2000;6(3):132-7. [pmid: 10912329].
Piccolo D, Soyer HP, Burgdorf W, et al. Concordance between telepathologic diagnosis and conventional histopathologic diagnosis: a multiobserver store-and-forward study on 20 skin specimens.[see comment]. Arch Dermatol. Jan. 2002;138(1):53-8. [pmid: 11790167].
Rashid E, Ishtiaq O, Gilani S, et al. Comparison of store and forward method of teledermatology with face-to-face consultation. J Ayub Med Coll Abbottabad. Apr–Jun. 2003;15(2):34-6. [pmid: 14552246].
Rayner S, Beaconsfield M, Kennedy C, et al. Subspecialty adnexal ophthalmological examination using telemedicine. J Telemed Telecare. 2001;7(Suppl 1):29-31. [pmid: 11576482].
Rogers MA, Small D, Buchan DA, et al. Home monitoring service improves mean arterial pressure in patients with essential hypertensionA randomized, controlled trial.[see comment]. Ann Intern Med. Jun 5. 2001;134(11):1024-32. [pmid: 11388815].
Roth A, Kajiloti I, Elkayam I, et al. Telecardiology for patients with chronic heart failure: the 'SHL' experience in Israel. Int J Cardiol. Oct. 2004;97(1):49-55. [pmid: 15336806].
Ruskin PE, Silver-Aylaian M, Kling MA, et al. Treatment outcomes in depression: comparison of remote treatment through telepsychiatry to in-person treatment. Am J Psychiatry. Aug. 2004;161(8):1471-6. [pmid: 15285975].
Russell TG, Jull GA, Wootton R. Can the Internet be used as a medium to evaluate knee angle?. Manual Ther. Nov. 2003;8(4):242-6.
Saari JM, Summanen P, Kivela T, et al. Sensitivity and specificity of digital retinal images in grading diabetic retinopathy. Acta Ophthalmol Scand. Apr. 2004;82(2):126-30. [pmid: 15043527].
Scalvini S, Zanelli E, Conti C, et al. Assessment of prehospital chest pain using telecardiology. J Telemed Telecare. 2002;8(4):231-6. [pmid: 12217107].
Shapiro M, James WD, Kessler R, et al. Comparison of skin biopsy triage decisions in 49 patients with pigmented lesions and skin neoplasms: store-and-forward teledermatology vs face-to-face dermatology. Arch Dermatol. May. 2004;140(5):525-8. [pmid: 15148095].
Shiba T, Yamamoto T, Seki U, et al. Screening and follow-up of diabetic retinopathy using a new mosaic 9-field fundus photography system. Diabetes Res Clin Pract. Jan. 2002;55(1):49-59. [pmid: 11755479].
Shores MM, Ryan-Dykes P, Williams RM, et al. Identifying undiagnosed dementia in residential care veterans: comparing telemedicine to in-person clinical examination. Int J Geriatr Psychiatry. Feb. 2004;19(2):101-8. [pmid: 14758575].
Smith LF, Bainbridge J, Burns J, et al. Evaluation of telemedicine for slit lamp examination of the eye following cataract surgery. Br J Ophthalmol. Apr. 2003;87(4):502-3. [pmid: 12642321]. [pmcid: 1771588].
Taylor P, Goldsmith P, Murray K, et al. Evaluating a telemedicine system to assist in the management of dermatology referrals. Br J Dermatol. Feb. 2001;144(2):328-33. [pmid: 11251567].
Taylor P, Kennedy C, Murdoch I, et al. Assessment of benefit in tele-ophthalmology using a consensus panel. J Telemed Telecare. 2003;9(3):140-5. [pmid: 12877775].
Tennant MT, Rudnisky CJ, Hinz BJ, et al. Tele-ophthalmology via stereoscopic digital imaging: a pilot project. Diabetes Technol Ther. 2000;2(4):583-7. [pmid: 11469622].
Terkelsen CJ, Norgaard BL, Lassen JF, et al. Telemedicine used for remote prehospital diagnosing in patients suspected of acute myocardial infarction. J Intern Med. Nov. 2002;252(5):412-20. [pmid: 12528759].
Ullah R, Gilliland D, Adams D. Otolaryngology consultations by real-time telemedicine. Ulster Med J. May. 2002;71(1):26-9. [pmid: 12137160]. [pmcid: 2475361].
Vuolio S, Winblad I, Ohinmaa A, et al. Videoconferencing for orthopaedic outpatients: one-year follow-up. J Telemed Telecare. 2003;9(1):8-11. [pmid: 12641886].
Wallace P, Haines A, Harrison R, et al. Joint teleconsultations (virtual outreach) versus standard outpatient appointments for patients referred by their general practitioner for a specialist opinion: a randomised trial.[see comment]. Lancet. Jun 8. 2002;359(9322):1961-8. [pmid: 12076550].
Wang S, Lee SB, Pardue C, et al. Remote evaluation of acute ischemic stroke: reliability of National Institutes of Health Stroke Scale via telestroke.[see comment]. Stroke. Oct. 2003;34(10):e188-91. [pmid: 14500929].
Welch G, Sokolove M, Mullin C, et al. Use of a Modem-Equipped Blood Glucose Meter Augmented with Bi-Weekly Educator Telephone Support Lowers HbA1c in Type 1 Diabetes. Diabetes. 2003;52(Suppl. 1):A100-A101.
Whited JD, Hall RP, Foy ME, et al. Teledermatology's impact on time to intervention among referrals to a dermatology consult service. Telemed J E Health. Fall. 2002;8(3):313-21. [pmid: 12419025].
Wilbright WA, Birke JA, Patout CA, et al. The use of telemedicine in the management of diabetes-related foot ulceration: a pilot study. Adv Skin Wound Care. Jun. 2004;17(5 Pt 1):232-8. [pmid: 15192491].
Wildi SM, Kim CY, Glenn TF, et al. Tele-endoscopy: a way to provide diagnostic quality for remote populations. Gastrointest Endosc. Jan. 2004;59(1):38-43. [pmid: 14722545].
Woods KF, Johnson JA, Kutlar A, et al. Sickle cell disease telemedicine network for rural outreach. J Telemed Telecare. 2000;6(5):285-90. [pmid: 11070590].
Yogesan K, Constable IJ, Barry CJ, et al. Telemedicine screening of diabetic retinopathy using a hand-held fundus camera. Telemedicine Journal. 2000;6(2):219-23. [pmid: 10957734].
Yoshino A, Shigemura J, Kobayashi Y, et al. Telepsychiatry: assessment of televideo psychiatric interview reliability with present- and next-generation internet infrastructures. Acta Psychiatr Scand. Sep. 2001;104(3):223-6. [pmid: 11531660].