# References

1 Hersh W. Telemedicine for the Medicare population. Evidence Report Technology Assessment No. 24. Rockville, MD: U.S. Department of Health and Human Services, Agency for Health Care Policy and Research; 2001. AHRQ Publication No. 01-E102
2 Grigsby B. 2004 TRC Report on US telemedicine activity: with an overview of non-US activity. 2004, Civic Research Institute: Kingston, NJ. p. 142 p.
3 Hersh W, Helfand M, Wallace J, et al. A systematic review of the efficacy of telemedicine for making diagnostic and management decisions. J Telemed Telecare. 2002;8(4):197-209. [pmid: 12217102].
4 Hersh WR, Helfand M, Wallace J, et al. Clinical outcomes resulting from telemedicine interventions: a systematic review. BMC Med Inf Decis Mak. 2001;1(1):5.
5 Centers for Medicare and Medicaid Services, US Department of Health and Human Services. Medicare program; revised process for making Medicare National Coverage Determinations. Federal Register 2003 Sep 26;68(187): 55634–41
6 Medicare Payment Advisory Commission. Report to the Congress: Medicare in Rural America. 2001:25–38.
7 Millman M, ed. Access to health care in America. Washington, DC: National Academy Press; 1993.
8 Egglin TK, Feinstein AR. Context bias. A problem in diagnostic radiology.[see comment]. Jama. Dec 4. 1996;276(21):1752-5. [pmid: 8940325].
9 Lijmer JG, Mol BW, Heisterkamp S, et al. Empirical evidence of design-related bias in studies of diagnostic tests.[see comment][erratum appears in JAMA 2000 Apr 19;283(15):1963]. Jama 1999 Sept.15;282(11):1061–6.
10 Chestnut R, Carney N, Maynard H, et al. Rehabilitation for traumatic brain injury: Evidence Report no. 2 (prepared by the Oregon Health & Science University under Contract No. 290-97-0018). 1999, Agency for Health Care Research: Rockville, MD.
11 Berry LL, Seiders K, Wilder SS. Innovations in access to care: a patient-centered approach. Ann Intern Med. Oct 7. 2003;139(7):568-74. [pmid: 14530228].
12 Murray M, Berwick DM. Advanced access: reducing waiting and delays in primary care.[see comment]. Jama. Feb 26. 2003;289(8):1035-40. [pmid: 12597760].
13 Barnard CM, Goldyne ME. Evaluation of an asynchronous teleconsultation system for diagnosis of skin cancer and other skin diseases. Telemedicine Journal & E Health. 2000;6(4):379-84. [pmid: 11242545].
14 Du Moulin MF, Bullens-Goessens YI, Henquet CJ, et al. The reliability of diagnosis using store-and-forward teledermatology. J Telemed Telecare. 2003;9(5):249-52. [pmid: 14599326].
15 Eminovic N, Witkamp L, Ravelli AC, et al. Potential effect of patient-assisted teledermatology on outpatient referral rates. J Telemed Telecare. 2003;9(6):321-7. [pmid: 14680515].
16 Lim AC, Egerton IB, See A, et al. Accuracy and reliability of store-and-forward teledermatology: preliminary results from the St George Teledermatology Project. Australas J Dermatol. Nov. 2001;42(4):247-51. [pmid: 11903155].
17 Oztas MO, Calikoglu E, Baz K, et al. Reliability of Web-based teledermatology consultations. J Telemed Telecare. 2004;10(1):25-8. [pmid: 15006212].
18 Rashid E, Ishtiaq O, Gilani S, et al. Comparison of store and forward method of teledermatology with face-to-face consultation. J Ayub Med Coll Abbottabad. Apr-Jun. 2003;15(2):34-6. [pmid: 14552246].
19 Taylor P, Goldsmith P, Murray K, et al. Evaluating a telemedicine system to assist in the management of dermatology referrals. Br J Dermatol. Feb. 2001;144(2):328-33. [pmid: 11251567].
20 Whited JD, Hall RP, Simel DL, et al. Reliability and accuracy of dermatologists' clinic-based and digital image consultations. 1999 693–702.
21 Lesher JL, Jr., Davis LS, Gourdin FW, et al. Telemedicine evaluation of cutaneous diseases: a blinded comparative study. 1998 Jan.27–31.
22 Shapiro M, James WD, Kessler R, et al. Comparison of skin biopsy triage decisions in 49 patients with pigmented lesions and skin neoplasms: store-and-forward teledermatology vs face-to-face dermatology. Arch Dermatol. May. 2004;140(5):525-8. [pmid: 15148095].
23 Jolliffe VM, Harris DW, Morris R, et al. Can we use video images to triage pigmented lesions?. Br J Dermatol. Dec. 2001;145(6):904-10. [pmid: 11899143].
24 Pak HS, Harden D, Cruess D, et al. Teledermatology: an intraobserver diagnostic correlation study, part I. Cutis. May. 2003;71(5):399-403. [pmid: 12769408].
25 Pak HS, Harden D, Cruess D, et al. Teledermatology: an intraobserver diagnostic correlation study, Part II. Cutis. Jun. 2003;71(6):476-80. [pmid: 12839260].
26 Coras B, Glaessl A, Kinateder J, et al. Teledermatoscopy in daily routine—results of the first 100 cases. Aktuelle Probl Dermatol 2003 32207–12.
27 Piccolo D, Soyer HP, Burgdorf W, et al. Concordance between telepathologic diagnosis and conventional histopathologic diagnosis: a multiobserver store-and-forward study on 20 skin specimens. Arch Dermatol. Jan. 2002;138(1):53-8. [pmid: 11790167].
28 Gomez-Ulla F, Fernandez MI, Gonzalez F, et al. Digital retinal images and teleophthalmology for detecting and grading diabetic retinopathy.[see comment]. Diabetes Care. Aug. 2002;25(8):1384-9. [pmid: 12145239].
29 Saari JM, Summanen P, Kivela T, et al. Sensitivity and specificity of digital retinal images in grading diabetic retinopathy. Acta Ophthalmol Scand. Apr. 2004;82(2):126-30. [pmid: 15043527].
30 Shiba T, Yamamoto T, Seki U, et al. Screening and follow-up of diabetic retinopathy using a new mosaic 9-field fundus photography system. Diabetes Res Clin Pract. Jan. 2002;55(1):49-59. [pmid: 11755479].
31 Baker CF, Rudnisky CJ, Tennant MT, et al. JPEG compression of stereoscopic digital images for the diagnosis of diabetic retinopathy via teleophthalmology. 2004 746–54, 2004 Dec.
32 Ferris DG, Litaker MS, Macfee MS, et al. Remote diagnosis of cervical neoplasia: 2 types of telecolposcopy compared with cervicography.[see comment]. J Fam Pract. Apr. 2003;52(4):298-304. [pmid: 12681091].
33 Ferris DG, Macfee MS, Miller JA, et al. The efficacy of telecolposcopy compared with traditional colposcopy. Obstet Gynecol. Feb. 2002;99(2):248-54. [pmid: 11814505].
34 Lee S, Broderick TJ, Haynes J, et al. The role of low-bandwidth telemedicine in surgical prescreening. J Pediatr Surg. Sep. 2003;38(9):1281-3. [pmid: 14523806].
35 Tennant MT, Rudnisky CJ, Hinz BJ, et al. Tele-ophthalmology via stereoscopic digital imaging: a pilot project. Diabetes Technol Ther. 2000;2(4):583-7. [pmid: 11469622].
36 Jaatinen PT, Aarnio P, Remes J, et al. Teleconsultation as a replacement for referral to an outpatient clinic. J Telemed Telecare. 2002;8(2):102-6. [pmid: 11972945].
37 Mallett RB. Teledermatology in practice. Clin Exp Dermatol. Jul. 2003;28(4):356-9. [pmid: 12823290].
38 Whited JD, Hall RP, Foy ME, et al. Teledermatology's impact on time to intervention among referrals to a dermatology consult service. Telemed J E Health. Fall. 2002;8(3):313-21. [pmid: 12419025].
39 Benatar D, Bondmass M, Ghitelman J, et al. Outcomes of chronic heart failure.[see comment]. Arch Intern Med. Feb 10. 2003;163(3):347-52. [pmid: 12578516].
40 Noel HC, Vogel DC, Erdos JJ, et al. Home telehealth reduces healthcare costs. Telemed J E Health. Summer. 2004;10(2):170-83. [pmid: 15319047].
41 Barnason S, Zimmerman L, Nieveen J, et al. Impact of a home communication intervention for coronary artery bypass graft patients with ischemic heart failure on self-efficacy, coronary disease risk factor modification, and functioning. Heart Lung. May-Jun. 2003;32(3):147-58. [pmid: 12827099].
42 Rogers MA, Small D, Buchan DA, et al. Home monitoring service improves mean arterial pressure in patients with essential hypertension. A randomized, controlled trial.[see comment]. Ann Intern Med. Jun 5. 2001;134(11):1024-32. [pmid: 11388815].
43 Phillips VL, Vesmarovich S, Hauber R, et al. Telehealth: reaching out to newly injured spinal cord patients. Public Health Rep. 2001;116(Suppl 1):94-102. [pmid: 11889278]. [pmcid: 1913671].
44 Kobb R, Hoffman N, Lodge R, et al. Enhancing elder chronic care through technology and care coordination: report from a pilot. Telemed J E Health. Summer. 2003;9(2):189-95. [pmid: 12855041].
45 Maiolo C, Mohamed EI, Fiorani CM, et al. Home telemonitoring for patients with severe respiratory illness: the Italian experience. J Telemed Telecare. 2003;9(2):67-71. [pmid: 12699574].
46 Bellazzi R, Arcelloni M, Bensa G, et al. Design, methods, and evaluation directions of a multi-access service for the management of diabetes mellitus patients. Diabetes Technol Ther. 2003;5(4):621-9. [pmid: 14511417].
47 Biermann E, Dietrich W, Rihl J, et al. Are there time and cost savings by using telemanagement for patients on intensified insulin therapy? A randomised, controlled trial. Comput Methods Programs Biomed. Aug. 2002;69(2):137-46. [pmid: 12100793].
48 Izquierdo RE, Knudson PE, Meyer S, et al. A comparison of diabetes education administered through telemedicine versus in person. Diabetes Care. Apr. 2003;26(4):1002-7. [pmid: 12663564].
49 Montori VM, Helgemoe PK, Guyatt GH, et al. Telecare for patients with type 1 diabetes and inadequate glycemic control: a randomized controlled trial and meta-analysis. Diabetes Care. May. 2004;27(5):1088-94. [pmid: 15111526].
50 Welch G, Sokolove M, Mullin C, et al. Use of a Modem-Equipped Blood Glucose Meter Augmented with Bi-Weekly Educator Telephone Support Lowers HbA1c in Type 1 Diabetes. Diabetes. 2003;52(Suppl. 1):A100-A101.
51 Harvey-Berino J, Pintauro SJ, Gold EC. The feasibility of using Internet support for the maintenance of weight loss. Behav Modif. Jan. 2002;26(1):103-16. [pmid: 11799651].
52 Mullan B, Snyder M, Lindgren B, et al. Home monitoring for lung transplant candidates. Prog Transplant. Sep. 2003;13(3):176-82. [pmid: 14558631].
53 Bowman RJ, Kennedy C, Kirwan JF, et al. Reliability of telemedicine for diagnosing and managing eye problems in accident and emergency departments. Eye. Aug. 2003;17(6):743-6. [pmid: 12928688].
54 Crowston JG, Kirwan JF, Wells A, et al. Evaluating clinical signs in trabeculectomized eyes. Eye. Mar. 2004;18(3):299-303. [pmid: 15004581].
55 Craig J, Chua R, Wootton R, et al. A pilot study of telemedicine for new neurological outpatient referrals. J Telemed Telecare. 2000;6(4):225-8. [pmid: 11027124].
56 Craig J, Patterson V, Russell C, et al. Interactive videoconsultation is a feasible method for neurological in-patient assessment. European Journal of Neurology. 2000;7(6):699-702. [pmid: 11136358].
57 Handschu R, Littmann R, Reulbach U, et al. Telemedicine in emergency evaluation of acute stroke: interrater agreement in remote video examination with a novel multimedia system. Stroke. Dec. 2003;34(12):2842-6. [pmid: 14615620].
58 Wang S, Lee SB, Pardue C, et al. Remote evaluation of acute ischemic stroke: reliability of National Institutes of Health Stroke Scale via telestroke.[see comment]. Stroke. Oct. 2003;34(10):e188-91. [pmid: 14500929].
59 Menon AS, Kondapavalru P, Krishna P, et al. Evaluation of a portable low cost videophone system in the assessment of depressive symptoms and cognitive function in elderly medically ill veterans. J Nerv Ment Dis. Jun. 2001;189(6):399-401. [pmid: 11434642].
60 Yoshino A, Shigemura J, Kobayashi Y, et al. Telepsychiatry: assessment of televideo psychiatric interview reliability with present- and next-generation internet infrastructures. Acta Psychiatr Scand. Sep. 2001;104(3):223-6. [pmid: 11531660].
61 Shores MM, Ryan-Dykes P, Williams RM, et al. Identifying undiagnosed dementia in residential care veterans: comparing telemedicine to in-person clinical examination. Int J Geriatr Psychiatry. Feb. 2004;19(2):101-8. [pmid: 14758575].
62 Nordal EJ, Moseng D, Kvammen B, et al. A comparative study of teleconsultations versus face-to-face consultations. J Telemed Telecare. 2001;7(5):257-65. [pmid: 11571079].
63 Leggett P, Graham L, Steele K, et al. Telerheumatology—diagnostic accuracy and acceptability to patient, specialist, and general practitioner. Br J Gen Pract. Sep. 2001;51(470):746-8. [pmid: 11593837]. [pmcid: 1314104].
64 Endean ED, Mallon LI, Minion DJ, et al. Telemedicine in vascular surgery: does it work?. Am Surg. Apr. 2001;67(4):334-40. discussion 340–1. [pmid: 11307999].
65 Mashima PA, Birkmire-Peters DP, Syms MJ, et al. Telehealth: voice therapy using telecommunications technology. Am J Speech Lang Pathol. Nov. 2003;12(4):432-9. [pmid: 14658995].
66 Ruskin PE, Silver-Aylaian M, Kling MA, et al. Treatment outcomes in depression: comparison of remote treatment through telepsychiatry to in-person treatment. Am J Psychiatry. Aug. 2004;161(8):1471-6. [pmid: 15285975].
67 Woods KF, Johnson JA, Kutlar A, et al. Sickle cell disease telemedicine network for rural outreach. J Telemed Telecare. 2000;6(5):285-90. [pmid: 11070590].
68 Kennedy C, Yellowlees P. The effectiveness of telepsychiatry measured using the Health of the Nation Outcome Scale and the Mental Health Inventory. J Telemed Telecare. 2003;9(1):12-6. [pmid: 12641887].
69 Chua R, Craig J, Esmonde T, et al. Telemedicine for new neurological outpatients: putting a randomized controlled trial in the context of everyday practice. J Telemed Telecare. 2002;8(5):270-3. [pmid: 12396855].
70 Wallace P, Haines A, Harrison R, et al. Joint teleconsultations (virtual outreach) versus standard outpatient appointments for patients referred by their general practitioner for a specialist opinion: a randomised trial.[see comment]. Lancet. Jun 8. 2002;359(9322):1961-8. [pmid: 12076550].
71 Vuolio S, Winblad I, Ohinmaa A, et al. Videoconferencing for orthopaedic outpatients: one-year follow-up. J Telemed Telecare. 2003;9(1):8-11. [pmid: 12641886].
72 LaMonte MP, Bahouth MN, Hu P, et al. Telemedicine for acute stroke: triumphs and pitfalls. Stroke. Mar. 2003;34(3):725-8. [pmid: 12624298].
73 Cavallerano AA, Cavallerano JD, Katalinic P, et al. Use of Joslin Vision Network digital-video nonmydriatic retinal imaging to assess diabetic retinopathy in a clinical program. Retina. Apr. 2003;23(2):215-23. [pmid: 12707602].
74 Yu VL, Fagan LM, Wraith SM, et al. Antimicrobial selection by a computer. A blinded evaluation by infectious diseases experts. Jama. Sep. 21. 1979;242(12):1279-82. [pmid: 480542].
75 Miller RA, Pople HE Jr., Myers JD. Internist-1, an experimental computer-based diagnostic consultant for general internal medicine. N Engl J Med. Aug. 19. 1982;307(8):468-76. [pmid: 7048091].
76 Miller RA, Masarie FE Jr. The demise of the “Greek Oracle” model for medical diagnostic systems. Methods Inf Med. Jan. 1990;29(1):1-2. [pmid: 2407929].
77 Bates DW, Cohen M, Leape LL, et al. Reducing the frequency of errors in medicine using information technology.[see comment]. JAMIA. 2001;8(8):299-308. [pmid: 11418536]. [pmcid: 130074].
78 Ghandi T, Bates D. Computer adverse drug event (ADE) detection and alerts. In: Making Health Care Safer: A Critical Analysis of Patient Safety Practices. Evidence Report Technology Assessment No. 43. Rockville, MD: U.S. Department of Health and Human Services, Agency for Health Care Policy and Research; 2001 July. AHRQ Publication No. 01-E058.
79 Kaushal R, Bates D. Computerized physician order entry (CPOE) with clinical decision support systems (CDSSs). In: Making Health Care Safer: A Critical Analysis of Patient Safety Practices. Evidence Report Technology Assessment No. 43. Rockville, MD: U.S. Department of Health and Human Services, Agency for Health Care Policy and Research; 2001 July. AHRQ Publication No. 01-E058.

### Other Included Studies

Ades PA, Pashkow FJ, Fletcher G, et al. A controlled trial of cardiac rehabilitation in the home setting using electrocardiographic and voice transtelephonic monitoring. American Heart Journal. 2000;139(3):543-8. [pmid: 10689271].
Artinian NT, Washington OG, Templin TN. Effects of home telemonitoring and community-based monitoring on blood pressure control in urban African Americans: a pilot study. Heart Lung. May-Jun. 2001;30(3):191-9. [pmid: 11343005].
Bondmass M, Bolger N, Castro G, et al. The Effect of Home Monitoring and Telemanagement on Blood Pressure Control Among African Americans. Telemedicine Journal. 2000;6(1):15-23.
Bouchard S, Paquin B, Payeur R, et al. Delivering cognitive-behavior therapy for panic disorder with agoraphobia in videoconference. Telemed J E Health. Spring. 2004;10(1):13-25. [pmid: 15104911].
Braun RP, Vecchietti JL, Thomas L, et al. Telemedical wound care using a new generation of mobile telephones: a feasibility study. Arch Dermatol. Feb. 2005;141(2):254-8. [pmid: 15724023].
Breslow MJ, Rosenfeld BA, Doerfler M, et al. Effect of a multiple-site intensive care unit telemedicine program on clinical and economic outcomes: an alternative paradigm for intensivist staffing.[see comment]. Crit Care Med. Jan. 2004;32(1):31-8. [pmid: 14707557].
Chua R, Craig J, Wootton R, et al. Randomised controlled trial of telemedicine for new neurological outpatient referrals. J Neurol Neurosurg Psychiatry. Jul. 2001;71(1):63-6. [pmid: 11413265]. [pmcid: 1737484].
D'Souza R. Improving treatment adherence and longitudinal outcomes in patients with a serious mental illness by using telemedicine. J Telemed Telecare. 2002;8(Suppl 2):113-5. [pmid: 12217162].
Dawson E, Kennedy C, Bentley C, et al. The role of telemedicine in the assessment of strabismus. J Telemed Telecare. 2002;8(1):52-5. [pmid: 11809086].
de Lusignan S, Wells S, Johnson P, et al. Compliance and effectiveness of 1 year's home telemonitoring. The report of a pilot study of patients with chronic heart failure. Eur J Heart Fail. Dec. 2001;3(6):723-30. [pmid: 11738225].
Egner A, Phillips VL, Vora R, et al. Depression, fatigue, and health-related quality of life among people with advanced multiple sclerosis: results from an exploratory telerehabilitation study. NeuroRehabilitation. 2003;18(2):125-33. [pmid: 12867675].
Etherington IJ. Telecolposcopy - a feasibility study in primary care. J Telemed Telecare. 2002;8(Suppl 2):22-4. [pmid: 12217121].
Gardner SE, Frantz RA, Specht JK, et al. How accurate are chronic wound assessments using interactive video technology?. J Gerontol Nurs. Jan. 2001;27(1):15-20. quiz 52–3. [pmid: 11915092].
Givens GD, Elangovan S. Internet application to tele-audiology-“nothin' but net”. Am J Audiol. Dec. 2003;12(2):59-65. [pmid: 14964319].
Halstead LS, Dang T, Elrod M, et al. Teleassessment compared with live assessment of pressure ulcers in a wound clinic: a pilot study. Adv Skin Wound Care. Mar-Apr. 2003;16(2):91-6. [pmid: 12690232].
Haukipuro K, Ohinmaa A, Winblad I, et al. The feasibility of telemedicine for orthopaedic outpatient clinics--a randomized controlled trial. J Telemed Telecare. 2000;6(4):193-8. [pmid: 11027118].
Houghton PE, Kincaid CB, Campbell KE, et al. Photographic assessment of the appearance of chronic pressure and leg ulcers. Ostomy Wound Management. 2000;46(4):20-6.
Jenkins RL, McSweeney M. Assessing elderly patients with congestive heart failure via in-home interactive telecommunication. J Gerontol Nurs. Jan. 2001;27(1):21-7. [pmid: 11915093].
Jerant AF, Azari R, Martinez C, et al. A randomized trial of telenursing to reduce hospitalization for heart failure: patient-centered outcomes and nursing indicators. Home Health Care Serv Q. 2003;22(1):1-20. [pmid: 12749524].
Jolliffe VM, Harris DW, Whittaker SJ. Can we safely diagnose pigmented lesions from stored video images? A diagnostic comparison between clinical examination and stored video images of pigmented lesions removed for histology. Clin Exp Dermatol. Jan. 2001;26(1):84-7. [pmid: 11260186].
Jones OC, Wilson DI, Andrews S. The reliability of digital images when used to assess burn wounds. J Telemed Telecare. 2003;9(Suppl 1):S22-4. [pmid: 12952710].
Jones SM, Milroy C, Pickford MA. Telemedicine in acute plastic surgical trauma and burns. Ann R Coll Surg Engl. Jul. 2004;86(4):239-42. [pmid: 15239862]. [pmcid: 1964211].
Kim CY, Etemad B, Glenn TF, et al. Remote clinical assessment of gastrointestinal endoscopy (tele-endoscopy): an initial experience. Proceedings / AMIA ... Annual Symposium 2000
LaFramboise LM, Todero CM, Zimmerman L, et al. Comparison of Health Buddy with traditional approaches to heart failure management. Fam Community Health. Oct-Dec. 2003;26(4):275-88. [pmid: 14528134].
Mallett RB. Teledermatology in practice. Clin Exp Dermatol. Jul. 2003;28(4):356-9. [pmid: 12823290].
Morlion B, Knoop C, Paiva M, et al. Internet-based home monitoring of pulmonary function after lung transplantation. Am J Respir Crit Care Med. Mar 1. 2002;165(5):694-7. [pmid: 11874816].
Patricoski C, Kokesh J, Ferguson AS, et al. A comparison of in-person examination and video otoscope imaging for tympanostomy tube follow-up. Telemed J E Health. Winter. 2003;9(4):331-44. [pmid: 14980090].
Rayner S, Beaconsfield M, Kennedy C, et al. Subspecialty adnexal ophthalmological examination using telemedicine. J Telemed Telecare. 2001;7(Suppl 1):29-31. [pmid: 11576482].
Roth A, Kajiloti I, Elkayam I, et al. Telecardiology for patients with chronic heart failure: the ‘SHL’ experience in Israel. Int J Cardiol. Oct. 2004;97(1):49-55. [pmid: 15336806].
Russell TG, Jull GA, Wootton R. Can the Internet be used as a medium to evaluate knee angle?. Manual Ther. Nov. 2003;8(4):242-6.
Scalvini S, Zanelli E, Conti C, et al. Assessment of prehospital chest pain using telecardiology. J Telemed Telecare. 2002;8(4):231-6. [pmid: 12217107].
Smith LF, Bainbridge J, Burns J, et al. Evaluation of telemedicine for slit lamp examination of the eye following cataract surgery. Br J Ophthalmol. Apr. 2003;87(4):502-3. [pmid: 12642321]. [pmcid: 1771588].
Taylor P, Kennedy C, Murdoch I, et al. Assessment of benefit in tele-ophthalmology using a consensus panel. J Telemed Telecare. 2003;9(3):140-5. [pmid: 12877775].
Terkelsen CJ, Norgaard BL, Lassen JF, et al. Telemedicine used for remote prehospital diagnosing in patients suspected of acute myocardial infarction. J Intern Med. Nov. 2002;252(5):412-20. [pmid: 12528759].
Ullah R, Gilliland D, Adams D. Otolaryngology consultations by real-time telemedicine. Ulster Med J. May. 2002;71(1):26-9. [pmid: 12137160]. [pmcid: 2475361].
Wilbright WA, Birke JA, Patout CA, et al. The use of telemedicine in the management of diabetes-related foot ulceration: a pilot study. Adv Skin Wound Care. Jun. 2004;17(5 Pt 1):232-8. [pmid: 15192491].
Wildi SM, Kim CY, Glenn TF, et al. Tele-endoscopy: a way to provide diagnostic quality for remote populations. Gastrointest Endosc. Jan. 2004;59(1):38-43. [pmid: 14722545].
Yogesan K, Constable IJ, Barry CJ, et al. Telemedicine screening of diabetic retinopathy using a hand-held fundus camera. Telemedicine Journal. 2000;6(2):219-23. [pmid: 10957734].