# Executive Summary

## Overview

Telemedicine is the use of telecommunications technology for medical diagnostic, monitoring, and therapeutic purposes where distance and/or time separates the patient and health care provider. Both federal and private health insurers are now covering some telemedicine services, despite the fact that the benefits and costs of providing many of these services have not been well studied.

This report assesses the peer-reviewed literature of specific telemedicine study areas, with a focus on those that substitute for face-to-face medical diagnosis and treatment of the Medicare population. Thus, this report targets face-to-face clinical specialties (as opposed to radiology and pathology) and the Medicare population. It does not evaluate studies examining populations that usually are not covered by Medicare, such as children and pregnant women. The report identifies health care services that could be provided using telemedicine and describes existing programs in three categories of telemedicine: store-and-forward, home-based and office/hospital-based services.

## Introduction

This evidence report provides an update on the state of telemedicine, following the 2001 publication of Telemedicine for the Medicare Population.^1^ It identifies whether there has been significant progress in the number and types of telemedicine studies being conducted. More specifically, we searched for well-designed studies that evaluated telemedicine services in three technological categories described below.

### Store-and-forward Telemedicine

In store-and-forward telemedicine, clinical data are collected, stored, and then forwarded to be interpreted later. A store-and-forward system eliminates the need for the patient and the clinician to be available at either the same time or place. The following key questions were addressed for store-and-forward telemedicine services in Medicare-eligible patient populations.

1 Does store-and-forward telemedicine result in comparable diagnostic decisions and recommendations for clinical management?
2 Does store-and-forward telemedicine result in comparable health outcomes?
3 Does the availability of store-and-forward telemedicine services improve access to care?

### Home-based Telemedicine

Home-based telemedicine services enable physicians and other health care providers to monitor physiologic measurements, test results, images, and sounds, usually collected in a patient's residence or a care facility. The use of home-based telemedicine services in Medicare-eligible patient populations was examined, asking the following questions relative to conventional care using face-to-face encounters.

1 Does home-based telemedicine result in comparable diagnostic decisions and recommendations for management?
2 Does the use of home-based telemedicine result in comparable health outcomes?
3 Does the use of home-based telemedicine improve access to care?

### Office/Hospital-based Telemedicine

Office/hospital-based telemedicine services are real-time clinician-patient interactions that substitute for face-to-face encounters between a patient and a physician or other health care provider. The use of office/hospital-based telemedicine was evaluated relative to face-to-face encounters on the basis of the following questions.

1 Does office/hospital-based telemedicine result in comparable diagnosis and appropriateness of recommendations for management?
2 Does office/hospital-based telemedicine result in comparable health outcomes?
3 Does the availability of office/hospital-based telemedicine improve access to care?

## Methods

The Oregon Evidence-based Practice Center (EPC) team that developed this report sought to identify peer-reviewed literature in the three study areas. We searched the peer-reviewed literature using the Ovid MEDLINE® electronic bibliographic database. We also searched through telemedicine reports and compilations, including their reference lists.

The inclusion criteria for the evidence report update were that the study was relevant to at least one of the three study areas, addressed at least one key question in the analytic framework for that study area, and contained reported results. Exclusion criteria for the evidence report update were that the study did not address a key question, lacked reported results, had a study population that was not relevant to the Medicare population (i.e., children and pregnant adults) or substituted for a service that did not historically require face-to-face encounters (e.g., diagnostic services in radiology or pathology).

We categorized the included articles by the key question(s) they addressed. The included studies for each study area and key question were critically appraised to determine the strengths and limitations of the most important studies following a detailed rationale for the appraisal of study characteristics related to quality.

For each study area, we constructed an evidence table summarizing the strength of the evidence for each key question. We then constructed summary tables for clinical specialties or domains. For studies of diagnosis and management decisions, we explicitly noted whether studies assessed concordance (without a diagnostic gold standard) or accuracy (with a gold standard) of the telemedicine system when compared to conventional care.

## Results

### General Observations

Following review of the abstracts of all studies retrieved in the literature search, a total of 597 citations were determined potentially to have evidence for the efficacy of one of the three study areas. The full text of these 597 articles was reviewed. After exclusion criteria were applied, there were 97 articles included in evidence tables. Of these, 35 articles assessed store-and-forward telemedicine services, 27 articles evaluated home-based services, and 38 articles assessed office/hospital-based services. Some studies assessed more than one telemedicine study area.

### Specific Results

Individual studies were assessed for evidence based on criteria applicable to the study question. Studies were too heterogeneous to undertake any quantitative aggregate analyses such as meta-analysis.

Store-and-forward telemedicine. Similar to our original evidence report, the studies we found of store-and-forward telemedicine only assessed diagnosis or management decisions and not outcomes. As we also found in the original report, some aspects of the telemedicine systems used in home and office-hospital settings made use of store-and-forward techniques, but in the context of larger and/or interactive interventions.

1. Does store-and-forward telemedicine result in comparable diagnostic decisions and recommendations for clinical management?

Similar to the original report, the largest number of studies came from the specialty of dermatology. The most commonly assessed aspect of teledermatology was interobserver concordance. The range of concordance varied widely, from 41 percent to 87 percent for complete agreement to 51 percent to 96 percent for disease-category agreement. All of these studies were limited by the lack of measurement of concordance among more than one face-to-face examiner. Concordance studies assessing management decisions typically looked at decision to biopsy. While one study found complete agreement, others found lesser concordance. The studies of diagnostic accuracy typically compared the telemedicine diagnosis to some sort of gold standard, often a biopsy of a pigmented lesion. In these studies, telemedicine generally was nearly as good as face-to-face in correctness of diagnosis. The second most frequently studied clinical area was wound care. These studies demonstrated that some characteristics of skin wounds and ulcerations could be assessed effectively using store-and-forward telemedicine. However, most of these studies had small numbers of patients and very small numbers of clinicians, raising statistical power issues. Five studies provide data on store-and-forward applications in ophthalmology. Four of these studies show that a high accuracy of diagnosing diabetic retinopathy could be obtained. Other specialties studied included gynecology and gastroenterology.

2. Does store-and-forward telemedicine result in comparable health outcomes?

Similar to the previous report, there were no studies that assessed health outcomes using store-and-forward telemedicine interventions. This is problematic for assessing the overall benefit of store-and-forward telemedicine, since the outcomes from its use for diagnosis and management decisions are unclear.

3. Does the availability of store-and-forward telemedicine services improve access to care?

When store-and-forward telemedicine systems have been evaluated as a method for performing specialty consultations of patients followed by general practitioners or primary care clinicians, the systems have had only a small impact on reducing the need for subsequent face-to-face clinical evaluations by specialists. While these systems can aid in the triage of patients referred for consultation, they have not been shown conclusively either to improve access to care or to have a negative influence on access to care. Five studies reported evidence on the effect of store-and-forward techniques upon access to care. The methodologic quality of these studies generally was low.

Home-based telemedicine. Home-based telemedicine is most commonly used for management of chronic diseases or specific conditions, such as heart disease, diabetes mellitus, and rehabilitation. Some studies show telemedicine applied in this setting can be efficacious, although many are limited by small sample sizes, inadequate length of follow-up, and inconclusive results.

1. Does home-based telemedicine result in comparable diagnostic decisions and recommendations for management?

Two studies assessed diagnostic capabilities in the home in the areas of congestive heart failure assessment and pulmonary function monitoring. These studies found various levels of agreement and disagreement depending on the specific observation.

2. Does home-based telemedicine result in comparable health outcomes?

A variety of published studies have assessed chronic diseases afflicting patients in the Medicare population, such as congestive heart failure, diabetes mellitus, coronary artery disease, and hypertension. Unfortunately, the studies are very heterogeneous, and their limitations prevent broad conclusions. Interventions showing multi-faceted interventions demonstrate more benefit than single interventions, such as monitoring of blood sugar or blood pressure. However, in most studies, it is not possible to assess whether improved outcomes are due to the increased level of care provided by dedicated clinical staff versus the technology intervention.

3. Does the use of home-based telemedicine improve access to care?

No studies were identified that examined the effect of home-based telemedicine services on access to care.

Office/hospital-based telemedicine. A variety of studies were found that assessed office/hospital-based telemedicine. The largest number of studies assessed diagnosis and management decisions, and these studies examined a broad range of medical specialties. There were, however, very few studies of high methodologic quality.

1. Does office/hospital-based telemedicine services result in comparable diagnosis and appropriateness of recommendations for management?

For diagnosis and management decisions, the most frequently studied specialty was ophthalmology. As with store-and-forward studies, some aspects of ophthalmologic evaluation were amenable to interactive telemedicine, while others were not. Other frequently studied specialties included neurology and psychiatry, which demonstrated that some diagnostic assessments can be successfully administered via telemedicine.

2. Does office/hospital-based telemedicine result in comparable health outcomes?

Studies of outcomes also showed that for most of the clinical specialties assessed, outcomes with telemedicine interventions are comparable to those using conventional clinical evaluations. However, most of these studies are limited by small sample sizes and/or other problems. None of these studies attempted to measure their statistical power to avoid type-2 (beta) errors.

3. Does the availability of office/hospital-based telemedicine improve access to care?

Studies having relatively weak methodologies suggest that office/hospital-based telemedicine can improve access to care for patients in rural locations in medical applications in which patient evaluations can be performed using standard teleconferencing equipment.

## Discussion

This update on evidence about the efficacy of telemedicine for the Medicare population covered published peer-reviewed literature for the five years between 2000 and 2004. Similar to the findings of our original report a half-decade ago, there are still serious gaps in the evidence base for telemedicine. While this situation is hardly unique to telemedicine, having a solid evidence base is essential given that there is increased advocacy for health care payers, especially Medicare, to provide coverage for its use.

The best evidence for the effectiveness of telemedicine is in medical specialties for which verbal interactions are a key component of the patient assessment, such as psychiatry and neurology. Various psychiatric and neurological assessments can be administered effectively via interactive videoconferencing. Likewise, treatments administered in these specialties via telemedicine appear to achieve comparability with face-to-face care.

Our systematic review also identified several studies, a few of them of high methodologic quality, showing benefits of home-based telemedicine interventions in chronic diseases. These systems appear to enhance communication with health care providers and provide closer monitoring of general health, but the studies of these techniques were conducted in settings that required additional resources and dedicated staff. With ongoing improvements in telecommunications technology, particularly broadband connections to the home, further research, including larger clinical trials, will likely be informative.

The specialty with the largest number of studies is dermatology, and most studies of teledermatology have evaluated store-and-forward techniques. The body of evidence summarized in this report is consistent with the findings of the earlier report. There continues to be highly variable rates of interobserver and intraobserver agreement in diagnoses. This issue can only be resolved by high-quality studies that compare not only the concordance of telemedicine versus face-to-face diagnosis, but also the concordance of face-to-face versus face-to-face diagnosis in the same situation.

Of course, rates of concordance in a vacuum, i.e., without a clinical context of how the patient fared, are also limited from an evidence standpoint. What we ultimately need to know is the patient outcome. In other words, did the teledermatology encounter at least provide comparable care for the patient? A corollary question that must be answered is whether teledermatology resulted in harm from any missed diagnoses or other consequences of the telemedicine encounter. These questions can only be answered in studies of clinical outcomes, none of which were identified in this report. In general, advocacy for an expanded role for teledermatology will require further studies that examine rates of missed diagnoses, incorrect treatments, and when the technology is insufficient to avoid in-person encounters.

Other widely studied domains include ophthalmology and wound care. Teleophthalmology appears to result in high rates of diagnostic concordance and accuracy, but only for some eye conditions. It appears to be particularly efficacious in assessment of diabetic retinopathy. Studies of wound care show potential, but are limited by small sample sizes, use of only one assessor, and lacking comparison to other in-person examiners when assessing concordance.

There may be situations when the use of telemedicine is warranted even if the evidence is lacking. For example, there may be situations when care would be otherwise impossible to deliver except via telemedicine. This could include remote rural areas or other locations where medical care is not available locally and the patient is for whatever reason unable to travel to a setting where it can be obtained. However, even in these instances it is important to understand the efficacy of telemedicine so that any clinical shortcomings can be anticipated.

The present evidence base provides guidance on the clinical areas in which future research is most likely to be useful. It now is clear that continued small or methodologically weak studies are unlikely to add to the evidence base for telemedicine. In teledermatology, larger and more comprehensive analyses that assess key patient outcomes are needed. Likewise, there is a need for similar studies of clinical outcomes using office/hospital-based telemedicine in fields such as psychiatry and neurology. Well-designed randomized controlled trials will likely provide valuable information on the potential of these clinical applications. Longitudinal observational studies and demonstration projects also will be useful. Studies of home-based telemedicine should carefully address the independent contributions of technology and human resources in the complex delivery models for patients with chronic diseases.