# Acknowledgments

Valuable assistance for this project was provided by external peer reviewers, and the research team would like to acknowledge their helpful contributions to the project. A listing of those individuals appears in Appendix D. We also acknowledge the efforts of the Evidence-based Practice Center support staff, specifically Andrew Hamilton, MLS, MS. Our Task Order Officer from the Agency for Healthcare Research and Quality, Martin Erlichman, MS, also provided invaluable assistance and guidance in the preparation of this report.