# Discussion

## Evidence about Efficacy

This update on evidence about the efficacy of telemedicine for the Medicare population covered published peer-reviewed literature for the five years between 2000 and 2004. Similar to the findings of our original report a half-decade ago, there are still serious gaps in the evidence base for telemedicine. While this situation is hardly unique to telemedicine, having a solid evidence base is essential given that there is increased advocacy for health care payers, especially Medicare, to provide coverage for its use. In the discussion that follows, we will review telemedicine by specialty in the case of store-and-forward and office/hospital-based telemedicine and by disease domain in the case of home-based telemedicine.

The best evidence for the effectiveness of telemedicine is in medical specialties for which verbal interactions are a key component of the patient assessment, such as psychiatry and neurology. Various psychiatric and neurological assessments can be administered effectively via interactive videoconferencing. Likewise, treatments administered in these specialties via telemedicine appear to achieve comparability with face-to-face care. It can probably be concluded that medical care administered via interactive videoconferencing can achieve results that are comparable to their in-person counterparts.

Our systematic review also identified several studies, a few of them of high methodologic quality, showing benefits of home-based telemedicine interventions in chronic diseases. These systems appear to enhance communication with health care providers and provide closer monitoring of general health, but the studies of these techniques were conducted in settings that required additional resources and dedicated staff. Deployment of home monitoring technology in the absence of these integrated systems is unlikely to be beneficial. Systems designed to facilitate specific aspects of care, such as blood sugar and blood pressure measurements, provide less clear benefit. With ongoing improvements in telecommunications technology, particularly broadband connections to the home, further research, including larger clinical trials, will likely be informative.

The specialty with the largest number of studies is dermatology, and most studies of teledermatology have evaluated store-and-forward techniques. The body of evidence summarized in this report is consistent with the findings of the earlier report. There continues to be highly variable rates of interobserver and intraobserver agreement in diagnoses. This issue can only be resolved by high-quality studies that compare not only the concordance of telemedicine versus face-to-face diagnosis, but also the concordance of face-to-face versus face-to-face diagnosis in the same situation. It should be noted that the teleophthalmology field has done this in most of their diagnostic concordance studies.

The published studies of teledermatology have other flaws as well. For example, most of them included only a small number of teledermatologists. Over half of the studies we identified used three or fewer teledermatologists. In addition, most of the studies deployed teledermatology only in a laboratory type of setting. The few studies of real-world use of teledermatology found that most patients required subsequent face-to-face clinical encounters. Thus, it appears that the expense and time commitment of teledermatology systems have not yet demonstrated the potential for improving access to care.

Of course, rates of concordance in a vacuum, i.e., without a clinical context of how the patient fared, are also limited from an evidence standpoint. What we ultimately need to know is the patient outcome. In other words, did the teledermatology encounter at least provide comparable care for the patient? A corollary question that must be answered is whether teledermatology resulted in harm from any missed diagnoses or other aspects of the telemedicine situation. These questions can only be answered in studies of clinical outcomes, none of which were identified in this report. One study has been completed (personal communication, J Whited), but at the time of this writing has not yet been submitted for publication. In general, advocacy for an expanded role for teledermatology will require further studies that examine rates of missed diagnoses, incorrect treatments, and when the technology is insufficient to avoid in-person encounters.

Most published studies of teledermatology have examined store-and-forward techniques, with relatively few studies of real-time office-based techniques. Despite its current widespread use, additional evidence is required to conclude that store-and-forward teledermatology can be routinely substituted for face-to-face encounters in the evaluation of new referrals to dermatologists. Dermatologic practice also involves follow-up visits of patients who have previously received a comprehensive dermatologic evaluation. Store-and-forward teledermatology may be better suited to such follow-up visits, but there have been no published reports of experience with this type of visit. Store-and-forward techniques also may be a useful adjunct in dermatologic consultations for settings in which patients are located a great distance from the consultant (such as isolated rural settings). The published studies suggest that a fraction of such patients may successfully avoid face-to-face visits to complete the dermatologic evaluation.

Teleophthalmology has been widely studied, and this field has produced commercial systems for retinal photographs that are becoming widely used as a clinical tool to augment face-to-face evaluations of patients at risk for diabetic retinopathy.^73^ The quality of studies in this domain is slightly higher than in dermatology, although the results are equivocal. Essentially, teleophthalmology results in high rates of diagnostic concordance and accuracy for only some eye conditions. It appears to be most efficacious for the assessment of diabetic retinopathy. However, there are a number of diagnoses for which it fares less well, and it is often unusable altogether when certain patient characteristics are present, such as cataracts and other lens abnormalities. The value of a technology that is only useful for some conditions must be assessed in the larger picture of clinical outcomes and ultimately the economics of investing in equipment that is not always useful.

Also widely studied is the use of telemedicine for wound care. The key observation from studies assessing telemedicine for this purpose is that all of the studies have small sample sizes, use only one assessor, and do not compare in-person examiners when assessing concordance. These studies present a trend of comparability, but serious questions remain about their statistical power and reproducibility.

The situation of gynecology, in particular telecolposcopy, is also instructive. Studies show that the accuracy of diagnosis by telemedicine is comparable to face-to-face assessment. However, the accuracy of neither of these approaches is terribly efficacious, in the range of 50–60 percent.

An often-touted benefit of telemedicine is the provision of care to rural areas, where specialists are less prevalent and individuals in need of them must travel great distances to see them. Studies of rural populations have tended to be of poorer methodological quality than studies of urban and suburban populations. The limited evidence available supports the use of office/hospital-based telemedicine for providing continuity care of stable patients by specialists. The technological platform for such systems is relatively uncomplicated and can be based on widely available teleconferencing equipment.

In general, the role of telemedicine most likely to demonstrate value could be as an adjunct to care that is centered around the in-person visit. As noted above, it could, for example, serve as a means to triage skin lesions, injuries, and other problems that arise where appropriate specialty care is not available. In most instances, clinical care will likely still require in-person diagnosis and management. Likewise, telemedicine may also play a role in managing the growing number of elderly and other infirmed individuals with chronic diseases. Its value may not be as a substitute for in-person care as much as an adjunct to it.

Experience with telemedicine has similarities to other attempts to apply computer technology to clinical environments. Computer-based expert systems went through a long period of experimental evaluation and limited deployment, and systems designed to enhance (or even replace) clinician judgment were found to be best suited to narrow clinical domains.^74^–^76^ Nevertheless, the use of computer-based decision support has steadily increased, as it has been more appropriately integrated into the clinical care process, serving more as an assistant than a replacement of clinical judgment and expertise.^77^ Well-designed and definitive clinical trials of this type of decision support have enhanced the adoption of the technology.^78,^ ^79^

As noted in Chapter 1, this review is limited in scope to the peer-reviewed literature of telemedicine. While this spectrum of data does not cover all or even most of the experience with telemedicine, it does provide the most objective, evidence-based assessment of this technology. The presence of a small number of well-designed studies with positive outcomes that our analysis identified shows that it is possible to demonstrate efficacy of telemedicine.

Of course, there may be situations when the use of telemedicine is warranted even if the evidence is lacking. For example, there may be situations when care would be otherwise impossible to deliver except via telemedicine. This could include remote rural areas or other locations where medical care is not available locally and the patient is for whatever reason unable to travel to a setting where it can be obtained. However, even in these instances it is important to understand the efficacy of telemedicine so any clinical shortcomings can be anticipated. We are reassured that no studies show telemedicine to cause any significant harm.

We also acknowledge that the efficacy of telemedicine is not immune to other forces in health care, such as the structure of the delivery system. There are instances when reimbursement or other incentives are not amenable to innovations, technical or otherwise. In particular, fee-for-service health care will likely provide incentive for modalities of care that are reimbursed, not necessarily those that provide the best quality care. Therefore it will be important for ongoing research to take into account the health care setting when evaluating the efficacy of telemedicine.

## Future Research

The present evidence base provides guidance on the clinical areas in which future research is most likely to be useful. It now is clear that continued small or methodologically weak studies are unlikely to add to the evidence base for telemedicine. In teledermatology, larger and more comprehensive analyses that assess key patient outcomes are needed. Likewise, there is a need for similar studies of clinical outcomes using office/hospital-based telemedicine in fields such as psychiatry and neurology. Well-designed RCTs will likely provide valuable information on the potential of these clinical applications. Longitudinal observational studies and demonstration projects also will be useful. Studies of home-based telemedicine should carefully address the independent contributions of technology and human resources in the complex delivery models for patients with chronic diseases.

We recognize the limitations of advice that telemedicine be studied with more and larger RCTs. Not only are such trials expensive, but they are difficult to carry out. They also have a long lead-time from their planning and inception to completion and analysis of results. Another challenge with RCTs in this area is that telemedicine is not a single technology or intervention. It is a tool that is used to deliver different aspects of clinical care for diverse diseases. Due to the time and expense of RCTs, other means to assess telemedicine interventions objectively should also be explored. Given the growing use of electronic health records, selective data could be extracted on patients with telemedicine interventions to assess them longitudinally. Such studies will be most feasible in large integrated delivery networks with advanced electronic health record systems.

This report has found that the evidence base for telemedicine is incomplete yet improving. Further well-designed and targeted research that provides high-quality data will provide a strong contribution to understanding how best to deploy technological resources in health care.

## Conclusion

The promise of telemedicine is not matched by the strength of its evidence base. The technology to administer telemedicine is prevalent and, in some locations, ubiquitous. Telemedicine is widely used, with increasing numbers of health care payers reimbursing for its use. However, outside of a small number of clinical specialties, the evidence base for the efficacy of telemedicine is weak. Areas where telemedicine is most promising include home health and specialties where care can be delivered via interactive videoconferencing, such as psychiatry and neurology. There is mixed evidence for the efficacy of telemedicine in dermatology and ophthalmology. Further research must address the limited evidence base so that the optimal use of telemedicine can be ascertained.