# Results

## Overview of Peer-reviewed Studies

As in the previous report, there were a large number of studies that met our inclusion criteria (Table 7), yet the methodology of many studies was weak (Table 8). Only a quarter of the studies met the criteria for Class I methodology, and even these had problems such as relatively small sample size and inadequate description of study details, such as concealment of allocation and other aspects of the randomization process. Some studies were included in more than one telemedicine study area.

Table 7 Summary of included studies

| UPDATE | | | | ORIGINAL REPORT
Modality | Diagnosis and management | Access | Outcomes | Total | Diagnosis and management | Access | Outcomes | Total
Store and forward | 30 | 5 | 0 | 35 | 22 | 2 | 0 | 24
Home-based | 2 | 0 | 25 | 27 | 4 | 2 | 19 | 25
Office/hospital-based | 20 | 9 | 9 | 38 | 33 | 7 | 6 | 46
Total | 52 | 14 | 34 | 100 | 59 | 11 | 25 | 95

Table 8 Summary of studies by key questions and results

Summary by key question | Total | I-A | I-B | I-C | II-B | II-C | II-D | III-B | III-C
Diagnosis and management store-and-forward | 30 | 2 | 3 | 2 | 21 | 2 | 0
Diagnosis and management home-based | 2 | 0 | 0 | 0 | 0 | 2 | 0
Diagnosis and management office/hospital-based | 20 | 1 | 3 | 1 | 13 | 2 | 0
Diagnosis and management total | 52 | 3 | 6 | 3 | 34 | 6 | 0
Outcomes store-and-forward | 0 | 0 | 0 | 0 | 0 | 0 | 0
Outcomes home-based | 25 | 6 | 2 | 0 | 17 | 0 | 0
Outcomes office/hospital-based | 9 | 2 | 0 | 0 | 6 | 1 | 0
Outcomes total | 34 | 8 | 2 | 0 | 23 | 1 | 0
Access store-and-forward | 5 | 0 | 1 | 0 | 1 | 0 | 0 | 2 | 1
Access home-based | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
Access office/hospital-based | 9 | 0 | 1 | 1 | 3 | 1 | 0 | 3 | 1
Access total | 14 | 0 | 2 | 1 | 4 | 1 | 0 | 5 | 2
All total | 100 | 11 | 10 | 4 | 61 | 8 | 0 | 5 | 2

Another problem with many of these studies concerns a statistical issue. As noted earlier, the goal of most telemedicine studies is only to show that telemedicine is “comparable” to in-person care, not necessarily “better,” especially when it can provide that care with decreased cost, increased convenience, and/or access to care when none was previously available. One way to determine whether two approaches are comparable is to show there is no statistically significant difference between them. However, lack of statistical significance can also occur even when there is a difference, but the study lacks adequate statistical power to detect it. For this reason, studies with small sample sizes should compute, in addition to an alpha value (the well-known p value), the value of beta. This value estimates the probability that a difference between two comparison groups truly exists when the study results fail to show a difference (also known as a type 2 error). Virtually none of the studies we reviewed assessed beta error, and as such, the “statistical comparability” may exist because there was inadequate statistical power to show otherwise.

In assessing diagnostic and management decision studies, a Class I study had to include not only a comparison of the telemedicine and in-person decisions but also one of the following:

- In the case of concordance studies, a comparison of a “baseline” concordance between two or more face-to-face examiners,
- In the case of accuracy studies, have measurement against a suitable “gold standard” with measures such as sensitivity and specificity.

Therefore, when there was just a comparison of telemedicine and in-person concordance, the study was rated as Class II. Studies were also rated as Class II when the diagnostic assessment did not include a definitive gold standard consisting of an objective test (e.g., biopsy) or a commonly accepted clinical judgment (e.g., visual findings on gastrointestinal endoscopy or of diabetic retinopathy). Class III studies were excluded from our analysis of diagnosis and management decisions.

For the strength of evidence, a grade of A or B was given when the study set out to demonstrate comparability and did so. Class II studies were not graded higher than B, since studies with this level of methodology do not have the quality of evidence to provide convincingly strong results.

For outcomes studies, a Class I study had to be a randomized controlled trial (RCT). RCTs with clear and obvious flaws were rated as Class II, as were cohort, pre-post, and observational studies. For the strength of evidence, a grade of A or B was given when the study set out to demonstrate comparability and did so, or when the study set out to show superiority of telemedicine and did so. Similar to diagnostic and management efficacy studies, Class II studies of outcomes were also not graded higher than B.

## Store-and-Forward Telemedicine

Similar to our original evidence report, the studies we found of store-and-forward telemedicine only assessed diagnosis or management decisions and access to care, but not clinical outcomes (Evidence Tables 1 and 2 ^1^). As we also found in the original report, some aspects of the telemedicine systems in home and office-hospital settings made use of store-and-forward techniques, but in the context of larger and/or interactive interventions. A summary of all studies by medical specialty is shown in Table 9, which also includes a tally of those from our original report. Studies graded A or B for effect indicate comparability for telemedicine.

1 Evidence tables cited in this report are provided electronically at http://www.ahrq.gov/downloads/pub/evidence/pdf/telemedup/telemedup.pdf in Appendix C.

Table 9 Summary of studies of store-and-forward telemedicine for diagnosis and/or management decisions

UPDATE | Total | I-A | I-B | I-C | II-B | II-C | II-D | III-B | III-C
Dermatology | 13 | | 2 | | 9 | 2
Gastroenterology | 2 | | | | 2
Gynecology | 3 | | | 2 | 1
Ophthalmology | 5 | 2 | 1 | | 2
Plastic Surgery | 7 | | | | 7
Total | 30 | 2 | 3 | 2 | 21 | 2 | 0
ORIGINAL | Total | I-A | I-B | I-C | II-B | II-C | II-D | III-B | III-C
Ambulatory Care | 1 | | | | | 1
Dentistry | 1 | | | | | 1
Dermatology | 9 | | 2 | | 5 | | | 2
Neonatology | 1 | | | | | | | 1
Ophthalmology | 5 | | | | 2 | 1 | 1 | 1
Otolaryngology | 2 | | | | 1 | | | 1
Wound Care | 1 | | | | 1
Total | 20 | 0 | 2 | 0 | 9 | 3 | 1 | 5

Also similar to the original report, the largest number of studies came from the specialty of dermatology (Table 9). Of the 13 studies published since the last report, ten assessed some aspect of concordance, and four looked at accuracy. One study assessed aspects of both. Of the concordance studies, eight assessed diagnostic decisions and four assessed management decisions; two studies assessed both. Two of the diagnostic studies looked at some aspect of intraobserver concordance, while the remainder assessed interobserver concordance.

The most commonly assessed aspect of teledermatology was interobserver concordance.^13^–^19^ The range of concordance varied widely, from 41 percent to 87 percent for complete agreement to 51 percent to 96 percent for disease-category agreement. Unfortunately, all of these studies were limited by the lack of measurement of concordance among more than one face-to-face examiner. In other words, none of the studies compared face-to-face versus telemedicine agreement with face-to-face versus face-to-face agreement. As such, none of the studies could be rated as Class I. In our previous report, two studies did assess concordance of face-to-face examiners.^20, ^ ^21^ Concordance studies assessing management decisions typically looked at decision to biopsy. While one study found complete agreement,^22^ others found lesser concordance.^13, ^ ^23^–^25^

The studies of diagnostic accuracy typically compared the telemedicine diagnosis to some sort of gold standard, often a biopsy of a pigmented lesion.^13, ^ ^23, ^ ^26, ^ ^27^ Most of these studies did not calculate statistical significance, but some did show a trend towards less accuracy for telemedicine.

Store-and-forward applications of teledermatology have generally used commonly available digital cameras and varying techniques for storing and transmitting the digital photographs. Teledermoscopy is a technique by which a low-power lens is used to generate a magnified image of a discrete skin lesion. This methodology was tested in two studies of store-and-forward techniques and found to be comparable to face-to-face diagnosis of pigmented lesions.^26, ^ ^27^

The second most frequently studied clinical area was wound care. Seven studies, all Class II, demonstrated that some characteristics of skin wounds and ulcerations could be assessed effectively using store-and-forward telemedicine. However, most of these studies had small numbers of patients and very small numbers of clinicians, raising the statistical power issues described above.

Five studies provide data on store-and-forward applications in ophthalmology. Four of these studies show that a high accuracy of diagnosing diabetic retinopathy (DR) could be obtained.^28^–^31^ One of them found, however, that concordance was lower for severity of DR and specific abnormalities.^31^

Other specialties studied include gynecology and gastroenterology. The gynecology studies assessing colposcopy were hindered by the limitations of that procedure even when done in person.^32, ^ ^33^

Five studies published in 2000-2004 reported evidence on the effect of store-and-forward techniques upon access to care. The clinical domains of these five studies are summarized in Table 10. Details of the studie' designs and findings are provided in Evidence Table 2 ^2^. The methodological quality of these studies generally was low.

2 Evidence tables cited in this report are provided electronically at http://www.ahrq.gov/downloads/pub/evidence/pdf/telemedup/telemedup.pdf in Appendix C.

Table 10 Summary of studies of the effects of store-and-forward telemedicine on access to care

UPDATE | Total | I-B | II-B | III-B | III-C
Dermatology | 2 | 1 | | | 1
Ophthalmology | 1 | | | 1
General Surgery | 1 | | | 1
Multiple Specialties | 1 | | 1
Total | 5 | 1 | 1 | 2 | 1
ORIGINAL | Total | I-B | II-B | III-B | III-C
Dermatology | 2 | | 1 | | 1

The studies of access provide information about how telemedicine systems have been deployed in real-world situations and thereby provide an estimate of the actual clinical impact of the systems. All of the studies measured utilization of traditional (non-telemedicine) clinical services following the telemedicine intervention, and all reported the proportion of patients for whom the telemedicine service was the only care received in the index clinical episode. However, two of the studies^34, ^ ^35^ collected no data to assess whether the care provided by the telemedicine service was adequate.

All of the studies that included data on access to care examined the deployment of store-and-forward telemedicine systems for screening patients referred for medical or surgical specialty services following referral by clinicians in primary care or general practice settings. One study^36^ used only text information submitted by electronic mail, while the other four studies all were based on the collection of digital photographs, usually to supplement conventional clinical information submitted in a text format. The effect on utilization of specialty services was generally modest. In the two studies of teledermatology, more than 80 percent of patients were recommended to have subsequent face-to-face evaluations by dermatologists.^37, ^ ^38^ In a randomized trial of all specialty consultation requests in a rural Finnish community, the electronic mail-based store and forward system had no effect on the proportion of patients who received follow-up care in the local community rather than at the regional centers providing specialty services.^36^ The two other studies^34, ^ ^35^ used photography-based screening systems by which the majority of patients were recommended not to have specialty follow-up. However, these studies were of relatively low quality and did not collect any follow-up information on the screened patients.

The only study of access to care that was given a Class I rating evaluated a store-and-forward technique for screening primary care patients referred for dermatologic consultation in a Veterans Affairs medical center.^38^ That study was a randomized trial that included a measure of the time to completion of the consultation. Dermatologists evaluating the patients randomized to teledermatology could determine the time interval to a face-to-face dermatology appointment, while patients randomized to the conventional care group had only a routine appointment scheduled. Patients randomized to the teledermatology group had significantly shorter time intervals until the face-to-face appointment. We judged this to be an unfair comparison, because the study design itself favored improved access to care for the teledermatology group. Since it is likely that the hospital in which the study was conducted had a fixed number of appointment slots for the dermatology clinic, scheduling sooner appointments for patients in the teledermatology group would tend to reduce the pool of available appointments and cause the appointments available to the patients randomized to the conventional care group to be, on average, further distant in time.

## Home-Based Telemedicine

In contrast to store-and-forward telemedicine, though similar to our original report, most studies of home-based telemedicine evaluated the clinical outcomes of interventions (see Table 11). Two studies did assess diagnostic capabilities in the home, finding various amounts of agreement and disagreement depending on the observation (see Evidence Table 3 ^3^). Most outcomes studies included patients with chronic diseases common in the Medicare population, such as congestive heart failure, diabetes mellitus, coronary artery disease, and hypertension (see Evidence Table 4*).

3 Evidence tables cited in this report are provided electronically at http://www.ahrq.gov/downloads/pub/evidence/pdf/telemedup/telemedup.pdf in Appendix C.

Table 11 Summary of studies of home-based telemedicine for clinical outcomes

UPDATE | Total | I-A | I-B | I-C | II-B | II-C | II-D | III-B
Congestive Heart Failure | 6 | 1 | 1 | | 4
Chronic Disease | 3 | 1 | | | 2
Coronary Artery Disease | 2 | 1 | | | 1
Diabetes Mellitus | 5 | 1 | 1 | | 3
Hypertension | 3 | 1 | | | 2
Lung Transplantation | 1 | | | | 1
Multiple Sclerosis | 1 | | | | 1
Spinal Cord Injury | 1 | 1
Obesity | 1 | | | | 1
Psychiatry | 1 | | | | 1
Pulmonary Medicine | 1 | | | | | 1
Total | 25 | 6 | 2 | 0 | 17 | 0 | 0
ORIGINAL | Total | I-A | I-B | I-C | II-B | II-C | II-D | III-B
AIDS | 2 | 1 | 1
Alzheimer’s | 1 | | 1
Cardiology | 1 | | | | 1
Chronic Disease | 3 | | 1 | | 1 | | | 1
Diabetes Mellitus | 10 | 1 | 1 | | 8
Hypertension | 2 | 1 | 1
Neonatology | 1 | | 1
Pulmonary | 1 | | | | | | | 1
Total | 21 | 3 | 6 | 0 | 10 | 0 | 0 | 2

A common characteristic of the studies of home-based telemedicine was that the intervention included dedicated staff (usually nursing staff) that monitored the data recorded in the home and developed clinical management plans. Some of the studies were randomized controlled trials that compared such systems (technology and dedicated staff) to conventional care (such as visiting nurse services). These studies found improved outcomes with the telemedicine-based interventions, but the design of the studies made it difficult to discern the benefit of the dedicated program staff from the telemedicine intervention.

While a small number of the studies were well-designed RCTs,^39^–^43^ the rest were limited by either small sample sizes and/or control groups of dubious value. In addition, while all of the studies assessed achieved at least comparable benefits in clinical outcomes, and thus obtained an effect rating of A or B, the value of such comparability (e.g., same but not better blood sugar control or weight loss) was not clear.

Three studies of chronic disease in the elderly showed benefit of the dedicated programs in both patient functional status and reduced emergency department visits and hospital admissions.^40^–^44^ Some interventions tailored for specific diseases were found to be effective in congestive heart failure (CHF), hypertension, and pulmonary disease.^39, ^ ^42^–^45^ Other home-based interventions, such as blood sugar measurements intended to improve management of diabetes mellitus, were not found consistently superior to usual care.^46^–^50^ Interventions in other domains, such as obesity^51^ and lung transplantation,^52^ also failed to show benefit over usual care.

While two studies were identified in the original report that examined the effect of home-based telemedicine systems on access to care, no studies were identified in the 2000-2004 period. Home-based systems have nearly always been used to enhance the care of patients who already receive conventional clinical services, either through clinic visits or via home care agencies. The primary rationale for home-based telemedicine is to improve data collection and/or communication rather than to supplant conventional care (such as clinic or home visits). Thus, the lack of studies examining conventional measures of access to care is not surprising. Expanded definitions of access to care, such as “patient-centered access”^11^ are applicable to home-based systems and may provide suitable models for future research on the deployment of home-based systems.

## Office/Hospital-Based Telemedicine

Studies of office/hospital-based telemedicine provide evidence on diagnosis and management decisions (see Table 12 and Evidence Table 5 ^4^), clinical outcomes (see Table 13 and Evidence Table 6*), and access to care (see Table 14 and Evidence Table 7*).

4 Evidence tables cited in this report are provided electronically at http://www.ahrq.gov/downloads/pub/evidence/pdf/telemedup/telemedup.pdf in Appendix C.

Table 12 Summary of studies of office/hospital-based telemedicine for diagnosis and/or management decisions

UPDATE | Total | I-A | I-B | I-C | II-B | II-C | II-D | III-B | III-C
Cardiology | 2 | | | | 2
Dermatology | 1 | | | | 1
Gastroenterology | 1 | | | | 1
Neurology | 4 | | | | 4
Ophthalmology | 5 | | 1 | 1 | 1 | 2
Otolaryngology | 2 | | 1 | | 1
Psychiatry | 3 | 1 | | | 2
Rheumatology | 1 | | 1
Vascular Surgery | 1 | | | | 1
Total | 20 | 1 | 3 | 1 | 13 | 2 | 0 | 0 | 0
ORIGINAL | Total | I-A | I-B | I-C | II-B | II-C | II-D | III-B | III-C
Cardiology | 5 | | 1 | | 3 | | | | 1
Dentistry | 1 | | | | | | | | 1
Dermatology | 7 | | | | | 2 | | | 5
Emergency Medicine | 3 | | | | 3
Neurology | 2 | | 1 | | 1
Ophthalmology | 2 | | | | | 1 | | 1
Otolaryngology | 2 | | | | 1 | | | 1
Psychiatry | 7 | | 2 | | 5
Pulmonary | 1 | | | | 1
Rheumatology | 1 | | | | | | 1
Trauma | 1 | | | | 1
Urology | 1 | | | | | | | | 1
Total | 33 | 0 | 4 | 0 | 15 | 3 | 1 | 2 | 8

Table 13 Summary of studies of office/hospital-based telemedicine for clinical outcomes

UPDATE | Total | I-A | I-B | I-C | II-B | II-C | II-D | III-B
Critical Care | 1 | | | | 1
Neurology | 1 | | | | | 1
Orthopedics | 2 | | | | 2
Otolaryngology | 1 | 1
Psychiatry | 3 | 1 | | | 2
Wound Care | 1 | | | | 1
Total | 9 | 2 | 0 | 0 | 6 | 1 | 0
ORIGINAL | Total | I-A | I-B | I-C | II-B | II-C | II-D | III-B
Dermatology | 1 | | | | 1
Emergency Medicine | 1 | 1
Intensive Care | 1 | | | | 1
Neonatology | 1 | | | | 1
Neurosurgery | 2 | | | | | | | 2
Total | 6 | 1 | 0 | 0 | 3 | 0 | 0 | 2

Table 14 Summary of studies of the effect of office/hospital-based telemedicine on access to care

UPDATE | Total | I-B | I-C | II-B | II-C | III-B
Neurology | 2 | | | | 1 | 1
Orthopedics/Rheumatology | 3 | 1 | | 1 | | 1
Ophthalmology | 1 | | | | | 1
Multiple specialties | 1 | | 1
Psychiatry | 1 | | | 1
Hematology | 1 | | | 1
Total | 9 | 1 | 1 | 3 | 1 | 3
ORIGINAL | Total | I-B | I-C | II-B | II-C | III-B
Neurosurgery | 3 | | | 2 | | 1
Cardiology | 2 | | | | | 2
Multiple specialties | 2 | | | | | 2
Total | 7 | 0 | 0 | 2 | 0 | 5

For diagnosis and management decisions, the most commonly studied specialty was ophthalmology. As with store-and-forward studies, some aspects of ophthalmologic evaluation were amenable to interactive telemedicine, while others were not. One Class I study showed rates of disagreement in eye injuries under 10 percent,^53^ while another found disagreement was consistently higher with telemedicine than when comparing two in-person evaluations.^54^

Other frequently studied specialties included neurology and psychiatry. Although the studies were rated Class II, two studies showed neurological diagnosis was highly concordant^55, ^ ^56^ and two studies showed that the NIH Stroke Scale could be reliably administered via telemedicine.^57, ^ ^58^ A few Class II studies demonstrated concordance on a variety of psychiatric scales.^59^–^61^ Studies in other specialties, such as dermatology,^62^ rheumatology,^63^ and vascular surgery^64^ demonstrated that some diagnostic assessments can be successfully administered interactively via telemedicine.

Studies of clinical outcomes also showed that for most of the clinical specialties assessed, outcomes between conventional and telemedicine interventions were comparable. However, most of these studies were limited by small sample sizes (with the caveats concerning statistical significance described earlier), lack of randomization, and assessment of less than the full range of clinical outcomes. None of these studies attempted to measure statistical power to avoid beta error. Class I RCTs showing comparable outcomes were done in otolaryngology^65^ and psychiatry.^66^

The studies of access have examined the use of office-based telemedicine in both suburban and rural settings and have examined both specialist evaluations and follow-up continuity care. In limited studies of patients with sickle cell anemia^67^ and patients with chronic psychiatric disorders,^68^ office-based telemedicine appeared to be adequate for the ongoing routine care of patients in rural areas, with few problems reported. For new evaluations by specialists of patients referred by general practitioners, the use of office-based telemedicine led to a significantly greater rate of diagnostic test utilization than face-to-face consultations for neurology patients^69^ but not for patients needing other types of specialty care.^70, ^ ^71^ Two studies compared office-based telemedicine to telephone consultations between a referring physician and a specialist.^63, ^ ^72^ Both these studies had weak designs but had results suggesting that the telemedicine system provided faster access to definitive care.

## Studies of Telemedicine in Non-Medicare Populations

A total of 28 studies identified in the literature search were excluded from consideration for evidence tables because they were conducted in populations not eligible for Medicare services based on their demographic characteristics. All of these 28 studies were considered to have evidence potentially applicable to the key questions on the basis of the initial title and abstract review. The populations examined in these studies included children, pregnant women, incarcerated prisoners, and active duty military personnel. These studies were subjected to further review, and twelve were deemed to have evidence suitable for inclusion in evidence tables if we had not applied the population exclusion. Seven of the studies examined home-based telemedicine, three examined store-and-forward techniques, and two examined office-based telemedicine applications. The studies' findings were consistent with the findings of the studies included in the evidence tables. We concluded that excluding studies conducted on non-Medicare populations had not biased our overall conclusions.