# Methods

Evidence reports aim to define the limits of the evidence, clarifying when assertions about the value of the intervention are based on strong evidence from clinical studies. The quality of the evidence on effectiveness is a key component, but not the only component, of decision-making on coverage decisions. Both national and local Medicare coverage determinations are also based on whether a service has been determined to be “reasonable and necessary” based on “descriptive information, and scientific and clinical evidence.”^5^

The Medicare Payment Advisory Commission has recognized the value that telemedicine services can add to patient care, particularly following the passage of the Medicare, Medicaid, and SCHIP Beneficiary Act of 2000 (BIPA.)^6^ However, the potential for overuse of telemedicine services and the need for demonstrated efficacy of telemedicine services prior to making coverage decisions remains an overriding concern.

## Analytic Framework and Key Questions about the Efficacy of Telemedicine Services

To determine the key questions and guide the review of the literature in the evaluation of telemedicine, we developed an analytic framework, as shown in Figure 1.

Figure 1. Analytic framework

We then made explicit the key questions for each of the three study areas. For studies of diagnosis and management decisions and of clinical outcomes, the key questions were assessed from the standpoint of determining whether the telemedicine system provided comparable care, since telemedicine can be deemed efficacious when the quality of clinical care provided is as good as, but not necessarily better than, in-person care.

A Store and forward
  1 Does store-and-forward telemedicine result in comparable diagnostic decisions and recommendations for clinical management?
  2 Does store-and-forward telemedicine result in comparable health outcomes?
  3 Does the availability of store-and-forward telemedicine services improve access to care?
B Home-based
  1 Does home-based telemedicine result in comparable diagnostic decisions and recommendations for management?
  2 Does the use of home-based telemedicine result in comparable health outcomes?
  3 Does the use of home-based telemedicine improve access to care?
C Office/hospital-based
  1 Does office/hospital-based telemedicine result in comparable diagnosis and appropriateness of recommendations for management?
  2 Does office/hospital-based telemedicine result in comparable health outcomes?
  3 Does the availability of office/hospital-based telemedicine improve access to care?

## Literature Search Strategy

We searched the literature for information about ongoing telemedicine programs, activities, and services. This search focused on obtaining English-language journal articles and reports pertaining to the three study areas. We identified programs from the following:

Electronic bibliographic database. The search strategy was similar to that used in the prior report. It was designed to find any publications about telemedicine and was used to search the MEDLINE® database using Ovid, version 19.2.0. The key MeSH terms associated with the search include telemedicine, remote consultation, telecommunications and delivery of health care. Appendix A * details the complete search string. The initial search, which identified telemedicine articles published between January 2000 and June 2004, resulted in 3,848 citations. An update of the same strategy in November 2004 yielded 224 additional citations. Other databases, such as EMBASE® and CINAHL®, were not searched, since their coverage tends to duplicate MEDLINE® for telemedicine.

* Appendices cited in this report are provided electronically at http://www.ahrq.gov/downloads/pub/evidence/pdf/telemedup/telemedup.pdf.

Reference lists. Reference lists of previously published telemedicine systematic reviews were searched, resulting in the inclusion of 11 studies to those identified by our search strategy. Of these 11 studies, six were subsequently included following application of the inclusion criteria. Reference lists of included studies also were searched.

## Selection of Abstracts and Full-Text Articles

The results of the literature search and selection of articles for inclusion are shown in Figure 2. All citations were entered into an EndNote® database and were tracked based on inclusion/exclusion status throughout the literature review process.

Figure 2. Results of literature search and abstract review

Note: Articles may fit into more than one key question category.

Four reviewers (WRH, DHH, SMS and TLD) conducted independent screening reviews of all citation titles and abstracts (if available) obtained from the citation acquisition. The citations were dually reviewed. The reviewers read citation titles and abstracts (or titles only if the abstract was not available) to make inclusion decisions for subsequent full-text review. The full-text articles were divided by key question and forwarded to the appropriate investigator for inclusion/exclusion assessment. Table 1 lists the inclusion and exclusion criteria for both the title/abstract level and the full-text level. The inclusion criteria were that the study be relevant to at least one of the three study areas; that it address at least one key question in the analytic framework for that study area; and that it contain reported results (i.e., “data”). Exclusion criteria were that the study did not address a key question, addressed a key question but did not contain reported results, had a study population that was not relevant to the Medicare population, or that the service did not require face-to-face encounters (i.e., radiology or pathology diagnosis). For the store-and-forward area, we included studies that used store-and-forward techniques as well as studies that used systems that could be easily adaptable to store-and-forward. We excluded reports of telephone care programs and equivalent programs that used electronic mail instead of the telephone, although programs that used electronic mail as a substitute for face-to-face encounters were included. We also excluded studies of services that provided medical advice directly to the public.

Table 1 Inclusion/exclusion criteria

Code # | Explanation
| Inclusion
1 | KEY QUESTION AND DATA
| Addresses a key question on one of the service areas and contains data (results)
| Exclusion
2 | NO KEY QUESTION
| Does not address a key question
3 | KEY QUESTION, NO DATA
| Addresses a key question, but does not contain data
4 | WRONG POPULATION
| Addresses key question and contains data, but population of study is outside our scope
5 | GOOD BACKGROUND MATERIAL and/or REVIEW
| However, does not meet inclusion criteria
6 | OTHER
| Indicate reason

Reliability of the inclusion/exclusion decisions was assessed by noting the percent of agreement and kappa values for each pair of reviewers (Table 2). Generally, agreement regarding inclusion or exclusion was high among the reviewers. We retrieved the full-text articles for citations selected for possible inclusion by either reviewer.

Table 2 Inter-rater reliability

Reviewers | Percent agreement | Kappa value
WRH, SMS | 89.5 | .56
WRH, TLD | 91.9 | .59
DHH, SMS | 85.8 | .40
DHH, TLD | 91.2 | .42

## Data Abstraction

All studies rated as relevant on the basis of review of titles and abstracts were retrieved, photocopied, and distributed to one of the investigators (WRH or DHH). Studies judged to have evidence about a key question were then abstracted. For each key question, data from each study were abstracted using electronic abstraction forms (Appendix B ^1^), and entered into an evidence table. Evidence tables are presented in full in Appendix C.* A second investigator reviewed all studies included in evidence tables to verify the evidence table content. The study quality ratings of all included studies were assigned at this time (see further details in the next section). A complete list of excluded studies appears in Appendix D.^*^

1 Appendices cited in this report are provided electronically at http://www.ahrq.gov/downloads/pub/evidence/pdf/telemedup/telemedup.pdf.

## Assessment of Study Quality

We critically appraised the included studies for each study area and key question. Studies that examined the effect of telemedicine activities on clinical outcomes or management were rated for quality according to the scale shown in Table 3.^7^ The optimal design for studies of a diagnostic test is different from the optimal design for studies of therapies. For this reason, we used a separate scale to rate the quality of studies that compared the accuracy of “telediagnoses” to diagnoses made in conventional clinical encounters (Table 4). We also abstracted features of the study design that were likely to be associated with bias in studies of diagnostic test performance.^8, ^ ^9^ We paid particular attention to known problems in telediagnosis studies, such as small sample sizes (less than 10–20 patients), selective application of definitive diagnosis testing, and insufficiently long follow-up to determine diagnosis when a gold-standard test was not or could not be performed.

Table 3 Classification of evidence for studies of clinical outcomes

Study Class | Characteristic
I | Properly designed random controlled trials
II | Random controlled trials that contain design flaws preventing specification of Class I
| Properly designed trials with control groups not randomized
| Multi-center of population-based longitudinal (cohort) study
| Case control studies
III | Descriptive studies (uncontrolled case series)
| Clinical experience
| Expert opinion
| Case reports

Table 4 Classification of evidence for diagnostic and management decisions

Study Class | Characteristic
I | Case series of consecutive patients from relevant population of individuals who would use telemedicine; using an objective gold standard with blinded interpretation of results; with inter-observer analysis
II | Case series of patients from relevant population of individuals who would use telemedicine; using an objective gold standard
III | Case series not from relevant population or not using appropriate methodology for diagnostic test evaluation

In appraising studies addressing access to care, we adapted criteria described by the Institute of Medicine (IOM)^10^ as applied to the use of telemedicine. The model of access to care incorporated three types of indicators: barriers (structural, financial, and personal); utilization; and outcomes (mortality, well-being, or functionality). The IOM has recommended that studies of access to care measure both utilization and outcomes, and our criteria included both measures. Studies that examined only outcomes of care were assigned to the Outcomes category rather than to the Access category.

The definition of access that we used had originally been proposed in a report by the IOM published in 1993^7^ and had been widely disseminated prior to the period of time covered by the studies reviewed for the current report. Other models of access to care have been described,^11, ^ ^12^ but these models include elements of staff deployment and scheduling strategies that have rarely been addressed in studies of telemedicine. Thus, we found the IOM model to be best suited to the published literature in this domain.

Studies of access to care were rated for quality according to the scale shown in Table 5. Review of the studies of access in the original report^1^ showed that the majority relied on utilization indicators alone. A few used indicators of reduced barriers to care. Most studies used models of access that included 1) increased opportunity to obtain a service locally, and 2) reduced amount of time for seeking and/or obtaining care.

Table 5 Classification of strength of evidence for studies of access to care

Study Class | Characteristic
I | Appropriately comparable comparison group not exposed to telemedicine services; valid measures of utilization and outcomes
II | Appropriately comparable comparison group not exposed to telemedicine services; valid measure of utilization
III | Comparison group absent or not comparable in some respects; valid measure of utilization; outcomes may also be measured

Studies in all categories also were classified using a four-level scale that summarized the strength of the study's findings for direction of effect (Table 6). This classification system was modified from the system used in the original report^1^ to reflect that the key questions require only that home-based telemedicine be comparable to rather than superior to conventional care. For those studies, the goal was now to determine whether diagnostic and management decisions or clinical outcomes were comparable, rather than determining the directionality of an effect. Studies were classified as clearly comparable when the confidence for measures of association was high and probably comparable when those measures were lower. The difference in these definitions of direction of effect had a small effect on the classification of studies given a quality rating of I when comparing the findings of the original report and the current report.

Table 6 Classification of direction of effect

A | Strong improvement or clearly comparable
B | Weak improvement or probably comparable
C | Conflicting evidence for improvement or comparability
D | Negative effect (evidence that technology does not provide comparability or improvement)

Because of the larger evidence base for studies of diagnosis/management and clinical outcomes, we excluded Class III studies from the analysis in these categories. Class III studies were included in the evidence tables for access to care. We included tallies of Class III studies in all summary tables that show the number of studies and their class and effect for each specialty.

## Data Synthesis

Results of the evidence report update are presented in full in the evidence tables (Appendix C ^2^). The investigator for each key question constructed separate evidence tables for each of the three study areas. In general, the evidence tables include author/date, key research question(s), study design/level, population, sample/selection, measures, results, quality rating, and limitations.

2 Appendices cited in this report are provided electronically at http://www.ahrq.gov/downloads/pub/evidence/pdf/telemedup/telemedup.pdf.

For the study areas with more than two studies, we constructed a summary table of specialties or domains and the strength of the evidence for each key question and type of telemedicine. The efficacy for telemedicine can therefore be gleaned from the number of studies that have a “positive” direction of effect, i.e., are rated A or B. For those procedures or services that have evidence, the summary tables show which analytic framework links are supported by evidence. We also interpret our synthesis and discuss the limitations of our approach to this evaluation.

## Peer Review Process

Thirteen peer reviewers were selected based on their expertise in the field of telemedicine and their availability to review the draft report. Refer to Appendix E ^3^ for the list of peer reviewers. The draft report was submitted to the peer reviewers along with a peer review form. The review form was developed by the research team and was based on one used in our original study and those used by other research teams at the Oregon Evidence-based Practice Center. The peer reviewers had three weeks to respond. The comments from the peer reviewers were received and distributed to the investigators for their consideration and response. A spreadsheet was prepared that contained the comments of the peer reviewers and our response to them. The peer review comments aided in creating this improved, comprehensive final document.

3 Appendices cited in this report are provided electronically at http://www.ahrq.gov/downloads/pub/evidence/pdf/telemedup/telemedup.pdf.