# Introduction

## Goal of the Report

The goal of this report is to present an overview of the scientific evidence on diagnosis and management decisions, clinical outcomes, and access to services through the use of three categories of telemedicine services: store-and-forward, home-based, and office/hospital-based. The report is intended to provide an update on the evidence for the efficacy of telemedicine services in the Medicare population. Consequently, the scope of this report is limited to telemedicine programs and clinical settings that have been used for, or are likely to be applied to, Medicare beneficiaries.

This report provides an update on the state of telemedicine, following the 2001 publication of Telemedicine for the Medicare Population (AHRQ Publication No. 01-E012).^1^ Our initial report found that while telemedicine was in widespread use, the evidence of efficacy for those uses was lacking. But even more problematic was the quality of evaluative studies. Many studies were performed using poor methodologies and small sample sizes. Indeed, our major conclusion was not that telemedicine was not efficacious, but rather that the quality of the studies evaluating it prevented one from making that determination at all. Another goal of the current report is to determine whether there has been progress in the number and quality of telemedicine studies that have been conducted since then.

We note that this report only presents a view of telemedicine from the standpoint of the peer-reviewed medical literature. This does not represent the sum of all experience with telemedicine. Indeed, telemedicine continues to be widely used. According to the 2004 TRC Report on Telemedicine Activity (Telemedicine Research Center and Telemedicine Information Exchange),^2^ 48,194 non-radiology teleconsultations took place in 2003 in 46 states. Mental health, cardiology, dermatology, orthopedics, and neurology represent some of the clinical specialties most actively utilizing telemedicine services. This report also identified a number of barriers to telemedicine services. The most significant of these barriers are the difficulty associated with integrating telemedicine services into health care delivery, lack of long-term funding, and lack of reimbursement for the provision of telemedicine services.^2^

Despite the peer-reviewed literature representing only a subset of all telemedicine experience, it is important to analyze telemedicine using an evidence-based approach, especially when the goal is to inform decisions about coverage. As such, this report undertakes a systematic if limited review of the efficacy for the telemedicine services and usages described above.

## Definitions

Telemedicine is the use of telecommunications technology for medical diagnostic, monitoring, and therapeutic purposes when distance and/or time separates the participants. Some descriptions use the broader term telehealth to indicate care beyond that provided in medical encounters (e.g., health education, health-related Web sites, etc.). Other descriptions use narrower terms focused on medical specialties, such as teledermatology or teleradiology. A telemedicine encounter is the event where clinical services are provided using telemedicine. The narrower term teleconsultation is used when a traditional specialist medical consultation is performed using telemedicine.

## Telemedicine Study Areas

This report examines telemedicine services in three areas: store-and-forward, home-based, and office/hospital-based services. Each of these three services are evaluated for their efficacy in three functions: diagnosis and management decisions, clinical outcomes, and access to care. Because the decision to use telemedicine is only predicated on it performing comparably to face-to-face care, studies are assessed from the standpoint of telemedicine to perform comparable to, but not necessarily better than, conventional care.

The terminology used in this update varies from the terminology used in the 2001 report. The term self-monitoring/testing has been replaced with home-based, and the term clinician-interactive has been replaced with office/hospital-based. The updated terms more accurately reflect the services that they describe and match the terminology used in subsequent publication of the findings of the 2001 evidence report in the peer-reviewed literature.^3, ^ ^4^

Store-and-forward telemedicine services collect medical data, store them, and then forward them to be interpreted later. Store-and-forward systems provide the ability to capture and store digital still or moving images of patients, as well as audio and text data. A store-and-forward system eliminates the need to have the patient and the specialist available at the same time. Store-and-forward is therefore an asynchronous, non-interactive form of telemedicine. It is usually employed as a clinical consultation (as opposed to an office or hospital visit).

Home-based telemedicine services enable physicians and others to monitor physiologic measurements, test results, images, and sounds, usually collected in a patient's residence or a nursing facility. Post-acute-care hospital patients, patients with chronic illnesses, and patients with conditions that limit their mobility often require close monitoring and follow-up. These patients also may be taking medications that require testing and/or titration of dosage.

Telemedicine systems use a variety of strategies to accomplish this monitoring. For example, several technologies allow patients to upload monitoring data directly to a health care system or to enter it into a home computer, whereby it can be transferred to a provider. Others make use of high-bandwidth phone or cable television infrastructure to apply two-way interactive video, audio, and medical diagnostic instrumentation. The close monitoring afforded by these approaches may allow better health care through early detection of problems or more precise dosing of medications and biologic agents, potentially reducing costs.

Some common forms of home-based telemedicine services are blood pressure measurement and blood glucose measurement performed by a diabetic patient and used by a clinician to evaluate the patient's glycemic control and to recommend changes in management. Other medical conditions for which home-based telemedicine services have been developed include asthma (in which spirometry is measured), congestive heart failure (weights, symptoms, blood pressure), cardiac arrhythmias (electrocardiography), anticoagulation therapy (prothrombin time), and post-acute hospital care. Monitoring may facilitate preventive measures to be taken before problems get so severe that hospitalization becomes necessary. Telemetry devices could also provide a more cost-effective method of care, by reducing medical visits for conditions that are not severe. Home-based telemedicine systems also may enhance patient-provider communication.

Office/hospital-based telemedicine services are real-time, clinician-patient interactions that conventionally would require face-to-face encounters between a patient and a health professional. Examples of office/hospital-based services that might be delivered by telemedicine include office visits, hospital visits, consultations, and home visits, as well as a variety of specialized examinations and procedures.

Telemedicine is commonly used to make diagnosis or management decisions, often by a specialist located remotely from the patient. Because many diagnostic decisions in medicine are not made definitively, it is often adequate to demonstrate that telemedicine results in concordant as opposed to accurate decisions. This is particularly true in specialties like dermatology, where diagnoses are made by visualizing skin lesions and not confirmed with definitive testing before treatment is begun. Making accurate decisions usually requires more definitive testing, such as biopsies, which are not routinely done for many conditions, especially those that are not life-threatening.

For this reason, we distinguish in this report between concordance and accuracy in making diagnoses. We note other dimensions of concordance, such as the measure used (usually either percent agreement or Cohen's kappa measure for categorical data and correlation for continuous data), comparison to the same diagnostician (intraobserver) versus a different one (interobserver), and whether concordance of telemedicine versus face-to-face diagnosis is compared to face-to-face versus face-to-face diagnosis. Studies of the highest quality must include the latter as a reference to the comparison of telemedicine. In our original report, few studies made this important comparison. Accuracy is usually measured by comparison with some gold standard using sensitivity and specificity.

The clinical outcomes assessed in this study are limited to measures of clinical care, such as health status, improvement in clinical parameters (e.g., blood glucose or blood pressure), and recovery from disease. We do not focus on utilization or economic outcomes.

This review has a number of limitations of scope. Our gathering of evidence is limited to the peer-reviewed literature. Only studies assessing populations relevant to Medicare (non-pregnant adults) are assessed. Studies focusing on non-clinical care (teleradiology and telepathology) are excluded, as are those focusing on economics as well as patient or provider satisfaction. We also do not look explicitly at telemedicine from the context of changes in the health care system or implementation of wider information technologies unless such aspects were specifically assessed in peer-reviewed studies.

## Other Telemedicine Research Summaries

Several other reports have analyzed the quality of telemedicine studies, some of which are systematic reviews. These include:

Bashshur R, Shannon G, Sapci H. Telemedicine evaluation. 2004. In: Proceedings of the Second International Symposium on the Future Directions for Telemedicine; 2004 May 22–24; Ann Arbor, MI.

Brantley D, Laney-Cummings K, and Spivack R. Innovation, Demand and Investment in Telehealth. 2004, Department of Commerce: Washington, DC. http://www.technology.gov/reports/TechPolicy/Telehealth/2004Report.pdf.

Currell R, et al., Telemedicine versus face-to-face patient care: effects on professional practice and health care outcomes, in The Cochrane Database of Systematic Reviews. 2000, Update Software: Oxford, UK. CD002098.

Grigsby J, Brega A, DeVore P. Health services research and evidence of telemedicine. In: Proceedings of the Second International Symposium on the Future Directions for Telemedicine; 2004 May 22–24; Ann Arbor, MI.

Hailey D, Ohinmaa A, Roine R. Study quality and evidence of benefit in recent assessments of telemedicine. J Telemed Telecare 2004 10(6):318–24.

Heinzelmann P et al. A review of clinical outcomes in telemedicine/telehealth. In: Proceedings of the Second International Symposium on the Future Directions for Telemedicine; 2004 May 22–24; Ann Arbor, MI.

Hersh W, Wallace J, Patterson P, et al. Telemedicine for the Medicare Population. Evidence Report/Technology Assessment No. 24. Rockville, MD: U.S. Department of Health and Human Services, Agency for Health Care Quality and Research. 2001 Jul. AHRQ Publication No. 01-E102.

Jennett P, Scott R, Hailey D, et al. Socio-Economic Impact of Telehealth: Evidence Now for Health Care in the Future: Volume One: State of the Science Report. 2003, Health Telematics Unit, University of Calgary: Calgary, AB.