# Appendix E: Peer Reviewers

Individuals

Reviewer | Affiliation
Jeanette C. Hartshorn, PhD, RN, FAAN | UTMB Telehealth Center
| University of Texas
| Galveston, TX
Michael A. Hillman, MD, MBA | Marshfield Clinic
| Marshfield, WI
Penny Jennett, PhD | Health Telematics Unit
| University of Calgary
| Calgary AB
Bonnie J. Wakefield, PhD, RN | Center for Research in the Implementation of Innovative Strategies in Practice (CRISP)
| VA Medical Center
| Iowa City, IA

Organizations

Organization/Agency | Reviewer | Affiliation
American Academy of Dermatology | Hon Pak, MD | Department of Dermatology
| | Brooke Army Medical Center
| | Fort Sam Houston, TX
American Telemedicine Association | Nina Antoniotti, PhD, MBA, RN | Marshfield Clinic Telehealth Network
| | Marshfield, WI
Association of Telehealth Service Providers | Josie Henderson | Telemedicine Research Center
| | Portland, OR
National Association for Home Care & Hospice | Theresa Forster | Vice President for Research NAHC

Federal Agencies

Agency for Healthcare Research and Quality | J. Michael Fitzmaurice, Ph.D., FACMI | Senior Science Advisor for Information Technology
| | 540 Gaither Road, Suite 3026
| | Rockville, Maryland
Agency for Healthcare Research and Quality | Martin Erlichman, MS | Task Order Officer
| | 540 Gaither Road
| | Rockville, MD
Centers for Medicare & Medicaid Services | Shamiram R. Feinglass, MD, MPH | Medical Officer
| | Medicare Coverage & Analysis Group
| | 7500 Security Boulevard
| | Mailstop C1-09-06
| | Baltimore, MD
Indian Health Service | Mark Carroll, MD | Flagstaff, AZ
U.S. Department of Health and Human Services | Dena Puskin, ScD | Office for the Advancement of Telehealth
| | Rockville, MD