# Appendix D: Listing of Excluded Studies

## References

Aarnio P, Jaatinen P, Hakkari K, et al. A new method for surgical consultations with videoconference. Annales Chirurgiae et Gynaecologiae. 2000;89(4):336-40. Excluded - contains no or inadequate data. [pmid: 11204968].
Aarnio P, Rudenberg H, Ellonen M, et al. User satisfaction with teleconsultations for surgery. J Telemed Telecare. 2000;6(4):237-41. Excluded - does not meet our definition of telemedicine. [pmid: 11027127].
Aas IH. A qualitative study of the organizational consequences of telemedicine. J Telemed Telecare. 2001;7(1):18-26. Excluded - contains no or inadequate data. [pmid: 11265934].
Abbott KC, Mann S, DeWitt D, et al. Physician-to-physician consultation via electronic mail: the Walter Reed Army Medical Center Ask a Doc system. Mil Med. Mar. 2002;167(3):200-4. Excluded - does not meet our definition of telemedicine. [pmid: 11901566].
Abdoh AA, Krousel-Wood MA, Re RN. Accuracy of telemedicine in detecting uncontrolled hypertension and its impact on patient management. Telemed J E Health. Winter. 2003;9(4):315-23. Excluded - does not address a key question. [pmid: 14980088].
Abrahamian H, Schueller A, Mauler H, et al. Transfer of knowledge from the specialist to the generalist by videoconferencing: effect on diabetes care. J Telemed Telecare. 2002;8(6):350-5. Excluded - contains no or inadequate data. [pmid: 12537923].
Agha Z, Schapira RM, Maker AH. Cost effectiveness of telemedicine for the delivery of outpatient pulmonary care to a rural population. Telemed J E Health. Fall. 2002;8(3):281-91. Excluded - does not address a key question. [pmid: 12419022].
Albisser AM. Clinical studies with home glucose clamping. Ann Endocrinol (Paris). Feb. 2001;62(1 Pt 1):11-8. Excluded - no comparison group. [pmid: 11240403].
Alessi NE. Quantitative documentation of the therapeutic efficacy of adolescent telepsychiatry. Telemed J E Health. Fall. 2003;9(3):283-9. Excluded - contains no or inadequate data. [pmid: 14611696].
Amir O, Shabtai E. Public information services in the field of communication disorders: comparison between teleservice and E-service. Telemed J E Health. Winter. 2002;8(4):369-75. Excluded - does not address a key question. [pmid: 12626106].
Andersson G, Lundstrom P, Strom L. Internet-based treatment of headache: does telephone contact add anything?. Headache. Apr. 2003;43(4):353-61. Excluded - does not meet our definition of telemedicine. [pmid: 12656706].
Andrews D, Gouda MS, Higgins S, et al. A comparative study of a new wireless continuous cardiorespiratory monitor for the diagnosis and management of patients with congestive heart failure at home.[erratum appears in J Telemed Telecare. 2002;8(6):361.]. J Telemed Telecare. 2002;8(Suppl 2):101-3. Excluded - contains no or inadequate data. [pmid: 12217157].
Anonymous. Summaries for patients. Home monitoring service improves blood pressure control in patients with high blood pressure. Ann Intern Med 2001 Jun 5; 134(11):S-9. Excluded - does not address a key question
Anonymous. Sacramento hospital boosts outcomes by focusing on high-risk CHF patients. Data Strategies & Benchmarks. 2001 May; 5(5):68–7, 65. Excluded - contains no or inadequate data
Anonymous. CHF managers make the case for home-monitoring technology. Dis Manag Advis 2002 Oct; 8(10):156–8, 145. Excluded - does not address a key question
Anonymous. Demo produces stunning results in care of complex patients. Clinical Resource Management 2002 Feb; 3(2):21–5. Excluded - contains no or inadequate data
Anonymous. Study suggests video visits have significant cost, quality benefits. Dis Manag Advis 2002 Mar; 8(3):44–7, 33. Excluded - contains no or inadequate data
Anonymous. Online doctor-patient communication tool saves time on phone. Perform Improv Advis 2003 Mar; 7(3):37–9. Excluded - does not address a key question
Appel PR, Bleiberg J, Noiseux J. Self-regulation training for chronic pain: can it be done effectively by telemedicine?. Telemed J E Health. Winter. 2002;8(4):361-8. Excluded - contains no or inadequate data. [pmid: 12626105].
Aris IB, Wagie AA, Mariun NB, et al. An internet-based blood pressure monitoring system for patients. J Telemed Telecare. 2001;7(1):51-3. Excluded - no comparison group. [pmid: 11265939].
Arthur HM, Smith KM, Kodis J, et al. A controlled trial of hospital versus home-based exercise in cardiac patients. Med Sci Sports Exerc. Oct. 2002;34(10):1544-50. Excluded - does not address a key question. [pmid: 12370553].
Aucar J, Granchi T, Liscum K, et al. Is regionalization of trauma care using telemedicine feasible and desirable?. American Journal of Surgery. 2000;180(6):535-9. Excluded - does not address a key question. [pmid: 11182413].
Axford AT, Askill C, Jones AJ. Virtual multidisciplinary teams for cancer care. J Telemed Telecare. 2002;8(Suppl 2):3-4. Excluded - does not meet our definition of telemedicine. [pmid: 12217113].
Ayyagari A, Bhargava A, Agarwal R, et al. Use of telemedicine in evading cholera outbreak in Mahakumbh Mela, Prayag, UP, India: an encouraging experience. Telemed J E Health. Spring. 2003;9(1):89-94. Excluded - does not address a key question. [pmid: 12699612].
Bakke B, Mitchell J, Wonderlich S, et al. Administering cognitive-behavioral therapy for bulimia nervosa via telemedicine in rural settings. Int J Eat Disord. Dec. 2001;30(4):454-7. Excluded - no comparison group. [pmid: 11746307].
Baldwin L, Clarke M, Hands L, et al. The effect of telemedicine on consultation time. J Telemed Telecare. 2003;9(Suppl 1):S71-3. Excluded - does not address a key question. [pmid: 12952731].
Ballantyne GH, Hourmont K, Wasielewski A. Telerobotic laparoscopic repair of incisional ventral hernias using intraperitoneal prosthetic mesh. J Soc Laparoendosc Surg. Jan–Mar. 2003;7(1):7-14. Excluded - does not address a key question.
Banerjee S, Steenkeste F, Couturier P, et al. Telesurveillance of elderly patients by use of passive infra-red sensors in a ‘smart’ room. J Telemed Telecare. 2003;9(1):23-9. Excluded - does not meet our definition of telemedicine. [pmid: 12641889].
Barry CJ, Henderson C, Kanagasingam Y, et al. Working toward a portable tele-ophthalmic system for use in maximum-security prisons: a pilot study. Telemed J E Health. Fall. 2001;7(3):261-5. Excluded - wrong population. [pmid: 11564362].
Baruffaldi F, Gualdrini G, Toni A. Comparison of asynchronous and realtime teleconsulting for orthopaedic second opinions. J Telemed Telecare. 2002;8(5):297-301. Excluded - contains no or inadequate data. [pmid: 12396859].
Beach M, Goodall I and Miller P. Evaluating telemedicine for minor injuries units. J Telemed Telecare 2000 6(1) Excluded - no comparison group
Bellazzi R, Larizza C, Montani S, et al. A telemedicine support for diabetes management: the T-IDDM project. Comput Methods Programs Biomed. Aug. 2002;69(2):147-61. Excluded - does not address a key question. [pmid: 12100794].
Bellon E, Aerts W, Vanautgaerden M, et al. Web-access to a central medical record to improve cooperation between hospital and referring physicians. Studies in Health Technology & Informatics. 2002;93:145-53. Excluded - does not address a key question. [pmid: 15058426].
Belmont JM, Mattioli LF. Accuracy of analog telephonic stethoscopy for pediatric telecardiology. Pediatrics. Oct. 2003;112(4):780-6. Excluded - wrong population. [pmid: 14523166].
Benger J, Lock A, Cook J, et al. The effect of resolution, compression, colour depth and display modality on the accuracy of accident and emergency telemedicine. J Telemed Telecare. 2001;7(Suppl 1):6-7. Excluded - does not address a key question. [pmid: 11576472].
Bennett SJ, Hays LM, Embree JL, et al. Heart Messages: a tailored message intervention for improving heart failure outcomes. Journal of Cardiovascular Nursing. 2000;14(4):94-105. Excluded - does not meet our definition of telemedicine. [pmid: 10902106].
Berendt M, Schaefer B, Heglund MJ, et al. Telehealth for effective disease state management. Home Care Provid. Apr. 2001;6(2):67-72. Excluded - does not address a key question. [pmid: 11295686].
Berg BW, Vincent DS, Hudson DA. Remote critical care consultation: telehealth projection of clinical specialty expertise. J Telemed Telecare. 2003;9(Suppl 2):S9-11. Excluded - no comparison group. [pmid: 14728748].
Bielli E, Carminati F, La Capra S, et al. A Wireless Health Outcomes Monitoring System (WHOMS): development and field testing with cancer patients using mobile phones. BMC Med Inf Decis Mak. Jun 15. 2004;4(1):7. Excluded - does not meet our definition of telemedicine.
Billingsley KG, Schwartz DL, Lentz S, et al. The development of a telemedical cancer center within the Veterans Affairs Health Care System: a report of preliminary clinical results. Telemed J E Health. Spring. 2002;8(1):123-30. Excluded - contains no or inadequate data. [pmid: 12020412].
Bishai DM, Ferris DG, Litaker MS. What is the least costly strategy to evaluate cervical abnormalities in rural women? Comparing telemedicine, local practitioners, and expert physicians. Med Decis Making. Nov–Dec. 2003;23(6):463-70. Excluded - does not address a key question. [pmid: 14672106].
Bishop JE, O'Reilly RL, Maddox K, et al. Client satisfaction in a feasibility study comparing face-to-face interviews with telepsychiatry. J Telemed Telecare. 2002;8(4):217-21. Excluded - does not address a key question. [pmid: 12217104].
Blomdahl S, Calissendorff B, Jacobsson U. Patient-focused urban tele-ophthalmology services. J Telemed Telecare. 2002;8(Suppl 2):43-4. Excluded - contains no or inadequate data. [pmid: 12217130].
Blomdahl S, Maren N, Lof R. Tele-ophthalmology for the treatment in primary care of disorders in the anterior part of the eye. J Telemed Telecare. 2001;7(Suppl 1):25-6. Excluded - contains no or inadequate data. [pmid: 11576480].
Bose U, McLaren P, Riley A, et al. The use of telepsychiatry in the brief counselling of non-psychotic patients from an inner-London general practice. J Telemed Telecare. 2001;7(Suppl 1):8-10. Excluded - contains no or inadequate data. [pmid: 11576473].
Boukhors Y, Rabasa-Lhoret R, Langelier H, et al. The use of information technology for the management of intensive insulin therapy in type 1 diabetes mellitus. Diabetes Metab. Dec. 2003;29(6):619-27. Excluded - does not meet our definition of telemedicine. [pmid: 14707892].
Boulanger B, Kearney P, Ochoa J, et al. Telemedicine: a solution to the followup of rural trauma patients?. J Am Coll Surg. Apr. 2001;192(4):447-52. Excluded - does not address a key question. [pmid: 11294400].
Bove P, Stoianovici D, Micali S, et al. Is telesurgery a new reality? Our experience with laparoscopic and percutaneous procedures. J Endourol. Apr. 2003;17(3):137-42. Excluded - does not address a key question. [pmid: 12803985].
Bowater M. The experience of a rural general practitioner using videoconferencing for telemedicine. J Telemed Telecare. 2001;7(Suppl 2):24-5. Excluded - contains no or inadequate data. [pmid: 11747650].
Bracale M, Cesarelli M, Bifulco P. Telemedicine services for two islands in the Bay of Naples. J Telemed Telecare. 2002;8(1):5-10. Excluded - does not address a key question. [pmid: 11809078].
Braun RP, Meier M, Pelloni F, et al. Teledermatoscopy in Switzerland: a preliminary evaluation. Journal of the American Academy of Dermatology. 2000;42(5 Pt 1):770-5. Excluded - included in previous report. [pmid: 10775852].
Brebner EM, Brebner JA. Implementation and evaluation of telemedicine for remote health-care the European Northern Periphery Programme Project. J Telemed Telecare. 2001;7(Suppl 1):68-9. Excluded - does not address a key question. [pmid: 11576498].
Brebner EM, Brebner JA, Ruddick-Bracken H, et al. Evaluation of a pilot telemedicine network for accident and emergency work. J Telemed Telecare. 2002;8(Suppl 2):5-6. Excluded - contains no or inadequate data. [pmid: 12217114].
Brebner EM, Brebner JA, Ruddick-Bracken H, et al. Evaluation of an accident and emergency teleconsultation service for north-east Scotland. J Telemed Telecare. 2004;10(1):16-20. Excluded - contains no or inadequate data. [pmid: 15006210].
Brebner JA, Brebner EM, Ruddick-Bracken H, et al. The development of a pilot telemedicine network in Scotland: lessons learned. J Telemed Telecare. 2001;7(Suppl 2):83-4. Excluded - contains no or inadequate data. [pmid: 11747670].
Bremner F, Kennedy C, Rees A, et al. Usefulness of teleconsultations in neuro-ophthalmology. J Telemed Telecare. 2002;8(5):305-6. Excluded - contains no or inadequate data. [pmid: 12396861].
Brennan DM, Georgeadis AC, Baron CR, et al. The effect of videoconference-based telerehabilitation on story retelling performance by brain-injured subjects and its implications for remote speech-language therapy. Telemed J E Health. Summer. 2004;10(2):147-54. Excluded - contains no or inadequate data. [pmid: 15319044].
Brennan PF, Moore SM, Bjornsdottir G, et al. HeartCare: an Internet-based information and support system for patient home recovery after coronary artery bypass graft (CABG) surgery.[see comment]. J Adv Nurs. Sep. 2001;35(5):699-708. Excluded - contains no or inadequate data. [pmid: 11529972].
Brenner B. Is the provision of laboratory results via the Internet acceptable to patients? A survey of private patients in a large, specialist gynaecology practice. N Z Med J. Dec 12. 2003;116(1187):U711. Excluded - does not address a key question. [pmid: 14752539].
Brian J, Jamieson S. Post-surgical cardiac patients receive new level of care. Caring. Mar. 2002;21(3):28-9. Excluded - does not address a key question. [pmid: 11912896].
Broderick TJ, Harnett BM, Doarn CR, et al. Real-time Internet connections: implications for surgical decision making in laparoscopy. Ann Surg. Aug. 2001;234(2):165-71. Excluded - does not address a key question. [pmid: 11505061]. [pmcid: 1422002].
Brodey BB, Claypoole KH, Motto J, et al. Satisfaction of forensic psychiatric patients with remote telepsychiatric evaluation. Psychiatr Serv. 1305;51(10):1305-7. Excluded - wrong population. [pmid: 11013332].
Brown-Connolly NE. Patient satisfaction with telemedical access to specialty services in rural California. J Telemed Telecare. 2002;8(Suppl 2):7-10. Excluded - does not address a key question. [pmid: 12217115].
Brownrigg P, Lowry JC, Edmondson MJ, et al. Telemedicine in oral surgery and maxillofacial trauma: a descriptive account. Telemed J E Health. Spring. 2004;10(1):27-31. Excluded - contains no or inadequate data. [pmid: 15104912].
Burgess LP, Syms MJ, Holtel MR, et al. Telemedicine: teleproctored endoscopic sinus surgery. Laryngoscope. Feb. 2002;112(2):216-9. Excluded - contains no or inadequate data. [pmid: 11889372].
Bursell SE, Cavallerano JD, Cavallerano AA, et al. Stereo nonmydriatic digital-video color retinal imaging compared with Early Treatment Diabetic Retinopathy Study seven standard field 35-mm stereo color photos for determining level of diabetic retinopathy. Ophthalmology. Mar. 2001;108(3):572-85. Excluded - does not meet our definition of telemedicine. [pmid: 11237913].
Buurke JH, Kleissen RF, Nene A, et al. A feasibility study of remote consultation to determine suitability for surgery in stroke rehabilitation. J Telemed Telecare. 2004;10(2):108-12. Excluded - contains no or inadequate data. [pmid: 15068648].
Bynum A, Hopkins D, Thomas A, et al. The effect of telepharmacy counseling on metered-dose inhaler technique among adolescents with asthma in rural Arkansas. Telemed J E Health. Fall. 2001;7(3):207-17. Excluded - wrong population. [pmid: 11564356].
Bynum AB, Cranford CO, Irwin CA, et al. Participant satisfaction with a school telehealth education program using interactive compressed video delivery methods in rural Arkansas. J Sch Health. Aug. 2002;72(6):235-42. Excluded - wrong population. [pmid: 12212408].
Bynum AB, Irwin CA, Cranford CO, et al. The impact of telemedicine on patients' cost savings: some preliminary findings. Telemed J E Health. Winter. 2003;9(4):361-7. Excluded - does not address a key question. [pmid: 14980093].
Byrne JP, Mughal MM. Telementoring as an adjunct to training and competence-based assessment in laparoscopic cholecystectomy. Surgical Endoscopy. 1159;14(12):1159-61. Excluded - does not address a key question. [pmid: 11148789].
Cabrera MF, Arredondo MT, Quiroga J. Integration of telemedicine into emergency medical services. J Telemed Telecare. 2002;8(Suppl 2):12-4. Excluded - contains no or inadequate data. [pmid: 12217117].
Cadiere GB, Himpens J, Vertruyen M, et al. Evaluation of telesurgical (robotic) NISSEN fundoplication. Surgical Endoscopy. Sep. 2001;15(9):918-23. Excluded - does not address a key question. [pmid: 11605106].
Car J, Sheikh A. Email consultations in health care: 1--scope and effectiveness. Bmj. Aug 21. 2004;329(7463):435-8. Excluded - does not address a key question. [pmid: 15321902]. [pmcid: 514208].
Car J, Sheikh A. Email consultations in health care: 2--acceptability and safe application. Bmj. Aug 21. 2004;329(7463):439-42. Excluded - does not address a key question. [pmid: 15321903]. [pmcid: 514210].
Cargill A, Watson AR. Telecare support for patients undergoing chronic peritoneal dialysis. Perit Dial Int. Jan–Feb. 2003;23(1):91-4. Excluded - does not address a key question. [pmid: 12691517].
Cathala N, Brillat F, Mombet A, et al. Patient followup after radical prostatectomy by Internet medical file. J Urol. Dec. 2003;170(6 Pt 1):2284-7. Excluded - does not address a key question. [pmid: 14634397].
Cavallerano AA, Cavallerano JD, Katalinic P, et al. Use of Joslin Vision Network digital-video nonmydriatic retinal imaging to assess diabetic retinopathy in a clinical program. Retina. Apr. 2003;23(2):215-23. Excluded - no comparison group. [pmid: 12707602].
Cavan DA, Everett J, Plougmann S, et al. Use of the Internet to optimize self-management of type 1 diabetes: preliminary experience with DiasNet. J Telemed Telecare. 2003;9(Suppl 1):S50-2. Excluded - contains no or inadequate data. [pmid: 12952722].
Cavina E, Goletti O, Lippolis PV, et al. Telesonography: technical problems, solutions and results in the routine utilization from remote areas. Studies in Health Technology & Informatics. 2001;81:88-9. Excluded - does not address a key question. [pmid: 11317825].
Cawthorpe D. An evaluation of a computer-based psychiatric assessment: evidence for expanded use. Cyberpsychol Behav. Aug. 2001;4(4):503-10. Excluded - contains no or inadequate data. [pmid: 11708730].
Cervi PL, Everitt AS. Automatic voice mail for delivering computer-generated anticoagulant dose advice to patients. J Telemed Telecare. 2002;8(5):259-63. Excluded - does not address a key question. [pmid: 12396853].
Chae YM, Heon Lee J, Hee Ho S, et al. Patient satisfaction with telemedicine in home health services for the elderly. Int J Med Inf. May. 2001;61(23):167-73. Excluded - does not address a key question.
Chae YM, Park HJ, Cho JG, et al. The reliability and acceptability of telemedicine for patients with schizophrenia in Korea. J Telemed Telecare. 2000;6(2):83-90. Excluded - does not address a key question. [pmid: 10824375].
Chambers M, Connor S. Technology as an aid to coping with caring: a usability evaluation of a telematics intervention. Medinfo. 2001;10(Pt 2):1130-4. Excluded - does not meet our definition of telemedicine. [pmid: 11604905].
Chambers M, Connor SL. User-friendly technology to help family carers cope. J Adv Nurs. Dec. 2002;40(5):568-77. Excluded - does not meet our definition of telemedicine. [pmid: 12437606].
Chambers MG, Connor SL, McGonigle M, et al. Multimedia software to help caregivers cope. J Am Med Inform Assoc. Sep–Oct. 2003;10(5):504-11. Excluded - does not meet our definition of telemedicine. [pmid: 12807815]. [pmcid: 212788].
Chan DS, Callahan CW, Sheets SJ, et al. An Internet-based store-and-forward video home telehealth system for improving asthma outcomes in children. Am J Health Syst Pharm. Oct 1. 2003;60(19):1976-81. Excluded - wrong population. [pmid: 14531243].
Chan WM, Woo J, Hui E, et al. The role of telenursing in the provision of geriatric outreach services to residential homes in Hong Kong. J Telemed Telecare. 2001;7(1):38-46. Excluded - contains no or inadequate data. [pmid: 11265937].
Chao LW, Cestari TF, Bakos L, et al. Evaluation of an Internet-based teledermatology system. J Telemed Telecare. 2003;9(Suppl 1):S9-12. Excluded - contains no or inadequate data. [pmid: 12952705].
Chao LW, Enokihara MY, Silveira PS, et al. Telemedicine model for training non-medical persons in the early recognition of melanoma. J Telemed Telecare. 2003;9(Suppl 1):S4-7. Excluded - contains no or inadequate data. [pmid: 12952703].
Chase HP, Pearson JA, Wightman C, et al. Modem transmission of glucose values reduces the costs and need for clinic visits.[see comment]. Diabetes Care. May. 2003;26(5):1475-9. Excluded - wrong population. [pmid: 12716807].
Chen K, Lim A, Shumack S. Teledermatology: influence of zoning and education on a clinician's ability to observe peripheral lesions. Australas J Dermatol. Aug. 2002;43(3):171-4. Excluded - contains no or inadequate data. [pmid: 12121392].
Chen RS, Chen SK. Teledentistry using videoconferencing and a DICOM image management system. J Telemed Telecare. 2002;8(4):244-6. Excluded - contains no or inadequate data. [pmid: 12217110].
Cherry JC, Dryden K, Kobb R, et al. Opening a window of opportunity through technology and coordination: a multisite case study. Telemed J E Health. Fall. 2003;9(3):265-71. Excluded - contains no or inadequate data. [pmid: 14611694].
Cherry JC, Moffatt TP, Rodriguez C, et al. Diabetes disease management program for an indigent population empowered by telemedicine technology. Diabetes Technol Ther. 2002;4(6):783-91. Excluded - does not address a key question. [pmid: 12685802].
Chetney R. The Cardiac Connection program: home care that doesn't miss a beat. Home Healthc Nurse. Oct. 2003;21(10):680-6. Excluded - does not address a key question. [pmid: 14557707].
Cheung JC, Dick PT, Kraft SP, et al. Strabismus examination by telemedicine. Ophthalmology. 1999;107(11):1999-2005. Excluded - wrong population. [pmid: 11054321].
Choremis J, Chow DR. Use of telemedicine in screening for diabetic retinopathy.[see comment]. Can J Ophthalmol. Dec. 2003;38(7):575-9. Excluded - no comparison group. [pmid: 14740799].
Chua R, Craig J, Wootton R, et al. Cost implications of outpatient teleneurology. J Telemed Telecare. 2001;7(Suppl 1):62-4. Excluded - does not address a key question. [pmid: 11576496].
Cipolat C, Bader U, Rufli T, et al. Teledermatology in Switzerland. Aktuelle Probl Dermatol. 2003;32:257-60. Excluded - contains no or inadequate data.
Clement PF, Brooks FR, Dean B, et al. A neuropsychology telemedicine clinic. Mil Med. May. 2001;166(5):382-4. Excluded - contains no or inadequate data. [pmid: 11370198].
Clifton GD, Byer H, Heaton K, et al. Provision of pharmacy services to underserved populations via remote dispensing and two-way videoconferencing. Am J Health Syst Pharm. Dec 15. 2003;60(24):2577-82. Excluded - does not address a key question. [pmid: 14750497].
Collins K, Bowns I, Walters S. General practitioners' perceptions of asynchronous telemedicine in a randomized controlled trial of teledermatology. J Telemed Telecare. 2004;10(2):94-8. Excluded - contains no or inadequate data. [pmid: 15068645].
Collins K, Walters S, Bowns I. Patient satisfaction with teledermatology: quantitative and qualitative results from a randomized controlled trial. J Telemed Telecare. 2004;10(1):29-33. Excluded - does not address a key question. [pmid: 15006213].
Collins PW, Bolton-Maggs P, Stephenson D, et al. Pilot study of an Internet-based electronic patient treatment record and communication system for haemophilia, Advoy.com. Haemophilia. May. 2003;9(3):285-91. Excluded - does not address a key question. [pmid: 12694519].
Cone SW, Gehr L, Hummel R, et al. Case report of remote anesthetic monitoring using telemedicine. Anesth Analg 2004 Feb; 98(2):386–8, table of contents. Excluded - contains no or inadequate data
Constable IJ, Yogesan K, Eikelboom R, et al. Fred Hollows lecture: digital screening for eye disease. Clinical & Experimental Ophthalmology. 2000;28(3):129-32. Excluded - does not address a key question. [pmid: 10981779].
Cook DJ, Doolittle GC, Whitten PS. Administrator and provider perceptions of the factors relating to programme effectiveness in implementing telemedicine to provide end-of-life care. J Telemed Telecare. 2001;7(Suppl 2):17-9. Excluded - does not address a key question. [pmid: 11747648].
Cook HL, Heacock GL, Stanford MR, et al. Detection of retinal lesions after telemedicine transmission of digital images. Eye. 2000;14(Pt 4):563-71. Excluded - does not meet our definition of telemedicine. [pmid: 11040901].
Cook J, Edwards J, Mullings C, et al. Dentists' opinions of an online orthodontic advice service. J Telemed Telecare. 2001;7(6):334-7. Excluded - does not address a key question. [pmid: 11747634].
Cook J, Mullings C, Vowles R, et al. Online orthodontic advice: a protocol for a pilot teledentistry system. J Telemed Telecare. 2001;7(6):324-33. Excluded - contains no or inadequate data. [pmid: 11747633].
Corcoran H, Hui E, Woo J. The acceptability of telemedicine for podiatric intervention in a residential home for the elderly. J Telemed Telecare. 2003;9(3):146-9. Excluded - contains no or inadequate data. [pmid: 12877776].
Cornish PA, Church E, Callanan T, et al. Rural interdisciplinary mental health team building via satellite: a demonstration project. Telemed J E Health. Spring. 2003;9(1):63-71. Excluded - does not address a key question. [pmid: 12699609].
Corr P, Couper I, Beningfield SJ, et al. A simple telemedicine system using a digital camera. J Telemed Telecare. 2000;6(4):233-6. Excluded - does not meet our definition of telemedicine. [pmid: 11027126].
Cowain T. Cognitive-behavioural therapy via videoconferencing to a rural area. Aust N Z J Psychiatry. Feb. 2001;35(1):62-4. Excluded - no comparison group. [pmid: 11270458].
Coyle N, Khojainova N, Francavilla JM, et al. Audio-visual communication and its use in palliative care. J Pain Symptom Manage. Feb. 2002;23(2):171-5. Excluded - contains no or inadequate data. [pmid: 11844640].
Craig J, Chua R, Russell C, et al. A cohort study of early neurological consultation by telemedicine on the care of neurological inpatients. J Neurol Neurosurg Psychiatry. Jul. 2004;75(7):1031-5. Excluded - contains no or inadequate data. [pmid: 15201365]. [pmcid: 1739134].
Cummings DM, Morrissey S, Barondes MJ, et al. Screening for diabetic retinopathy in rural areas: the potential of telemedicine. J Rural Health. Winter. 2001;17(1):25-31. Excluded - no comparison group. [pmid: 11354719].
Dadd M, Doyle B, Wilson L, et al. Lessons learned from the Hospital Without Walls project. J Telemed Telecare 2002 8(Suppl 3):S3:11–4. Excluded - does not address a key question
Dale J, Connor S, Tolley K. An evaluation of the west Surrey telemedicine monitoring project. J Telemed Telecare. 2003;9(Suppl 1):S39-41. Excluded - contains no or inadequate data. [pmid: 12952718].
d'Annunzio G, Bellazzi R, Larizza C, et al. Telemedicine in the management of young patients with type 1 diabetes mellitus: a follow-up study. Acta Biomed Ateneo Parmense. 2003;74(Suppl 1):49-55. Excluded - contains no or inadequate data.
Dansky KH, Bowles KH. Lessons learned from a telehomecare project. Caring. Apr. 2002;21(4):18-22. Excluded - contains no or inadequate data. [pmid: 11957852].
Dansky KH, Palmer L, Shea D, et al. Cost analysis of telehomecare. Telemed J E Health. Fall. 2001;7(3):225-32. Excluded - does not address a key question. [pmid: 11564358].
Dansky KH, Yant B, Jenkins D, et al. Qualitative analysis of telehomecare nursing activities. Journal of Nursing Administration. Jul–Aug. 2003;33(78):372-5. Excluded - contains no or inadequate data. [pmid: 12909786].
Davis P. The application of telehealth to rheumatology. Clin Rheumatol. Sep. 2003;22(3):168-72. Excluded - contains no or inadequate data. [pmid: 14505205].
Davis P, Howard R, Brockway P. Telehealth consultations in rheumatology: cost-effectiveness and user satisfaction. J Telemed Telecare. 2001;7(Suppl 1):10-1. Excluded - does not address a key question. [pmid: 11576474].
Davis P, Howard R, Brockway P. An evaluation of telehealth in the provision of rheumatologic consults to a remote area.[see comment]. J Rheumatol. Aug. 2001;28(8):1910-3. Excluded - does not address a key question. [pmid: 11508599].
Davis RM, Fowler S, Bellis K, et al. Telemedicine improves eye examination rates in individuals with diabetes: a model for eye-care delivery in underserved communities. Diabetes Care. Aug. 2003;26(8):2476. Excluded - does not address a key question. [pmid: 12882889].
De Las Cuevas C, Artiles J, De La Fuente J, et al. Telepsychiatry in the Canary Islands: user acceptance and satisfaction. J Telemed Telecare. 2003;9(4):221-4. Excluded - does not address a key question. [pmid: 12952693].
de Lusignan S, Althans A, Wells S, et al. A pilot study of radiotelemetry for continuous cardiopulmonary monitoring of patients at home. J Telemed Telecare 2000 6(1) Excluded - contains no or inadequate data
Deb N, Thuret G, Estour B, et al. Screening for diabetic retinopathy in France. Diabetes Metab. Apr. 2004;30(2):140-5. Excluded - contains no or inadequate data. [pmid: 15223985].
Debray M, Couturier P, Greuillet F, et al. A preliminary study of the feasibility of wound telecare for the elderly. J Telemed Telecare. 2001;7(6):353-8. Excluded - contains no or inadequate data. [pmid: 11747638].
Deitsch SE, Frueh BC, Santos AB. Telepsychiatry for post-traumatic stress disorder. J Telemed Telecare. 2000;6(3):184-6. Excluded - contains no or inadequate data. [pmid: 10912339].
DeLeo G, Krishna S, Balas EA, et al. WEB-WAP based telecare. Proc AMIA Symp 2002:200–4. Excluded - contains no or inadequate data
Delgado DH, Costigan J, Wu R, et al. An interactive Internet site for the management of patients with congestive heart failure. Can J Cardiol. Nov. 2003;19(12):1381-5. Excluded - contains no or inadequate data. [pmid: 14631472].
DeMaio J, Schwartz L, Cooley P, et al. The application of telemedicine technology to a directly observed therapy program for tuberculosis: a pilot project. Clin Infect Dis. Dec 15. 2001;33(12):2082-4. Excluded - contains no or inadequate data. [pmid: 11698993].
Demartines N. Telemedicine applications in surgery. Aktuelle Probl Dermatol. 2003;32:94-101. Excluded - does not address a key question.
Demartines N, Mutter D, Marescaux J, et al. Preliminary assessment of the value and effect of expert consultation in telemedicine. J Am Coll Surg. 2000;190(4):466-70. Excluded - does not address a key question. [pmid: 10757385].
Demartines N, Mutter D, Vix M, et al. Assessment of telemedicine in surgical education and patient care. Ann Surg. 2000;231(2):282-91. Excluded - contains no or inadequate data. [pmid: 10674622]. [pmcid: 1420998].
Demartines N, Otto U, Mutter D, et al. An evaluation of telemedicine in surgery: telediagnosis compared with direct diagnosis. Archives of Surgery. 2000;135(7):849-53. Excluded - does not address a key question. [pmid: 10896381].
Demichelis F, Barbareschi M, Boi S, et al. Robotic telepathology for intraoperative remote diagnosis using a still-imaging-based system. American Journal of Clinical Pathology. Nov. 2001;116(5):744-52. Excluded - does not address a key question. [pmid: 11710693].
Demiris G, Speedie S, Finkelstein S, et al. Communication patterns and technical quality of virtual visits in home care. J Telemed Telecare. 2003;9(4):210-5. Excluded - does not address a key question. [pmid: 12952691].
DeMolles DA, Sparrow D, Gottlieb DJ, et al. A pilot trial of a telecommunications system in sleep apnea management. Med Care. Aug. 2004;42(8):764-9. Excluded - does not meet our definition of telemedicine. [pmid: 15258478].
Denton IC. Will patients use electronic personal health records? Responses from a real-life experience. J Healthc Inf Manag. Fall. 2001;15(3):251-9. Excluded - does not address a key question. [pmid: 11642143].
Deodhar J. Telemedicine by email--experience in neonatal care at a primary care facility in rural India. J Telemed Telecare. 2002;8(Suppl 2):20-1. Excluded - does not address a key question. [pmid: 12217120].
Diamond BJ, Shreve GM, Bonilla JM, et al. Telerehabilitation, cognition and user-accessibility. NeuroRehabilitation. 2003;18(2):171-7. Excluded - does not address a key question. [pmid: 12867679].
DiCianni N, Kobza L. A chance to heal. Home health agencies can improve patient care and increase profits with telehealth wound consulting. Health Manag Technol. Apr. 2002;23(4):22-4. Excluded - does not address a key question. [pmid: 11944571].
Dimmick SL, Burgiss SG, Robbins S, et al. Outcomes of an integrated telehealth network demonstration project. Telemed J E Health. Spring. 2003;9(1):13-23. Excluded - contains no or inadequate data. [pmid: 12699604].
Dimmick SL, Mustaleski C, Burgiss SG, et al. A case study of benefits & potential savings in rural home telemedicine. Home Healthc Nurse. 2000;18(2):124-35. Excluded - does not address a key question. [pmid: 11040644].
Doarn CR, Fitzgerald S, Rodas E, et al. Telemedicine to integrate intermittent surgical services into primary care. Telemed J E Health. Spring. 2002;8(1):131-7. Excluded - contains no or inadequate data. [pmid: 12020413].
Docherty EM, Ferguson J. Telemedical management of an odontoid peg fracture in the Shetland Isles. J Telemed Telecare. 2000;6(6):350-1. Excluded - contains no or inadequate data. [pmid: 11265105].
Dreyer NC, Dreyer KA, Shaw DK, et al. Efficacy of telemedicine in occupational therapy: a pilot study. J Allied Health. Spring. 2001;30(1):39-42. Excluded - contains no or inadequate data. [pmid: 11265272].
D'Souza R. Telemedicine for intensive support of psychiatric inpatients admitted to local hospitals. J Telemed Telecare 2000 6(1) Excluded - contains no or inadequate data
Dulou R, Poichotte A, Goasguen O, et al. Telemedicine in the management of a cervical dislocation by a mobile neurosurgeon. J Telemed Telecare. 2002;8(4):241-3. Excluded - contains no or inadequate data. [pmid: 12217109].
Dunn BE, Choi H, Almagro UA, et al. Combined robotic and nonrobotic telepathology as an integral service component of a geographically dispersed laboratory network. Hum Pathol. Dec. 2001;32(12):1300-3. Excluded - does not address a key question. [pmid: 11774160].
Dunne MG, Dunne SB. Improved teleradiology reporting using fax software. AJR Am J Roentgenol. Apr. 2004;182(4):871-4. Excluded - does not address a key question. [pmid: 15039156].
Durtschi A. Three patients' tele-home care experiences. Home Healthc Nurse. Jan. 2001;19(1):9-11. Excluded - contains no or inadequate data. [pmid: 11984924].
Egol KA, Helfet DL, Koval KJ. Efficacy of telemedicine in the initial management of orthopedic trauma. Am J Orthop. Jul. 2003;32(7):356-60. Excluded - contains no or inadequate data. [pmid: 12892282].
Eich HT, Muller RP, Schneeweiss A, et al. Initiation of a teleradiotherapeutic network for patients in German lymphoma studies. Int J Radiat Oncol Biol Phys. Mar 1. 2004;58(3):805-8. Excluded - does not address a key question. [pmid: 14967437].
Eisdorfer C, Czaja SJ, Loewenstein DA, et al. The effect of a family therapy and technology-based intervention on caregiver depression. Gerontologist. Aug. 2003;43(4):521-31. Excluded - wrong population. [pmid: 12937331]. [pmcid: 2413057].
Ellis DG, Mayrose J. The success of emergency telemedicine at the State University of New York at Buffalo. Telemed J E Health. Spring. 2003;9(1):73-9. Excluded - does not address a key question. [pmid: 12699610].
Ellis DG, Mayrose J, Jehle DV, et al. A telemedicine model for emergency care in a short-term correctional facility. Telemed J E Health. Summer. 2001;7(2):87-92. Excluded - wrong population. [pmid: 11421081].
Erlanger D, Kaushik T, Cantu R, et al. Symptom-based assessment of the severity of a concussion. J Neurosurg. Mar. 2003;98(3):477-84. Excluded - does not address a key question. [pmid: 12650417].
Fabrizio MD, Lee BR, Chan DY, et al. Effect of time delay on surgical performance during telesurgical manipulation. J Endourol. 2000;14(2):133-8. Excluded - does not address a key question. [pmid: 10772504].
Farup PG, Skar V. Collaboration by use of the Internet yields data of high quality and detects non-uniform management of patients with Helicobacter pylori infection.[see comment]. Scand J Gastroenterol. Dec. 2002;37(12):1466-70. Excluded - no comparison group. [pmid: 12523599].
Farzanfar R, Finkelstein J, Friedman RH. Testing the usability of two automated home-based patient-management systems. J Med Syst. Apr. 2004;28(2):143-53. Excluded - does not address a key question. [pmid: 15195845].
Faulkner K. Successes and failures in videoconferencing: a community health education programme. J Telemed Telecare. 2001;7(Suppl 2):65-7. Excluded - does not address a key question. [pmid: 11747664].
Ferguson J, Rowlands A, Palombo A, et al. Minor injuries telemedicine. J Telemed Telecare. 2003;9(Suppl 1):S14-6. Excluded - does not address a key question. [pmid: 12952707].
Ferris DG, Litaker MS, Gilman PA, et al. Patient acceptance and the psychological effects of women experiencing telecolposcopy and colposcopy. J Am Board Fam Pract. Sep–Oct. 2003;16(5):405-11. Excluded - does not address a key question. [pmid: 14645331].
Finch T, May C, Mair F, et al. Integrating service development with evaluation in telehealthcare: an ethnographic study. Bmj. Nov 22. 2003;327(7425):1205-9. Excluded - does not address a key question. [pmid: 14630758]. [pmcid: 274059].
Finkelstein J, Cabrera MR, Hripcsak G. Internet-based home asthma telemonitoring: can patients handle the technology?. Chest. 2000;117(1):148-55. Excluded - included in previous report. [pmid: 10631213].
Finkelstein SM, Speedie SM, Demiris G, et al. Telehomecare: quality, perception, satisfaction. Telemed J E Health. Summer. 2004;10(2):122-8. Excluded - contains no or inadequate data. [pmid: 15319041].
Fortin JP, Gagnon MP, Cloutier A, et al. Evaluation of a telemedicine demonstration project in the Magdalene Islands. J Telemed Telecare. 2003;9(2):89-94. Excluded - contains no or inadequate data. [pmid: 12699578].
Fries BE and James M. Identifying “appropriate” applicants for home and community based services: the MI Choice screening system. Cent Home Care Policy Res Policy Briefs 2003 Spring; (13):1–6. Excluded - does not address a key question
Fries BE, Shugarman LR, Morris JN, et al. A screening system for Michigan's home- and community-based long-term care programs. Gerontologist. Aug. 2002;42(4):462-74. Excluded - does not address a key question. [pmid: 12145374].
Frosch DL, Kaplan RM, Felitti VJ. A randomized controlled trial comparing internet and video to facilitate patient education for men considering the prostate specific antigen test.[see comment]. J Gen Intern Med. Oct. 2003;18(10):781-7. Excluded - does not address a key question. [pmid: 14521639]. [pmcid: 1494924].
Fujiwara T, Nishimura T, Ohkuko T, et al. Rationale and design of HOMED-BP Study: hypertension objective treatment based on measurement by electrical devices of blood pressure study. Blood Press Monit. Feb. 2002;7(1):77-82. Excluded - contains no or inadequate data. [pmid: 12040250].
Galvan FH, Bing EG, Bluthenthal RN. Accessing HIV testing and care. Journal of Acquired Immune Deficiency Syndromes: JAIDS. 2000;25(2):15. Excluded - contains no or inadequate data.
Gilbertson L, Langhorne P, Walker A, et al. Domiciliary occupational therapy for patients with stroke discharged from hospital: randomised controlled trial. Bmj. 2000;320(7235):603-6. Excluded - does not address a key question. [pmid: 10698876]. [pmcid: 27300].
Givens GD, Blanarovich A, Murphy T, et al. Internet-based tele-audiometry system for the assessment of hearing: a pilot study. Telemed J E Health. Winter. 2003;9(4):375-8. Excluded - does not address a key question. [pmid: 14980095].
Goldfield GS, Boachie A. Delivery of family therapy in the treatment of anorexia nervosa using telehealth. Telemed J E Health. Spring. 2003;9(1):111-4. Excluded - contains no or inadequate data. [pmid: 12699614].
Gomez EJ, Caceres C, Lopez D, et al. A web-based self-monitoring system for people living with HIV/AIDS. Comput Methods Programs Biomed. Jul. 2002;69(1):75-86. Excluded - contains no or inadequate data. [pmid: 12088595].
Gomez EJ, Hernando ME, Garcia A, et al. Telemedicine as a tool for intensive management of diabetes: the DIABTel experience. Comput Methods Programs Biomed. Aug. 2002;69(2):163-77. Excluded - no comparison group. [pmid: 12100795].
Gonzalez F, Iglesias R, Suarez A, et al. Tele-ophthalmology link between a primary health care centre and a reference hospital. Med Inform Internet Med. Oct–Dec. 2001;26(4):251-63. Excluded - no comparison group. [pmid: 11783710].
Graham LE, McGimpsey S, Wright S, et al. Could a low-cost audio-visual link be useful in rheumatology? J Telemed Telecare 2000 6(1) Excluded - included in previous report
Granlund H. Aspects of quality: face-to-face versus teleconsulting. Aktuelle Probl Dermatol. 2003;32:158-66. Excluded - does not address a key question.
Granlund H, Thoden CJ, Carlson C, et al. Realtime teleconsultations versus face-to-face consultations in dermatology: immediate and six-month outcome. J Telemed Telecare. 2003;9(4):204-9. Excluded - does not address a key question. [pmid: 12952690].
Gray J, Brain K, Iredale R, et al. A pilot study of telegenetics. J Telemed Telecare. 2000;6(4):245-7. Excluded - does not address a key question. [pmid: 11027129].
Gray JE, Safran C, Davis RB, et al. Baby CareLink: using the internet and telemedicine to improve care for high-risk infants. Pediatrics. 1318;106(6):1318-24. Excluded - wrong population. [pmid: 11099583].
Greist JH, Marks IM, Baer L, et al. Behavior therapy for obsessive-compulsive disorder guided by a computer or by a clinician compared with relaxation as a control. J Clin Psychiatry. Feb. 2002;63(2):138-45. Excluded - does not meet our definition of telemedicine. [pmid: 11874215].
Guilfoyle C, Wootton R, Hassall S, et al. Videoconferencing in facilities providing care for elderly people. J Telemed Telecare 2002 8(Suppl 3):S3:22–4. Excluded - does not address a key question
Haegen TW, Cupp CC, Hunsaker DH. Teleotolaryngology: a retrospective review at a military tertiary treatment facility. Otolaryngol Head Neck Surg. May. 2004;130(5):511-8. Excluded - wrong population. [pmid: 15138414].
Hagan L, Morin D, Lepine R. Evaluation of telenursing outcomes: satisfaction, self-care practices, and cost savings. Public Health Nurs. 2000;17(4):305-13. Excluded - does not address a key question. [pmid: 10943779].
Hall JA, Huber DL. Telephone management in substance abuse treatment. Telemedicine Journal & E Health. 2000;6(4):401-7. Excluded - contains no or inadequate data. [pmid: 11242548].
Hansson KS, Allebeck P, Malm U. Event recording in psychiatric care: development of an instrument and 1-year results. Nord J Psychiatry. 2001;55(1):25-31. Excluded - contains no or inadequate data. [pmid: 11827603].
Harley J, McLaren P, Blackwood G, et al. The use of videoconferencing to enhance tertiary mental health service provision to the island of Jersey. J Telemed Telecare. 2002;8(Suppl 2):36-8. Excluded - contains no or inadequate data. [pmid: 12217127].
Harno K, Arajarvi E, Paavola T, et al. Clinical effectiveness and cost analysis of patient referral by videoconferencing in orthopaedics. J Telemed Telecare. 2001;7(4):219-25. Excluded - contains no or inadequate data. [pmid: 11506757].
Harno K, Paavola T, Carlson C, et al. Patient referral by telemedicine: effectiveness and cost analysis of an Intranet system. J Telemed Telecare. 2000;6(6):320-9. Excluded - does not address a key question. [pmid: 11265100].
Harper DM, Moncur MM, Harper WH, et al. The technical performance and clinical feasibility of telecolposcopy. J Fam Pract. 2000;49(7):623-7. Excluded - no comparison group. [pmid: 10923572].
Hashimoto S, Shirato H, Kaneko K, et al. Clinical efficacy of telemedicine in emergency radiotherapy for malignant spinal cord compression. Journal of Digital Imaging. Sep. 2001;14(3):124-30. Excluded - contains no or inadequate data. [pmid: 11720334].
Hatzakis M Jr., Haselkorn J, Williams R, et al. Telemedicine and the delivery of health services to veterans with multiple sclerosis. J Rehabil Res Dev. May–Jun. 2003;40(3):265-82. Excluded - wrong population. [pmid: 14582530].
Hauber RP, Jones ML. Telerehabilitation support for families at home caring for individuals in prolonged states of reduced consciousness. J Head Trauma Rehabil. Dec. 2002;17(6):535-41. Excluded - contains no or inadequate data. [pmid: 12802244].
Helveston EM, Orge FH, Naranjo R, et al. Telemedicine: Strabismus e-consultation. J Aapos. Oct. 2001;5(5):291-6. Excluded - contains no or inadequate data. [pmid: 11641638].
High WA, Houston MS, Calobrisi SD, et al. Assessment of the accuracy of low-cost store-and-forward teledermatology consultation. Journal of the American Academy of Dermatology. 2000;42(5 Pt 1):776-83. Excluded - included in previous report. [pmid: 10775853].
Hildebrand R, Chow H, Williams C, et al. Feasibility of neuropsychological testing of older adults via videoconference: implications for assessing the capacity for independent living. J Telemed Telecare. 2004;10(3):130-4. Excluded - does not meet our definition of telemedicine. [pmid: 15165437].
Hill JV, Allman LR, Ditzler TF. Utility of real-time video teleconferencing in conducting family mental health sessions: two case reports. Telemed J E Health. Spring. 2001;7(1):55-9. Excluded - contains no or inadequate data. [pmid: 11321710].
Hilty DM, Luo JS, Morache C, et al. Telepsychiatry: an overview for psychiatrists. CNS Drugs. 2002;16(8):527-48. Excluded - does not address a key question. [pmid: 12096934].
Hilty DM, Marks SL, Urness D, et al. Clinical and educational telepsychiatry applications: a review.[see comment]. Can J Psychiatry. Jan. 2004;49(1):12-23. Excluded - does not address a key question. [pmid: 14763673].
Hilty DM, Nesbitt TS, Canning RD, et al. Telepsychiatry for the management of a liver transplantation candoesate in the primary care setting. Gen Hosp Psychiatry. 2000;22(2):122-3. Excluded - contains no or inadequate data. [pmid: 10896490].
Hilty DM, Sison JI, Nesbitt TS, et al. Telepsychiatric consultation for ADHD in the primary care setting. J Am Acad Child Adolesc Psychiatry. 2000;39(1):15-6. Excluded - wrong population. [pmid: 10638062].
Hui E and Woo J. Telehealth for older patients: the Hong Kong experience. J Telemed Telecare 2002 8(Suppl 3):S3:39–41. Excluded - does not address a key question
Hui E, Woo J, Hjelm M, et al. Telemedicine: a pilot study in nursing home residents. Gerontology. Mar–Apr. 2001;47(2):82-7. Excluded - contains no or inadequate data. [pmid: 11287732].
Hunkeler EM, Meresman JF, Hargreaves WA, et al. Efficacy of nurse telehealth care and peer support in augmenting treatment of depression in primary care.[see comment][comment]. Archives of Family Medicine. 2000;9(8):700-8. Excluded - does not meet our definition of telemedicine. [pmid: 10927707].
Jacklin PB, Roberts JA, Wallace P, et al. Virtual outreach: economic evaluation of joint teleconsultations for patients referred by their general practitioner for a specialist opinion. Bmj. Jul 12. 2003;327(7406):84. Excluded - does not address a key question. [pmid: 12855528]. [pmcid: 164917].
Jacobsen SE, Sprenger T, Andersson S, et al. Neuropsychological assessment and telemedicine: a preliminary study examining the reliability of neuropsychology services performed via telecommunication. J Int Neuropsychol Soc. Mar. 2003;9(3):472-8. Excluded - does not address a key question. [pmid: 12666771].
Jamara RJ, Denial A, Valentini D, et al. Clinical quality assessment using computer monitor photoimages of optic nerve head cupping. Optometry & Vision Science. 2000;77(8):433-6. Excluded - does not address a key question. [pmid: 10966070].
Jian G, Mao J, Jiang J. Telediagnosis of 168 cases of renal disease. J Telemed Telecare. 2002;8(6):360-1. Excluded - no comparison group. [pmid: 12537926].
Jithoo R, Govender PV, Corr P, et al. Telemedicine and neurosurgery: experience of a regional unit based in South Africa. J Telemed Telecare. 2003;9(2):63-6. Excluded - contains no or inadequate data. [pmid: 12699573].
Johanson M, Gustafsson M, Johansson LA. A remote auscultation tool for advanced home health-care. J Telemed Telecare. 2002;8(Suppl 2):45-7. Excluded - contains no or inadequate data. [pmid: 12217131].
Johnston D, Jones BN 3rd. Telepsychiatry consultations to a rural nursing facility: a 2-year experience. J Geriatr Psychiatry Neurol. Summer. 2001;14(2):72-5. Excluded - no comparison group. [pmid: 11419570].
Jones BN, 3rd, Johnston D, Reboussin B, et al. Reliability of telepsychiatry assessments: subjective versus observational ratings.[see comment]. J Geriatr Psychiatry Neurol. Summer. 2001;14(2):66-71. Excluded - contains no or inadequate data. [pmid: 11419569].
Jones D, Gill P, Harrison R, et al. An exploratory study of language interpretation services provided by videoconferencing. J Telemed Telecare. 2003;9(1):51-6. Excluded - does not address a key question. [pmid: 12641894].
Kaufman DR, Patel VL, Hilliman C, et al. Usability in the real world: assessing medical information technologies in patients' homes. J Biomed Inform. Feb–Apr. 2003;36(12):45-60. Excluded - does not address a key question. [pmid: 14552846].
Kawasaki S, Ito S, Satoh S, et al. Use of telemedicine in periodic screening of diabetic retinopathy. Telemed J E Health. Fall. 2003;9(3):235-9. Excluded - does not address a key question. [pmid: 14611690].
Kennedy C, Blignault I, Hornsby D, et al. Videoconferencing in the Queensland health service. J Telemed Telecare. 2001;7(5):266-71. Excluded - does not address a key question. [pmid: 11571080].
Kennedy C, Kirwan J, Cook C, et al. Telemedicine techniques can be used to facilitate the conduct of multicentre trials. J Telemed Telecare. 2000;6(6):343-7. Excluded - does not address a key question. [pmid: 11265104].
Kennedy C, Van Heerden A, Cook C, et al. Utilization and practical aspects of tele-ophthalmology between South Africa and the UK. J Telemed Telecare. 2001;7(Suppl 1):20-2. Excluded - contains no or inadequate data. [pmid: 11576478].
Kennedy C and Yellowlees P. A community-based approach to evaluation of health outcomes and costs for telepsychiatry in a rural population: preliminary results. J Telemed Telecare 2000 6(1) Excluded - contains no or inadequate data
Kenwright M, Marks IM. Computer-aided self-help for phobia/panic via internet at home: a pilot study. Br J Psychiatry. May. 2004;184:448-9. Excluded - no comparison group. [pmid: 15123511].
Kerner R, Yogev Y, Belkin A, et al. Maternal self-administered fetal heart rate monitoring and transmission from home in high-risk pregnancies. Int J Gynaecol Obstet. Jan. 2004;84(1):33-9. Excluded - wrong population. [pmid: 14698827].
Kirkwood KT, Peck DF, Bennie L. The consistency of neuropsychological assessments performed via telecommunication and face to face. J Telemed Telecare. 2000;6(3):147-51. Excluded - included in previous report. [pmid: 10912332].
Kiuru MJ, Paakkala TA, Kallio TT, et al. Effect of teleradiology on the diagnosis, treatment and prognosis of patients in a primary care centre. J Telemed Telecare. 2002;8(1):25-31. Excluded - no comparison group. [pmid: 11809081].
Kobza L, Scheurich A. The impact of telemedicine on outcomes of chronic wounds in the home care setting. Ostomy Wound Management. 2000;46(10):48-53. Excluded - no comparison group.
Korhonen I, Iivainen T, Lappalainen R, et al. TERVA: system for long-term monitoring of wellness at home. Telemed J E Health. Spring. 2001;7(1):61-72. Excluded - contains no or inadequate data. [pmid: 11321711].
Kornowski R, Zlochiver S, Botzer L, et al. Validation of vital signs recorded via a new telecare system. J Telemed Telecare. 2003;9(6):328-33. Excluded - contains no or inadequate data. [pmid: 14680516].
Kruger DF, White K, Galpern A, et al. Effect of modem transmission of blood glucose data on telephone consultation time, clinic work flow, and patient satisfaction for patients with gestational diabetes mellitus. J Am Acad Nurse Pract. Aug. 2003;15(8):371-5. Excluded - wrong population. [pmid: 14509102].
Krupinski E, Barker G, Rodriguez G, et al. Telemedicine versus in-person dermatology referrals: an analysis of case complexity. Telemed J E Health. Summer. 2002;8(2):143-7. Excluded - does not address a key question. [pmid: 12079603].
Krupinski EA, Barker G, Lopez AM, et al. An analysis of unsuccessful teleconsultations. J Telemed Telecare. 2004;10(1):6-10. Excluded - does not address a key question. [pmid: 15006208].
Krupinski EA, Engstrom M, Barker G, et al. The challenges of following patients and assessing outcomes in teledermatology. J Telemed Telecare. 2004;10(1):21-4. Excluded - contains no or inadequate data. [pmid: 15006211].
Labiris G, Coertzen I, Katsikas A, et al. An eight-year study of internet-based remote medical counselling. J Telemed Telecare. 2002;8(4):222-5. Excluded - does not address a key question. [pmid: 12217105].
Labiris G, Fanariotis M, Christoulakis C, et al. Tele-ophthalmology and conventional ophthalmology using a mobile medical unit in remote Greece. J Telemed Telecare. 2003;9(5):296-9. Excluded - does not address a key question. [pmid: 14599335].
Labiris G, Papadopoulis G, Lentaris G, et al. Internet based counseling to remote orthopedic patients. Acta Orthop Scand. Jun. 2004;75(3):366-7. Excluded - does not address a key question. [pmid: 15260433].
Ladyzynski P, Wojcicki JM, Krzymien J, et al. Teletransmission system supporting intensive insulin treatment of out-clinic type 1 diabetic pregnant women. Technical assessment during 3 years' application. Int J Artif Organs. Mar. 2001;24(3):157-63. Excluded - wrong population. [pmid: 11314810].
Lahtela JT, Lamminen H. Telemedical devices in diabetes management. Ann Med. 2002;34(4):241-7. Excluded - does not address a key question. [pmid: 12371708].
Lamminen H, Lamminen J, Ruohonen K, et al. A cost study of teleconsultation for primary-care ophthalmology and dermatology. J Telemed Telecare. 2001;7(3):167-73. Excluded - does not address a key question. [pmid: 11346477].
Lamminen H, Tuomi ML, Lamminen J, et al. A feasibility study of realtime teledermatology in Finland. J Telemed Telecare. 2000;6(2):102-7. Excluded - contains no or inadequate data. [pmid: 10824378].
Lange A, van de Ven JP, Schrieken BA, et al. Internet-mediated, protocol-driven treatment of psychological dysfunction. J Telemed Telecare. 2000;6(1):15-21. Excluded - contains no or inadequate data. [pmid: 10824385].
Lankford DA. Wireless CPAP patient monitoring: accuracy study. Telemed J E Health. Summer. 2004;10(2):162-9. Excluded - does not address a key question. [pmid: 15319046].
Lateef F, Anantharaman V. Maritime radio-medical services: the Singapore General Hospital experience. Am J Emerg Med. Jul. 2002;20(4):349-51. Excluded - does not address a key question. [pmid: 12098185].
Lau C, Churchill RS, Kim J, et al. Asynchronous web-based patient-centered home telemedicine system. IEEE Trans Biomed Eng. Dec. 2002;49(12):1452-62. Excluded - contains no or inadequate data. [pmid: 12542241].
Lee BR, Png DJ, Liew L, et al. Laparoscopic telesurgery between the United States and Singapore. Annals of the Academy of Medicine, Singapore. 2000;29(5):665-8. Excluded - does not address a key question.
Lee JH, Kim JH, Jhoo JH, et al. A telemedicine system as a care modality for dementia patients in Korea. Alzheimer Disease & Associated Disorders. 2000;14(2):94-101. Excluded - contains no or inadequate data. [pmid: 10850748].
Leifer D. Net gains for health. Nurs Stand. May 28–Jun 3. 2003;17(37):16-8. Excluded - does not address a key question.
Leonard S. The development and evaluation of a telepsychiatry service for prisoners. J Psychiatr Ment Health Nurs. Aug. 2004;11(4):461-8. Excluded - wrong population. [pmid: 15255921].
Leong FJ, Nicholson AG, McGee JO. Robotic telepathology: efficacy and usability in pulmonary pathology. J Pathol. Jun. 2002;197(2):211-7. Excluded - does not address a key question. [pmid: 12015745].
Lessing K, Blignault I. Mental health telemedicine programmes in Australia. J Telemed Telecare. 2001;7(6):317-23. Excluded - does not address a key question. [pmid: 11747632].
Lester J, Prady S, Finegan Y, et al. Learning from e-patients at Massachusetts General Hospital. Bmj. May 15. 2004;328(7449):1188-90. Excluded - does not address a key question. [pmid: 15142930]. [pmcid: 411105].
Lieder TR. Telemedicine company brings ICU patients to the physician. American Journal of Health System Pharmacy. 2000;57(24):2246-7. Excluded - contains no or inadequate data. [pmid: 11146964].
Lim AC, See AC, Shumack SP. Progress in Australian teledermatology. J Telemed Telecare. 2001;7(Suppl 2):55-9. Excluded - contains no or inadequate data. [pmid: 11747660].
Lin CC, Bai Y, Chen JY. Reliability of information provided by patients of a virtual psychiatric clinic. Psychiatr Serv. Aug. 2003;54(8):1167-8. Excluded - does not address a key question. [pmid: 12883154].
Lin CC, Chen HS, Chen CY, et al. Implementation and evaluation of a multifunctional telemedicine system in NTUH. Int J Med Inf. May. 2001;61(23):175-87. Excluded - does not address a key question.
Lin DY, Blumenkranz MS, Brothers RJ, et al. The sensitivity and specificity of single-field nonmydriatic monochromatic digital fundus photography with remote image interpretation for diabetic retinopathy screening: a comparison with ophthalmoscopy and standardized mydriatic color photography.[see comment]. Am J Ophthalmol. Aug. 2002;134(2):204-13. Excluded - does not address a key question. [pmid: 12140027].
Liu L and Miyazaki M. Telerehabilitation at the University of Alberta. J Telemed Telecare 2000 6(2) Excluded - contains no or inadequate data
Loane MA, Bloomer SE, Corbett R, et al. A randomized controlled trial assessing the health economics of realtime teledermatology compared with conventional care: an urban versus rural perspective. J Telemed Telecare. 2001;7(2):108-18. Excluded - does not address a key question. [pmid: 11331049].
Loane MA, Bloomer SE, Corbett R, et al. A comparison of real-time and store-and-forward teledermatology: a cost-benefit study. Br J Dermatol. 143(6):1241-7. Excluded - no comparison group. [pmid: 11122028].
Loane MA, Bloomer SE, Corbett R, et al. A randomized controlled trial to assess the clinical effectiveness of both realtime and store-and-forward teledermatology compared with conventional care. J Telemed Telecare 2000 6(1) Excluded - included in previous report
Loh PK, Ramesh P, Maher S, et al. Can patients with dementia be assessed at a distance? The use of Telehealth and standardised assessments. Intern Med J. May. 2004;34(5):239-42. Excluded - does not address a key question. [pmid: 15151669].
Louis AA, Turner T, Gretton M, et al. A systematic review of telemonitoring for the management of heart failure. Eur J Heart Fail. Oct. 2003;5(5):583-90. Excluded - contains no or inadequate data. [pmid: 14607195].
Lowry J. The development of a telemedicine system for a centralized maxillofacial unit serving four towns. J Telemed Telecare. 2001;7(Suppl 1):58-9. Excluded - does not address a key question. [pmid: 11576494].
Luethi U, Risch L, Korte W, et al. Telehematology: critical determinants for successful implementation. Blood. Jan 15. 2004;103(2):486-8. Excluded - contains no or inadequate data. [pmid: 12969957].
Lyketsos CG, Roques C, Hovanec L, et al. Telemedicine use and the reduction of psychiatric admissions from a long-term care facility. J Geriatr Psychiatry Neurol. Summer. 2001;14(2):76-9. Excluded - contains no or inadequate data. [pmid: 11419571].
Lynch J, Weaver L, Hall P, et al. Using telehealth technology to support CME in end-of-life care for community physicians in Ontario. Telemed J E Health. Spring. 2004;10(1):103-7. Excluded - contains no or inadequate data. [pmid: 15104922].
Macduff C, West B, Harvey S. Telemedicine in rural care. Part 1: Developing and evaluating a nurse-led initiative. Nurs Stand. Apr 25–May 1. 2001;15(32):33-8. Excluded - does not address a key question.
Macduff C, West B, Harvey S. Telemedicine in rural care. Part 2: Assessing the wider issues. Nurs Stand. May 2–8. 2001;15(33):33-7. Excluded - does not address a key question.
MacFarlane A, Harrison R, Wallace P. The benefits of a qualitative approach to telemedicine research. J Telemed Telecare. 2002;8(Suppl 2):56-7. Excluded - does not address a key question. [pmid: 12217137].
Mair F, Boland A, Angus R, et al. A randomized controlled trial of home telecare. J Telemed Telecare. 2002;8(Suppl 2):58-60. Excluded - contains no or inadequate data. [pmid: 12217138].
Malone F, Callahan CW, Chan DS, et al. Caring for children with asthma through teleconsultation: “ECHO-Pac, The Electronic Children's Hospital of the Pacific”. Telemed J E Health. Summer. 2004;10(2):138-46. Excluded - wrong population. [pmid: 15319043].
Mann T, Colven R. A picture is worth more than a thousand words: enhancement of a pre-exam telephone consultation in dermatology with digital images. Acad Med. Jul. 2002;77(7):742-3. Excluded - contains no or inadequate data. [pmid: 12114161].
Mantzouranis EC. User friendliness aspects of home care telematics. Methods Inf Med. 2002;41(5):370-5. Excluded - does not address a key question. [pmid: 12501807].
Marchevsky AM, Lau SK, Khanafshar E, et al. Internet teleconferencing method for telepathology consultations from lung and heart transplant patients. Hum Pathol. Apr. 2002;33(4):410-4. Excluded - does not address a key question. [pmid: 12055675].
Marcin JP, Nesbitt TS, Kallas HJ, et al. Use of telemedicine to provide pediatric critical care inpatient consultations to underserved rural Northern California. J Pediatr. Mar. 2004;144(3):375-80. Excluded - wrong population. [pmid: 15001947].
Maree DM, Videler EA, Hallauer M, et al. Comparison of a new desktop spirometer (Diagnosa) with a laboratory spirometer. Respiration. 2001;68(4):400-4. Excluded - does not address a key question. [pmid: 11464088].
Marietti C. Healthcare innovations in technology systems Telehealth in the city. The Charles R. Drew University-Nortel partnership delivers quality healthcare to an urban neighborhood. Healthcare Informatics. Jun. 2001;18(6):97-8. Excluded - does not address a key question. [pmid: 11419337].
Marks IM, Kenwright M, McDonough M, et al. Saving clinicians' time by delegating routine aspects of therapy to a computer: a randomized controlled trial in phobia/panic disorder. Psychol Med. Jan. 2004;34(1):9-17. Excluded - does not address a key question. [pmid: 14971623].
Martin EM, Coyle MK, Warden DL, et al. Telephonic nursing in traumatic brain injury. Am J Nurs. Oct. 2003;103(10):75-81. Excluded - does not address a key question. [pmid: 14530713].
Martin S, Rankin G. Using commercially available technology to assist in the delivery of person-centred health and social care. J Telemed Telecare. 2002;8(Suppl 2):60-2. Excluded - contains no or inadequate data. [pmid: 12217139].
Mathewson C, Adkins VK, Jones ML. Initial experiences with telerehabilitation and contingency management programs for the prevention and management of pressure ulceration in patients with spinal cord injuries. J Wound Ostomy Continence Nurs. 2000;27(5):269-71. Excluded - contains no or inadequate data. [pmid: 10999965].
Mattson S, Shearer N, Long C. Exploring telehealth opportunities in domestic violence shelters. J Am Acad Nurse Pract. Oct. 2002;14(10):465-70. Excluded - contains no or inadequate data. [pmid: 12426804].
Mavrogeni SI, Tsirintani M, Kleanthous C, et al. Supervision of thrombolysis of acute myocardial infarction using telemedicine. J Telemed Telecare. 2000;6(1):54-8. Excluded - contains no or inadequate data. [pmid: 10824393].
May C, Gask L, Ellis N, et al. Telepsychiatry evaluation in the north-west of England: preliminary results of a qualitative study. J Telemed Telecare 20006(1) Excluded - contains no or inadequate data
Mbao MN, Eikelboom RH, Atlas MD, et al. Evaluation of video-otoscopes suitable for teleotology. Telemed J E Health. Winter. 2003;9(4):325-30. Excluded - contains no or inadequate data. [pmid: 14980089].
McCafferty M, Sorbellini D, Cianci P. Telemetry to home: successful discharge of patients with ventricular assist devices. Crit Care Nurse. Jun. 2002;22(3):43-51. Excluded - contains no or inadequate data. [pmid: 12092292].
McGauran A. Telemedicine Straight to video. Health Service Journal. Jul 31. 2003;113(5866):26-7. Excluded - contains no or inadequate data. [pmid: 12916407].
McIntosh A, Thie J. The development of a new model for community telemedicine services. J Telemed Telecare. 2001;7(Suppl 1):69-72. Excluded - does not address a key question. [pmid: 11576499].
McKinstry B, Walker J, Campbell C, et al. Telephone consultations to manage requests for same-day appointments: a randomised controlled trial in two practices. Br J Gen Pract. Apr. 2002;52(477):306-10. Excluded - does not meet our definition of telemedicine. [pmid: 11942448]. [pmcid: 1314272].
McLaren P, Ahlbom J, Riley A, et al. The North Lewisham telepsychiatry project: beyond the pilot phase. J Telemed Telecare. 2002;8(Suppl 2):98-100. Excluded - contains no or inadequate data. [pmid: 12217156].
Meade B, Barnett P. Emergency care in a remote area using interactive video technology: a study in prehospital telemedicine. J Telemed Telecare. 2002;8(2):115-7. Excluded - does not address a key question. [pmid: 11972948].
Melcer T, Crann B, Hunsaker D, et al. A retrospective evaluation of the development of a telemedicine network in a military setting. Mil Med. Jun. 2002;167(6):510-5. Excluded - wrong population. [pmid: 12099089].
Melcer T, Hunsaker D, Crann B, et al. A prospective evaluation of ENT telemedicine in remote military populations seeking specialty care. Telemed J E Health. Fall. 2002;8(3):301-11. Excluded - contains no or inadequate data. [pmid: 12419024].
Mengden T, Vetter H, Tisler A, et al. Tele-monitoring of home blood pressure. Blood Press Monit. Aug. 2001;6(4):185-9. Excluded - does not address a key question. [pmid: 11805466].
Michelson G, Striebel W, Prihoda W, et al. Telemedicine in the control of intra-ocular pressure. J Telemed Telecare 2000 6(1) Excluded - contains no or inadequate data
Mielonen ML, Vaisanen L, Moring J, et al. Implementation of a telepsychiatric network in northern Finland. Aktuelle Probl Dermatol. 2003;32:132-40. Excluded - does not address a key question.
Miller EA. Telemedicine and doctor-patient communication: an analytical survey of the literature. J Telemed Telecare. 2001;7(1):1-17. Excluded - does not address a key question. [pmid: 11265933].
Miller GG, Levesque K. Telehealth provides effective pediatric surgery care to remote locations. J Pediatr Surg. May. 2002;37(5):752-4. Excluded - wrong population. [pmid: 11987093].
Miloud GL. Response to: Heartcare: an Internet-based information and support system for patient home recovery after coronary artery bypass graft (CABG) surgery by P. Flatley Brennan, S.M. Moore, G. Bjornsdottir, J. Jones, C. Visovsky and M. Rogers (2001) Journal Of Advanced Nursing 35, 699–708.[comment]. J Adv Nurs 2002 May; 38(4):425; author reply 425–6. Excluded - does not address a key question
Mitchell JG, Disney AP, Roberts M. Renal telemedicine to the home. J Telemed Telecare. 2000;6(1):59-62. Excluded - contains no or inadequate data. [pmid: 10824394].
Miyashita T, Takizawa M, Nakai K, et al. Realtime ultrasound screening by satellite telecommunication. J Telemed Telecare. 2003;9(Suppl 1):S60-1. Excluded - does not address a key question. [pmid: 12952726].
Miyashita T, Takizawa M, Nakai K, et al. Telemedicine of the heart: real-time telescreening of echocardiography using satellite telecommunication. Circ J. Jun. 2003;67(6):562-4. Excluded - does not address a key question. [pmid: 12808280].
Miyazaki M, Stuart M, Liu L, et al. Use of ISDN video-phones for clients receiving palliative and antenatal home care. J Telemed Telecare. 2003;9(2):72-7. Excluded - does not address a key question. [pmid: 12699575].
Mizushima H, Uchiyama E, Nagata H, et al. Japanese experience of telemedicine in oncology. Int J Med Inf. May. 2001;61(23):207-15. Excluded - does not address a key question.
Molinari G, Reboa G, Frascio M, et al. The role of telecardiology in supporting the decision-making process of general practitioners during the management of patients with suspected cardiac events. J Telemed Telecare. 2002;8(2):97-101. Excluded - does not address a key question. [pmid: 11972944].
Moller DS, Doeseriksen A, Sorensen S, et al. Accuracy of telemedical home blood pressure measurement in the diagnosis of hypertension. J Hum Hypertens. Aug. 2003;17(8):549-54. Excluded - does not address a key question. [pmid: 12874612].
Moller DS, Doeseriksen A, Sorensen S, et al. Tele-monitoring of home blood pressure in treated hypertensive patients. Blood Press. 2003;12(1):56-62. Excluded - does not address a key question. [pmid: 12699137].
Montani S, Bellazzi R, Quaglini S, et al. Meta-analysis of the effect of the use of computer-based systems on the metabolic control of patients with diabetes mellitus. Diabetes Technol Ther. Fall. 2001;3(3):347-56. Excluded - does not address a key question. [pmid: 11762513].
Montironi R, Thompson D, Scarpelli M, et al. Transcontinental communication and quantitative digital histopathology via the Internet; with special reference to prostate neoplasia. J Clin Pathol. Jun. 2002;55(6):452-60. Excluded - does not address a key question. [pmid: 12037030]. [pmcid: 1769673].
Morrison J, Bergauer NK, Jacques D, et al. Telemedicine: cost-effective management of high-risk pregnancy. Manag Care 2001 Nov; 10(11):42–6, 48–9. Excluded - wrong population
Mueller TM, Vuckovic KM, Knox DA, et al. Telemanagement of heart failure: a diuretic treatment algorithm for advanced practice nurses. Heart Lung. Sep–Oct. 2002;31(5):340-7. Excluded - does not address a key question. [pmid: 12487012].
Mukundan S Jr., Vydareny K, Vassallo DJ, et al. Trial telemedicine system for supporting medical students on elective in the developing world. Acad Radiol. Jul. 2003;10(7):794-7. Excluded - does not address a key question. [pmid: 12862289].
Murdoch I, Bainbridge J, Taylor P, et al. Postoperative evaluation of patients following ophthalmic surgery. J Telemed Telecare 2000 6(1) Excluded - contains no or inadequate data
Murphy JC. Telemedicine offers new way to manage asthma. Am J Health Syst Pharm. Sep 15. 2001;58(18):1693-1696. Excluded - contains no or inadequate data. [pmid: 11571810].
Nakagawa A, Marks IM, Park JM, et al. Self-treatment of obsessive-compulsive disorder guided by manual and computer-conducted telephone interview. J Telemed Telecare. 2000;6(1):22-6. Excluded - does not meet our definition of telemedicine. [pmid: 10824386].
Nakajima I, Juzoji H, Wijarnpreecha S, et al. The final report of the project ‘AMINE’ the Asia Pacific Medical Information Network using with ETS-V. Int J Med Inf. May. 2001;61(23):87-96. Excluded - does not address a key question.
Nakamoto H, Hatta M, Tanaka A, et al. Telemedicine system for home automated peritoneal dialysis. Advances in Peritoneal Dialysis. 2000;16:191-4. Excluded - contains no or inadequate data. [pmid: 11045291].
Nakamoto H, Kawamoto A, Tanabe Y, et al. Telemedicine system using a cellular telephone for continuous ambulatory peritoneal dialysis patients. Advances in Peritoneal Dialysis. 2003;19:124-9. Excluded - contains no or inadequate data. [pmid: 14763048].
Nelson EL, Barnard M, Cain S. Treating childhood depression over videoconferencing. Telemed J E Health. Spring. 2003;9(1):49-55. Excluded - wrong population. [pmid: 12699607].
Niiranen S, Lamminen H. Feasibility of personal prothrombin time measurement in anticoagulant treatment follow-up. J Telemed Telecare. 2002;8(6):359-60. Excluded - contains no or inadequate data. [pmid: 12537925].
Niiranen S, Lamminen H, Mattila H, et al. Personal health care services through digital television. Comput Methods Programs Biomed. Jun. 2002;68(3):249-59. Excluded - does not address a key question. [pmid: 12074851].
Niiranen S, Lamminen H, Niemi K, et al. A cost study of new media supported near oral anticoagulant treatment follow-up. Int J Med Inf. Apr. 2003;70(1):19-29. Excluded - does not address a key question.
Norris TE, Hart GL, Larson EH, et al. Low-bandwidth, low-cost telemedicine consultations in rural family practice.[see comment]. J Am Board Fam Pract. Mar–Apr. 2002;15(2):123-7. Excluded - does not address a key question. [pmid: 12002196].
Nowakowski R, Hammack G. Ophthalmic telemedicine at the Alabama Institute for Deaf and Blind. Optometry (St Louis, Mo ). Jan. 2001;72(1):8-12. Excluded - contains no or inadequate data.
Oakley AM. Teledermatology in New Zealand. J Cutan Med Surg. Mar–Apr. 2001;5(2):111-6. Excluded - contains no or inadequate data. [pmid: 11443482].
Oakley AM, Kerr P, Duffill M, et al. Patient cost-benefits of realtime teledermatology--a comparison of data from Northern Ireland and New Zealand. J Telemed Telecare. 2000;6(2):97-101. Excluded - does not address a key question. [pmid: 10824377].
Ogasawara K, Ito K, Jiang G, et al. Preliminary clinical evaluation of a video transmission system for home visits. J Telemed Telecare. 2003;9(5):292-5. Excluded - does not address a key question. [pmid: 14599334].
Oh JA, Kim HS, Yoon KH, et al. A telephone-delivered intervention to improve glycemic control in type 2 diabetic patients. Yonsei Med J. Feb. 2003;44(1):1-8. Excluded - does not address a key question. [pmid: 12619168].
Oliveira MR, Wen CL, Neto CF, et al. Web site for training nonmedical health-care workers to identify potentially malignant skin lesions and for teledermatology. Telemed J E Health. Fall. 2002;8(3):323-32. Excluded - does not address a key question. [pmid: 12419026].
Olver IN, Selva-Nayagam S. Evaluation of a telemedicine link between Darwin and Adelaide to facilitate cancer management. Telemedicine Journal. 2000;6(2):213-8. Excluded - does not address a key question. [pmid: 10957733].
Orlov OI, Levanov VM, Merrell RC, et al. A pilot telemedicine project in the Privolzhsky District, Russia. Telemed J E Health. Fall. 2003;9(3):291-5. Excluded - contains no or inadequate data. [pmid: 14611697].
Ostojic V, Stipic-Markovic A, Tudman Z, et al. A feasibility study of realtime telemedicine in Croatia using Internet videoconferencing. J Telemed Telecare. 2000;6(3):172-6. Excluded - does not address a key question. [pmid: 10912337].
Paiva T, Coelho H, Almeida A, et al. Neuroteleconsultation for general practitioners. Studies in Health Technology & Informatics. 2000;78:329-41. Excluded - does not address a key question. [pmid: 11151604].
Paiva T, Coelho H, Araujo MT, et al. Neurological teleconsultation for general practitioners. J Telemed Telecare. 2001;7(3):149-54. Excluded - does not address a key question. [pmid: 11346474].
Pak HS. Teledermoscopy: a specific application of teledermotology [comment]. Skinmed. Sep–Oct. 2002;1(1):18-9. Excluded - does not address a key question. [pmid: 14673231].
Pallawala PM, Lun KC. EMR based telegeriatric system. Int J Med Inf. May. 2001;61(23):229-34. Excluded - does not address a key question.
Pallawala PM, Lun KC. EMR-based TeleGeriatric system. Medinfo. 2001;10(Pt 1):849-53. Excluded - contains no or inadequate data. [pmid: 11604856].
Palombo A, Ferguson J, Rowlands A, et al. An evaluation of a telemedicine fracture review clinic. J Telemed Telecare. 2003;9(Suppl 1):S31-3. Excluded - does not address a key question. [pmid: 12952714].
Pandit RB. Role of cardiophone in the pre-hospital treatment of acute myocardial infarction. Journal of the Association of Physicians of India. Sep. 2001;49:946. Excluded - does not meet our definition of telemedicine. [pmid: 11837777].
Park DG, Kim HC. Comparative study of telecommunication methods for emergency telemedicine. J Telemed Telecare. 2003;9(5):300-3. Excluded - does not address a key question. [pmid: 14599336].
Patricoski C, Ferguson AS. ECG acquisition using telemedicine in Alaska. Alaska Med. Jul–Sep. 2003;45(3):60-3. Excluded - contains no or inadequate data. [pmid: 14686011].
Patricoski C, Kokesh J, Ferguson AS, et al. A comparison of in-person examination and video otoscope imaging for tympanostomy tube follow-up. Telemed J E Health. Winter. 2003;9(4):331-44. Excluded - does not address a key question. [pmid: 14980090].
Patten SB. Prevention of depressive symptoms through the use of distance technologies. Psychiatr Serv. Mar. 2003;54(3):396-8. Excluded - does not meet our definition of telemedicine. [pmid: 12610251].
Patterson V. Teleneurology in Northern Ireland: a success. J Telemed Telecare 2002 8(Suppl 3):S3:46–7. Excluded - does not address a key question
Patterson V, Hoque F, Vassallo D, et al. Store-and-forward teleneurology in developing countries. J Telemed Telecare. 2001;7(Suppl 1):52-3. Excluded - contains no or inadequate data. [pmid: 11576491].
Patterson V, Humphreys J, Chua R. Teleneurology by email. J Telemed Telecare. 2003;9(Suppl 2):S42-3. Excluded - does not address a key question. [pmid: 14728758].
Patterson VH, Craig JJ, Wootton R. Effective diagnosis of spinal cord compression using telemedicine. Br J Neurosurg. 2000;14(6):552-4. Excluded - contains no or inadequate data. [pmid: 11272034].
Pearson B, Katz SE, Soucie V, et al. Evidence-based care for depression in Maine: dissemination of the Kaiser Permanente Nurse Telecare Program. Psychiatr Q. Spring. 2003;74(1):91-102. Excluded - does not meet our definition of telemedicine. [pmid: 12602791].
Pedley D, Ferguson J, Palombo A, et al. Community coronary units: strategies to promote pre-hospital thrombolysis. J Telemed Telecare. 2002;8(Suppl 2):24-5. Excluded - does not address a key question. [pmid: 12217122].
Pelletier-Fleury N, Gagnadoux F, Philippe C, et al. A cost-minimization study of telemedicine. The case of telemonitored polysomnography to diagnose obstructive sleep apnea syndrome. Int J Technol Assess Health Care. Fall. 2001;17(4):604-11. Excluded - does not address a key question. [pmid: 11758304].
Perlemuter L, Yomtov B. Feasibility and usefulness of dedicated software and e-mail for self-monitoring blood glucose in treating diabetes. Diabet Med. Aug. 2002;19(8):701-2. Excluded - does not address a key question. [pmid: 12147159].
Person DA. Pacific Island Health Care Project: early experiences with a Web-based consultation and referral network. Pacific Health Dialog. 2000;7(2):29-35. Excluded - contains no or inadequate data. [pmid: 11588916].
Piccolo D, Peris K, Chimenti S, et al. Jumping into the future using teledermoscopy.[see comment]. Skinmed. Sep–Oct. 2002;1(1):20-4. Excluded - contains no or inadequate data. [pmid: 14673232].
Pierce LL, Steiner V, Govoni AL, et al. Internet-based support for rural caregivers of persons with stroke shows promise. Rehabil Nurs 2004. May–Jun. 2004;29(3):95-9. Excluded - does not address a key question.
Piwernetz K. DIABCARE Quality Network in Europe--a model for quality management in chronic diseases. Int Clin Psychopharmacol. Apr. 2001;16(Suppl 3):S5-13. Excluded - does not address a key question. [pmid: 11459330].
Pollard SE, LePage JP. Telepsychiatry in a rural inpatient setting. Psychiatr Serv. Dec. 2001;52(12):1659. Excluded - does not address a key question. [pmid: 11726763].
Poon WS, Leung CH, Lam MK, et al. The comparative impact of video-consultation on neurosurgical health services. Int J Med Inf. Jul. 2001;62(23):175-80. Excluded - no comparison group.
Port K, Palm K, Viigimaa M. Self-reported compliance of patients receiving antihypertensive treatment: use of a telemonitoring home care system. J Telemed Telecare. 2003;9(Suppl 1):S65-6. Excluded - no comparison group. [pmid: 12952728].
Prado M, Roa L, Reina-Tosina J, et al. Renal telehealthcare system based on a patient physiological image: a novel hybrid approach in telemedicine. Telemed J E Health. Summer. 2003;9(2):149-65. Excluded - does not address a key question. [pmid: 12855038].
Reeves PM. Coping in cyberspace: the impact of Internet use on the ability of HIV-positive individuals to deal with their illness. J Health Commun. 2000;5:47-59. Excluded - does not address a key question. [pmid: 11010356].
Regnard C. Using videoconferencing in palliative care. Palliative Medicine. 2000;14(6):519-28. Excluded - does not address a key question. [pmid: 11219882].
Ricker JH, Rosenthal M, Garay E, et al. Telerehabilitation needs: a survey of persons with acquired brain injury. J Head Trauma Rehabil. Jun. 2002;17(3):242-50. Excluded - contains no or inadequate data. [pmid: 12086577].
Robinson JG, Conroy C, Wickemeyer WJ. A novel telephone-based system for management of secondary prevention to a low-density lipoprotein cholesterol < or = 100 mg/dl. American Journal of Cardiology. 2000;85(3):305-8. Excluded - does not meet our definition of telemedicine. [pmid: 11078297].
Rogers MA, Buchan DA, Small D, et al. Telemedicine improves diagnosis of essential hypertension compared with usual care. J Telemed Telecare. 2002;8(6):344-9. Excluded - does not meet our definition of telemedicine. [pmid: 12537922].
Romano MJ, Hernandez J, Gaylor A, et al. Improvement in asthma symptoms and quality of life in pediatric patients through specialty care delivered via telemedicine. Telemed J E Health. Winter. 2001;7(4):281-6. Excluded - no comparison group. [pmid: 11886666].
Rosenfeld BA, Dorman T, Breslow MJ, et al. Intensive care unit telemedicine: alternate paradigm for providing continuous intensivist care.[see comment]. Crit Care Med. 2000;28(12):3925-31. Excluded - included in previous report. [pmid: 11153637].
Ross MD, Twombly IA, Bruyns C, et al. Telecommunications for health care over distance: the Virtual Collaborative Clinic. Studies in Health Technology & Informatics. 2000;70:286-91. Excluded - contains no or inadequate data. [pmid: 10977558].
Ross SE, Moore LA, Earnest MA, et al. Providing a web-based online medical record with electronic communication capabilities to patients with congestive heart failure: randomized trial.[see comment]. J Med Internet Res. May 14. 2004;6(2):e12. Excluded - does not address a key question. [pmid: 15249261].
Russell TG, Jull GA, Wootton R. The diagnostic reliability of Internet-based observational kinematic gait analysis. J Telemed Telecare. 2003;9(Suppl 2):S48-51. Excluded - no comparison group. [pmid: 14728760].
Safran C. The collaborative edge: patient empowerment for vulnerable populations. Int J Med Inf. Mar. 2003;69(23):185-90. Excluded - wrong population.
Saligari J, Flicker L, Loh PK, et al. The clinical achievements of a geriatric telehealth project in its first year. J Telemed Telecare 2002 8(Suppl 3):S3:53-5. Excluded - no comparison group
Salmon S, Brint G, Marshall D, et al. Telemedicine use in two nurse-led minor injuries units. J Telemed Telecare 2000 6(1) Excluded - contains no or inadequate data
Sanford JA, Jones M, Daviou P, et al. Using telerehabilitation to identify home modification needs. Assist Technol. Summer. 2004;16(1):43-53. Excluded - does not address a key question. [pmid: 15357147].
Savard L, Borstad A, Tkachuck J, et al. Telerehabilitation consultations for clients with neurologic diagnoses: cases from rural Minnesota and American Samoa. NeuroRehabilitation. 2003;18(2):93-102. Excluded - contains no or inadequate data. [pmid: 12867672].
Scalvini S, Zanelli E, Volterrani M, et al. A pilot study of nurse-led, home-based telecardiology for patients with chronic heart failure. J Telemed Telecare. 2004;10(2):113-7. Excluded - contains no or inadequate data. [pmid: 15068649].
Scherrer-Bannerman A, Fofonoff D, Minshall D, et al. Web-based education and support for patients on the cardiac surgery waiting list. J Telemed Telecare 2000 6(2) Excluded - contains no or inadequate data
Schmid-Grendelmeier P, Doe P, Pakenham-Walsh N. Teledermatology in sub-Saharan Africa. Aktuelle Probl Dermatol. 2003;32:233-46. Excluded - does not address a key question.
Schopp LH, Johnstone BR and Merveille OC. Multidimensional telecare strategies for rural residents with brain injury. J Telemed Telecare 2000 6(1) Excluded - does not address a key question
Setterberg SR, Busseri MA, Fleissner RM, et al. Remote assessment of the use of seclusion and restraint with paediatric psychiatric patients. J Telemed Telecare. 2003;9(3):176-9. Excluded - wrong population. [pmid: 12877781].
Sezeur A, Degramont A, Touboul E, et al. Teleconsultation before chemotherapy for recently operated on patients. American Journal of Surgery. Jul. 2001;182(1):49-51. Excluded - contains no or inadequate data. [pmid: 11532415].
Shannon G, Nesbitt T, Bakalar R, et al. Telemedicine/telehealth: an international perspective. Organizational models of telemedicine and regional telemedicine networks. Telemed J E Health. Spring. 2002;8(1):61-70. Excluded - does not address a key question. [pmid: 12020406].
Sicotte C, Lehoux P. Teleconsultation: rejected and emerging uses. Methods Inf Med. 2003;42(4):451-7. Excluded - does not address a key question. [pmid: 14534649].
Sicotte C, Lehoux P, Fortier-Blanc J, et al. Feasibility and outcome evaluation of a telemedicine application in speech-language pathology. J Telemed Telecare. 2003;9(5):253-8. Excluded - no comparison group. [pmid: 14599327].
Simpson J, Doze S, Urness D, et al. Telepsychiatry as a routine service--the perspective of the patient. J Telemed Telecare. 2001;7(3):155-60. Excluded - does not address a key question. [pmid: 11346475].
Sing A, Salzman J, Sing D. Problems and risks of unsolicited e-mails in patient-physician encounters in travel medicine settings. J Travel Med. May–Jun. 2001;8(3):109-12. Excluded - does not address a key question. [pmid: 11468110].
Sixsmith AJ. An evaluation of an intelligent home monitoring system. J Telemed Telecare. 2000;6(2):63-72. Excluded - contains no or inadequate data. [pmid: 10824373].
Smith AC, Batch J, Lang E, et al. The use of online health techniques to assist with the delivery of specialist paediatric diabetes services in Queensland. J Telemed Telecare. 2003;9(Suppl 2):S54-7. Excluded - wrong population. [pmid: 14728762].
Smith AC, Isles A, McCrossin R, et al. The point-of-referral barrier--a factor in the success of telehealth. J Telemed Telecare. 2001;7(Suppl 2):75-8. Excluded - wrong population. [pmid: 11747668].
Smith AC, Kairl JA, Kimble R. Post-acute care for a paediatric burns patient in regional Queensland. J Telemed Telecare. 2002;8(5):302-4. Excluded - wrong population. [pmid: 12396860].
Smith AC, Williams M, Van der Westhuyzen J, et al. A comparison of telepaediatric activity at two regional hospitals in Queensland. J Telemed Telecare 2002 8(Suppl 3):S3:58–62. Excluded - wrong population
Stalfors J, Edstrom S, Bjork-Eriksson T, et al. Accuracy of tele-oncology compared with face-to-face consultation in head and neck cancer case conferences. J Telemed Telecare. 2001;7(6):338-43. Excluded - no comparison group. [pmid: 11747635].
Steel S, Lock S, Johnson N, et al. A feasibility study of remote monitoring of asthmatic patients. J Telemed Telecare. 2002;8(5):290-6. Excluded - contains no or inadequate data. [pmid: 12396858].
Stormo A, Sollid S, Stormer J, et al. Neurosurgical teleconsultations in northern Norway. J Telemed Telecare. 2004;10(3):135-9. Excluded - does not address a key question. [pmid: 15165438].
Stroetmann KA, Gruetzmacher P and Stroetmann VN. Improving quality of life for dialysis patients through telecare. J Telemed Telecare 2000 6(1) Excluded - does not address a key question
Sumner CR. Telepsychiatry: challenges in rural aging. J Rural Health. Fall. 2001;17(4):370-3. Excluded - contains no or inadequate data. [pmid: 12071564].
Tachakra S. Depth perception in telemedical consultations. Telemed J E Health. Summer. 2001;7(2):77-85. Excluded - does not address a key question. [pmid: 11421080].
Tachakra S, Dutton D, Newson R, et al. How do teleconsultations for remote trauma management change over a period of time? J Telemed Telecare2000 6(1) Excluded - contains no or inadequate data
Tachakra S, Jaye P, Bak J, et al. Supervising trauma life support by telemedicine. J Telemed Telecare 2000 6(1) Excluded - does not address a key question
Tachakra S, Loane M, Uche CU. A follow-up study of remote trauma teleconsultations. J Telemed Telecare. 2000;6(6):330-4. Excluded - no comparison group. [pmid: 11265101].
Tachakra S, Lynch M, Newson R, et al. A comparison of telemedicine with face-to-face consultations for trauma management. J Telemed Telecare 2000 6(1) Excluded - included in previous report
Taylor P. An assessment of the potential effect of a teledermatology system. J Telemed Telecare 2000 6(1) Excluded - contains no or inadequate data
Tennant MT, Greve MD, Rudnisky CJ, et al. Identification of diabetic retinopathy by stereoscopic digital imaging via tele-ophthalmology: a comparison to slide film. Can J Ophthalmol. Jun. 2001;36(4):187-96. Excluded - does not address a key question. [pmid: 11428527].
Theodoros D, Russell TG, Hill A, et al. Assessment of motor speech disorders online: a pilot study. J Telemed Telecare. 2003;9(Suppl 2):S66-8. Excluded - no comparison group. [pmid: 14728766].
Thorley PJ, Beacock DJ, Trickett CA, et al. 18FDG SPECT to assess myocardial viability: initial experience at a hospital remote from a cyclotron. Nuclear Medicine Communications. 2000;21(8):715-8. Excluded - does not address a key question. [pmid: 11039453].
Ting HH, Garratt KN, Singh M, et al. Low-risk percutaneous coronary interventions without on-site cardiac surgery: two years' observational experience and follow-up.[see comment]. American Heart Journal. Feb. 2003;145(2):278-84. Excluded - does not address a key question. [pmid: 12595845].
Tomuro K. Development of oral home telecare programme for the home-dwelling elderly: a pilot study. Gerodontology. Sep. 2004;21(3):177-80. Excluded - contains no or inadequate data. [pmid: 15369021].
Tsang MW, Mok M, Kam G, et al. Improvement in diabetes control with a monitoring system based on a hand-held, touch-screen electronic diary. J Telemed Telecare. 2001;7(1):47-50. Excluded - does not address a key question. [pmid: 11265938].
Tsilimigaki A, Maraka S, Tsekoura T, et al. Eighteen months' experience with remote diagnosis, management and education in congenital heart disease. J Telemed Telecare. 2001;7(4):239-43. Excluded - wrong population. [pmid: 11506760].
Tually P, Janssen J, Cowell S, et al. A preliminary assessment of Internet-based nuclear telecardiology to support the clinical management of cardiac disease in a remote community. J Telemed Telecare. 2003;9(Suppl 1):S69-71. Excluded - contains no or inadequate data. [pmid: 12952730].
Varri A, Koivuluoma M, Morvan C. A computer-assisted visual sleep scoring program. Studies in Health Technology & Informatics. 2000;78:285-97. Excluded - does not address a key question. [pmid: 11151600].
Wakefield BJ, Buresh KA, Flanagan JR, et al. Interactive video specialty consultations in long-term care. J Am Geriatr Soc. May. 2004;52(5):789-93. Excluded - no comparison group. [pmid: 15086663].
Wakefield BJ, Holman JE, Ray A, et al. Nurse and patient communication via low- and high-bandwidth home telecare systems. J Telemed Telecare. 2004;10(3):156-9. Excluded - does not address a key question. [pmid: 15165441].
Warden DL, Salazar AM, Martin EM, et al. A home program of rehabilitation for moderately severe traumatic brain injury patients. The DVHIP Study Group.[see comment]. J Head Trauma Rehabil. 1092;15(5):1092-102. Excluded - does not address a key question.
Watson J, Gasser L, Blignault I, et al. Taking telehealth to the bush: lessons from north Queensland. J Telemed Telecare. 2001;7(Suppl 2):20-3. Excluded - does not address a key question. [pmid: 11747649].
Whited JD. Teledermatology Current status and future directions. Am J Clin Dermatol. 2001;2(2):59-64. Excluded - does not address a key question. [pmid: 11705304].
Whitlock WL, Brown A, Moore K, et al. Telemedicine improved diabetic management. Mil Med. 2000;165(8):579-84. Excluded - does not address a key question. [pmid: 10957848].
Whitten P and Rowe-Adjibogoun J. Success and failure in a Michigan telepsychiatry programme. J Telemed Telecare 2002 8(Suppl 3):S3:75–7. Excluded - does not address a key question
Whitten PS. Teledermatology delivery modalities: real time versus store and forward. Aktuelle Probl Dermatol. 2003;32:24-31. Excluded - contains no or inadequate data.
Wiborg A, Widder B, Telemedicine in. Stroke in Swabia P. Teleneurology to improve stroke care in rural areas: The Telemedicine in Stroke in Swabia (TESS) Project.[see comment]. Stroke. Dec. 2003;34(12):2951-6. Excluded - contains no or inadequate data. [pmid: 14631092].
Wilson L, Onslow M, Lincoln M. Telehealth adaptation of the Lidcombe Program of Early Stuttering Intervention: five case studies. Am J Speech Lang Pathol. Feb. 2004;13(1):81-93. Excluded - wrong population. [pmid: 15101816].
Winters JM, Wang Y. Wearable sensors and telerehabilitation.[see comment]. IEEE Eng Med Biol Mag. May–Jun. 2003;22(3):56-65. Excluded - does not address a key question. [pmid: 12845820].
Wojcicki JM, Ladyzynski P, Krzymien J, et al. What we can really expect from telemedicine in intensive diabetes treatment: results from 3-year study on type 1 pregnant diabetic women. Diabetes Technol Ther. Winter. 2001;3(4):581-9. Excluded - wrong population. [pmid: 11911170].
Wootton R, Bloomer SE, Corbett R, et al. Multicentre randomised control trial comparing real time teledermatology with conventional outpatient dermatological care: societal cost-benefit analysis.[see comment]. Bmj. 1252;320(7244):1252-6. Excluded - does not address a key question.
Wootton R, McKelvey A, McNicholl B, et al. Transfer of telemedical support to Cornwall from a national telemedicine network during a solar eclipse. J Telemed Telecare 2000 6(1) Excluded - does not address a key question
Yogesan K, Cuypers M, Barry CJ, et al. Tele-ophthalmology screening for retinal and anterior segment diseases. J Telemed Telecare 2000 6(1) Excluded - included in previous report
Young NL, Barden W, Lefort S, et al. Telehomecare: a comparison of three Canadian models. Telemed J E Health. Spring. 2004;10(1):45-52. Excluded - contains no or inadequate data. [pmid: 15104915].
Young TL, Ireson C. Effectiveness of school-based telehealth care in urban and rural elementary schools. Pediatrics. Nov. 2003;112(5):1088-94. Excluded - wrong population. [pmid: 14595051].
Zabalgoitia M, Ismaeil M. Diagnostic and prognostic use of stress echo in acute coronary syndromes including emergency department imaging. Echocardiography. 2000;17(5):479-93. Excluded - does not address a key question. [pmid: 10979025].
Zaylor C, Nelson EL, Cook DJ. Clinical outcomes in a prison telepsychiatry clinic. J Telemed Telecare. 2001;7(Suppl 1):47-9. Excluded - wrong population. [pmid: 11576489].
Zenk BM, Bratton RL, Flipse TR, et al. Accuracy of detecting irregular cardiac rhythms via telemedicine. J Telemed Telecare. 2004;10(1):55-8. Excluded - no comparison group. [pmid: 15006218].
Zhang R, Yamauchi K, Nonogawa M, et al. A telemedicine system for collaborative work on radiographic coronary video-images. J Telemed Telecare. 2004;10(3):152-5. Excluded - contains no or inadequate data. [pmid: 15165440].