# Appendix C: Evidence Tables

Evidence Table 1. Studies of diagnosis and management for store-and-forward telemedicine

Source | Specialty | Purpose | Sample | Number of TM clinicians | Diagnosis or Management | Concordance | FTF v FTF concordance | Accuracy | Study class
Barnard, 2000 | Dermatology | Diagnostic agreement in all patients; accuracy of diagnosis in those with definitive diagnostic test | 50 cases, 25 confirmed by dx testing | 8 | Both | For 50 cases, 77% (range 67–84%) for primary dx and 90% (range 84–96%) for diff dx; decision to biopsy 40% for FTF vs. 45% for TM | No | For 25 cases, 84% FTF vs. 73% TM; for 8 cancers, 88% FTF vs. 90% TM | II-B
Coras, 2003 | Dermatology | Diagnostic agreement of teledermatoscopy | 100 cases of pigmented lesions using teledermatoscopy, 45% of which were biopsied | 3 | Diagnosis | | | For 45 cases, 91.1% FTF vs. 88.8% TM | I-B
DuMoulin, 2003 | Dermatology | Diagnostic agreement for TM | 106 cases referred by GP | 1 | Diagnosis | 54% full agreement, 9% partial agreement (diff dx), and 37% no agreement | No | | II-C
Eminovic, 2003 | Dermatology | Diagnostic agreement for patients seen via TM vs. FTF | 96 cases referred by GP | 12 | Diagnosis | 41% full agreement, 10% partial agreement (diff dx), and 49% no agreement | No | | II-C
Jolliffe, 2001, BJD | Dermatology | Decision by GP to triage pigmented lesions for TM assessment | 819 lesions assessed for referral | 5 | Management | For decision to refer, sens = 88% and spec = 66%; intraobserver kappa = 0.48 | No | | II-B
Jolliffe, 2001, CED | Dermatology | Comparison of pigmented lesions diagnosed by TM vs. FTF | 144 lesions assessed histologically | NS | Diagnosis | | | For 144 lesions, 43% FTF vs. 47% TM; no malignancies missed | I-B
Lim, 2001 | Dermatology | Diagnostic agreement for TM for primary and diff dx | 53 cases from 49 patients | 4 | Diagnosis | Self concordance vs. FTF 88%; concordance for 4 other derms 79% (range 73–85%) | No | | II-B
Oztas, 2003 | Dermatology | Diagnostic agreement for TM with pictures alone and clinical information added | 125 patients referred | 3 | Diagnosis | Agreement of TM was 55–58% without clinical information, 69–87% with clinical information | No | | II-B
Pak, 2003 (2 studies) | Dermatology | Intraobserver diagnostic agreement for TM | 404 patients referred | 1 | Both | Intraobserver (TM followed by FTF) agreement was 70% complete, 20.6% partial, and 9.4% none; for partial or no agreement, clinical significance was moderate 41.3% and severe 0.8%; biopsy rates false positive 17.1% and false negative 6.9% | No | | II-B
Piccolo, 2002 | Dermatology | Diagnostic agreement with teledermoscopy | 43 cases of pigmented lesions | 8 | Diagnosis | | | 91% FTF vs. 79–95% TM | II-B
Rashid, 2003 | Dermatology | Diagnostic agreement for TM | 26 skin conditions in 33 patients | 1 | Diagnosis | 81% agreement and 19% disagreement | No | | II-B
Shapiro, 2004 | Dermatology | Decision to perform a skin biopsy by FTF dermatologist | 49 patients with pigmented lesions | 1 | Management | 100% agreement on decision to biopsy | No | | II-B
Taylor, 2001 | Dermatology | Agreement for TM diagnosis and decision to make referral | 194 patients assessed 13 months after actual visit | 2 | Diagnosis | Agreement of TM was 77%; no difference between intra and interobserver | No | | II-B
Kim, 2000 | Gastroenterology | Accuracy of GI endoscopy transmitted by video | 5 patients for upper GI endoscopy, 5 patients for lower GI endoscopy - observed by TM | 1 | Diagnosis | 100% agreement on all diagnoses but G-E junction not seen clearly on 2 upper GI endoscopies | No | | II-B
Wildi, 2004 | Gastroenterology | Diagnostic quality of remote GI endoscopy | 50 patients undergoing GI endoscopy | 1 | Diagnosis | | | For major lesions, sens = 98%, spec = 80% | II-B
Etherington, 2002 | Gynecology | Diagnostic agreement in telecolposcopy | 81 women undergoing colopscopy | 1 | Diagnosis | For normal vs. abnormal, 91.4% agreement; for normal vs. low-grade CIN vs. high-grade CN, 79.0% agreement | No | | II-B
Ferris, 2002, OG | Gynecology | Diagnostic agreement in telecolposcopy | 186 women undergoing cervical biopsy after colposcopy (also interactive) | 2 | Both | Agreement for biopsy was 67.4% for site experts vs. interactive TM, 73.3% for local vs. site experts, 84.1% for local vs. interactive TM, and 72.6 for TM vs. S&F TM, comparable to decisions for endocervical curettage | Yes | Accuracy for local colposcopists 59.7%, local experts 52.7%, immediate TM 55.7%, later TM 49.7% | I-C
Ferris, 2002, JFP | Gynecology | Sensitivity of telecolposcopy and remote cervicography | 264 women undergoing cervical biopsy after colposcopy | 3 | Diagnosis | | | Accuracy with histology varied from 56.9% for local colopscopists to 52.4–55.5% for various types of TM | I-C
Baker, 2004 | Ophthalmology | Accuracy of different levels of JPEG compression for findings and management decisions in diabetic retinopathy (DR) | 20 diabetic patients with images compressed 55x and 113x | 1 | Diagnosis | Agreement varied for retinal abnormalities from kappa = 0.45–1.0, for level of retinopathy from 0.73–1.0, and for management recommendation follow-up from 0.64–1.0 | No | | II-B
Gomez-Ulla, 2002 | Ophthalmology | Agreement in detection and grading of DR | 126 eyes in 70 diabetic patients assessed for DR | 1 | Diagnosis | | | 100% accuracy on diagnosis of DR, 94% accuracy for class of DR | I-A
Saari, 2004 | Ophthalmology | Agreement in grading DR | 70 diabetic patients and controls assessed with various digital photography and handheld digital video (DV) camera | 3 | Diagnosis | | | Sens/spec best for red-free imaging (97.7%/98.9%), worst for DV (6.9%/50%) | I-A
Shiba, 2002 | Ophthalmology | Accuracy of fundus photography for DR | 61 diabetic patients assessed with digital photography for DR | 1 | Diagnosis | | | Sens/spec for best digital photography was 82.1%/100% | I-B
Yogesan, 2000 | Ophthalmology | Agreement in TM screening | 43 subjects assessed with digital indirect ophthalmoscope (DIO) and handheld fundus camera (HFC) vs. stereo fundus camera (gold standard) | 1 | Diagnosis | Correlation coefficient for DIO vs. gold standard was 0.80 and for HFC vs. gold standard was 0.76 | No | | II-B
Braun, 2005 | Wound Care | Wound assessment using new generation mobile telephone cameras | 61 wounds in 52 patients | 3 | Diagnosis | Agreement vs. FTF varied from kappa = 0.74–0.82 for TM physicians | No | | II-B
Gardner, 2001 | Wound Care | Accuracy of chronic wound assessments | 13 wound observations | 1 | Diagnosis | Agreement on 8 characteristics was 75–100% but only 54% on presence of epithelial tissue | No | | II-B
Halstead, 2003 | Wound Care | Management decisions in wound care for 4 yes/no decisions | 17 individuals with 20 wounds | 1 | Management | Agreement on management decisions averaged 89% | No | | II-B
Houghton, 2000 | Wound Care | Correlation of wounds assessed by pressure sore status tool (PSST) and photographs | Assessment of photographic wound assessment tool (PWAT) in 137 skin ulcers | 3 | Diagnosis | Intra-rater correlation on PWAT score was 96% and interrater correlation was 73% | No | | II-B
Jones, 2003 | Wound Care | Reliability of images to assess burn wounds | 60 burn wounds assessed with different resolution digital photographs | 1 | Diagnosis | Intraobserver kappa was 0.53–0.60 | No | | II-B
Jones, 2004 | Wound Care | Agreement of injury severity and operative priority in minor injuries requiring plastic surgery consultation | 82 trauma referrals | 3 | Both | Correlation for grade of injury 0.78–0.81 and for operative priority 0.87–0.93 | No | (Correlation on categorical data!) | II-B
Kim, 2003 | Wound Care | Accuracy of chronic wound assessments | 430 visits on 70 patients | NS | Diagnosis | Agreement for not healing was 67.1%, necrosis 77.0%, cellulitis 88.8%, osteomyelitis 72.5%, and not closed 96.7% | No | | II-B

Evidence Table 2. Studies of access for store-and-forward telemedicine

Source | Purpose/Design | Intervention | Control | Measure of access | Population/sample | Results | Limitations | Study class
Whited, 2002 | Evaluate system for screening dermatology referrals in a VA medical center | Digital image of skin lesion and standardized patient history | Text-based referral request | Time (in days) to definitive evaluation of skin problem | Primary care adult patients; mean age 61.3 years | Median time was 41 days in teledermatology group and 127 days in control group. 18.5% of teledermatology patients had definitive evaluation made by teledermatology. | Dermatology clinic had a substantial appointment backlog that likely exaggerated the difference between groups. | I-B
| Randomized trial of consecutive routine patient referrals | | | | N = 275
Mallett, 2003 | Evaluate teledermatology system for referrals from general practitioners | Referral letter and digital photographs submitted by electronic mail | None | Rate of subsequent face-to-face visits at dermatology clinic | Patients seen in offices of general practitioners in UK; age range 4 months to 94 years | A telediagnosis (based on the photographs and letter) in 48% of cases. Face-to-face appointments were made for 92% of patients, and 66% of patients were seen face-to-face. Of 99 patients for whom a telediagnosis was made, the face-to-face diagnosis was the same for 95%. | Face-to-face diagnosis was not blinded to telediagnosis. | III-C
| Prospective case series of referrals to a community dermatology clinic | | | | N = 325
Lee, 2003 | Evaluate system for prescreening patients for surgery by a mobile surgical team | Patient history, description of physical examination, laboratory results, and digital photographs submitted to consultant surgeons in USA by electronic mail | None | Consulting surgeons’ judgment of appropriateness of surgical therapy and actual completion of surgery by mobile surgical team | Adult patients referred for consideration of surgical therapy by local providers in Kenya | 35% of referred cases were judged appropriate for surgery; all of these patients underwent the planned surgery | Cases judged not to be surgical candidates by the electronic mail review were not re-evaluated face-to-face | III-B
| Case series | | | | N= 44
Jaatinen, 2002 | Compare results of specialty consultations conducted by electronic mail between physicians or by conventional visits in specialty clinics | Textual information provided by general practitioner using a web site. Consultant could ask for further information by electronic mail sent to the general practitioner | Appointment in specialty clinic | Location of further care provided after the consultation (local clinic vs. specialty clinic) | Adult patients (mean age 62 years) seen by general practitioners in single Finnish community; specialists located 15–95 km away | In both the telemedicine and conventional groups, 25% of patients received follow-up care in local community. | General practitioners could choose not to randomize patients if they preferred a face-to-face visit. | II-B
| Prospective randomized trial | | | | N = 72
Tennant, 2000 | Evaluate system for screening patients for diabetic retinopathy | Stereoscopic digital retinal photographs of dilated eyes were obtained by a local ophthalmic photographer. Satellite link used to transmit images to urban center to undergo review by retinal specialist | None | Follow-up care of screened patients | Patients with diabetes identified by general practitioners in remote Canadian community; mean age 55.4 years | 10% of patients were referred for laser photocoagulation | No information on prevalence of diabetes in the community or previous rates of screening | III-B
| Case series | | | | N = 100

Evidence Table 3. Studies of diagnosis and management for home-based telemedicine

Source | Domain | Purpose | Sample | Number of TM clinicians | Diagnosis or management | Concordance | FTF v FTF concordance | Accuracy | Study class
Jenkins, 2001 | Congestive heart failure (CHF) | Agreement in findings of CHF patients by home health nurses | 28 home care patients with CHF | 1 | Diagnosis | Of 18 items assessed, TM more likely to claim nail color abnormality and real-time nurse more likely to detect inspiratory wheeze, ankle edema, and pedal edema | No | | II-C
Morlion, 2002 | Pulmonary function testing (PFT) | Agreement between home and hospital spirometry after lung transplant | PFTs in 22 patients followed for an average of over 1 year | 0 | Diagnosis | | | Sens/positive predictive value for “alarm” episodes were 63%/39% | II-C

Evidence Table 4. Studies of health outcomes for home-based telemedicine

Source | Domain | Question | Study type | Control | Sample | Results | Limitations | Class
Artinian, 2003 | CHF | Does the medication compliance device Med-eMonitor monitoring improve care? | RCT | 9 patients with usual care | 9 patients with usual care plus compliance device and web-based monitoring | No change in behaviors, walking endurance, or functional class; improvement in quality of life for monitored group. | Small sample size, short (3-month) follow-up. | II-B
Benatar, 2003 | CHF | Does nurse telemanagement by advanced practice nurse and vital sign monitoring improve outcomes? | RCT | 108 patients with nurse home visit | 108 patients with transtelephonic home monitoring | Lower rate of hospital readmission and anxiety/depression; same Minnesota Living with Heart Failure Questionnaire and self-efficacy. | | I-A
de Lusignan, 2001 | CHF | Does home monitoring of vital signs and video consulting improve care? | RCT | 10 patients with usual care | 10 patients with home telemonitoring | Comparable weight, blood pressure, and quality of life. | Small sample size. | II-B
Jerant, 2001 | CHF | Does home videoconferencing plus electronic auscultation improve care? | RCT | 12 patients in usual care | 13 patients with telenursing care, 12 with usual plus telephone care | Both telephone and telecare had fewer emergency department visits and trends to fewer hospitalizations. | Usual plus telephone care of equal efficacy. | I-B
LaFramboise, 2003 | CHF | Does HealthBuddy telecommunication device improve care? | RCT | 23 patients with home visit, 26 with telephonic | 21 patients with Health Buddy, 20 with HB+home visit | All groups improved self-efficacy and symptoms over time but no difference between modalities. | Limited follow-up. | II-B
Roth, 2004 | CHF | Does home monitoring of vital signs improve care? | Pre-post | 118 patients before intervention | Same 118 patients after invention | Reduction in hospital days by two-thirds; near significant improvement in quality of life | Pre-post design means factors other than telemedicine could have influenced outcome | II-B
Chumbler, 2004 | Chronic disease in elderly | Does HealthBuddy, monitoring of vital signs, and videoconferencing improve cognitive and other function? | Prospective case control | 115 case-matched veterans referred from senior agencies or rehabilitation programs | 111 veterans enrolled in home telemonitoring project | Improvements in instrumental activities of daily living and functional independence measurement scales. | No randomization, groups may have differences. | II-B
Kobb, 2003 | Chronic disease in elderly | Does HealthBuddy, monitoring of vital signs, and videoconferencing improve cognitive and other function? | Cohort | 1120 patients receiving usual care | 281 patients receiving remote home care | Remote monitoring group had reduced hospital and nursing home admissions, ER and clinic visits. | No randomization, groups may have differences. | II-B
Noel, 2004 | Chronic disease in elderly | Does monitoring of vital signs directly into EHR improve quality of life and cognitive function? | RCT | 57 veterans | 47 veterans | Statistically significant reduction in bed days of care, urgent visits, HgbA1c, OARS cognitive status and functional level. | Many other measures showed no difference. | I-A
Ades, 2000 | Coronary artery disease | Does EKG and transtelephonic monitoring provide comparable outcomes for at-home cardiac rehabilitation? | Cohort | 50 patients receiving usual care | 83 patients | Exercise capacity, quality of life, and complications (none) comparable in both groups | No randomization, groups may have differences. | II-B
Barnarson, 2003 | Coronary artery disease | Does HealthyBuddy monitoring improve care? | RCT | 18 patients with Health Buddy asking series of questions | 17 patients with routine care | Communication intervention group had higher self-efficacy, comparable risk factor adherence, and better functional outcomes per SF-36. | Relatively small sample size. | I-A
Bellazzi, 2003 | DM | Does home glucose monitoring and videoconferencing improve outcomes? | Cohort | 67 users of diabetes telemedicine system | 62 non-users of system | HgbA1C differences not significant but less variance in experimental group. | No randomization, groups may have differences. | II-B
Biermann, 2002 | DM | Does home glucose monitoring improve outcomes? | RCT | 16 patients with conventional care | 27 patients with home glucose monitoring | Both groups had comparable drops in HgbA1C levels. | Small sample size, unexplained uneven distribution into groups. | II-B
Izquierdo, 2003 | DM | Does diabetes education delivered by telemedicine improve outcomes? | RCT | 22 patients with education delivered in-person | 24 patients with education delivered via telemedicine | No change in HgbA1C or behavior goals between groups. | | I-B
Welch, 2003 | DM | Does home glucose monitoring improve outcomes? | RCT | 26 patients who used modem-equipped glucometers | 26 patients who received usual care | Slightly larger drop in HgbA1C for experimental group but not significant | Results obtained from Montori paper, over half of subjects lost to follow-up at 12 months | II-B
Montori, 2004 | DM | Does home glucose monitoring with feedback improve outcomes? | RCT | 16 patients with glucometer transmission plus nurse feedback | 15 patients with glucometer transmission but no feedback | Statistically significant reduction in HgbA1C (8.2 vs. 7.8%), 50 more minutes per patient in phone time for experimental group | | I-A
Artinian, 2001 | Hypertension | Does home monitoring and community-based monitoring of blood pressure improve care? | RCT | 9 patients with usual care | 6 patients with home telemonitoring and 6 with community-based monitoring | Drop in BP for both experimental groups statistically significant over control group. | Small sample size, short (3-month) follow-up. | II-B
Bondmass, 2000 | Hypertension | Does home monitoring of blood pressure improve care? | Pre-post | 33 patients with uncontrolled hypertension >1 year | Same 33 patients after invention | Statistically significant reduction in blood pressure from average of 154/90 to 141/83 | Pre-post design means factors other than telemedicine could have influenced outcome | II-B
Rogers, 2001 | Hypertension | Does home monitoring of blood pressure improve care? | RCT | 55 patients with usual care | 56 patients with home telemonitoring | Better improvement in mean, systolic, and diastolic pressure (mmHg) for home telemedicine (-2.8, -4.9, -2.0) vs. control (+1.3, -0.1, +2.1). | Clinical significance of improvements in blood pressure not clear. | I-A
Mullan, 2003 | Lung transplantation | Does monitoring by home electronic symptom diary improve outcomes in patients awaiting lung transplant? | RCT | 52 patients with telephone reporting | 67 patients uploading electronic diary | Adherence, length of stay in hospital after transplant, and survival after transplant identical. | Few clinical parameters assessed. | II-B
Egner, 2003 | Multiple sclerosis | Does telerehabilitation program delivered via video or phone improve care? | RCT (subgroup analysis) | 7 patients with in-person and 11 patients with phone rehabilitation | 9 patients with video rehabilitation | Generally equivalent scores over two years on quality of well-being (QWB) scale, Center for Epidemiologic Studies Depression (CES-D) scale, and Fatigue Severity Scale (FSS). | Subgroup analysis of larger RCT, small sample size. | II-B
Phillips, 2001 | Newly injured spinal cord patients | Does video-based rehabilitation improve care? | RCT | 39 patients with standard intervention, 36 with telephone intervention | 36 patients with video intervention | Video intervention group had significantly higher Quality of Well-Being scale at one year and reduced annual hospital days | | I-A
Harvey-Berino, 2002 | Obesity | Does therapist-led Internet support group lead to better weight loss? | RCT | 15 patients in control group, 14 patients in therapist-led in-person group | 15 patients in therapist-led Internet group | Amount of weight loss comparable in all groups. | Small sample size. | II-B
D'Souza, 2002 | Psychiatry | Does a psycho-educational program by videoconference after inpatient discharge improve care? | Cohort | 27 patients discharged to conventional care | 24 patients discharged to care plus program | Telemedicine patients had higher adherence, lower readmission, and lower medication side effects. | No randomization, groups may have differences. | II-B
Maiolo, 2003 | Pulmonary Disease | Does home monitoring of pulmonary status of pulmonary status improve care? | Pre-post | 23 patients with home monitoring of pulmonary function | Same patients after intervention | Statistically significant reduction in hospital admissions (2.0 vs. 1.0) and acute exacerbations (1.4 vs. 0.63) | Pre-post design means factors other than telemedicine could have influenced outcome | II-B

Evidence Table 5. Studies of diagnosis and management for office/hospital-based telemedicine

Source | Specialty | Purpose | Sample | Number of TM clinicians | Diagnosis or management | Concordance | FTF v FTF concordance | Accuracy | Study class
Scalvini, 2002 | Cardiology | Remote diagnosis of chest pain by GP | 952 ECG diagnoses made by TM | NS | Diagnosis | | | Sens/spec of service was 97.4%/89.5% | I-B
Terkelsen, 2002 | Cardiology | Prehospital diagnosis in ambulances | 250 patients for prehospital diagnosis of acute MI | NS | Diagnosis | | | Sens/PPV for acute MI was 88%/56% | I-B
Nordal, 2001 | Dermatology | Agreement in diagnosis via videoconference | 121 patients referred to dermatologist | 2 | Diagnosis | Agreement was 72% complete and 14% partial | No | | II-B
Craig, 2000, EJN | Neurology | Agreement of neurologic inpatient assessment | 25 neurology inpatients | 1 | Diagnosis | | | 23 of 25 diagnoses correct by interactive videoconferencing | II-B
Craig, 2000, JTT | Neurology | Agreement of neurologic outpatient assessment | 25 neurology outpatients | 1 | Diagnosis | | | 24 or 25 diagnoses correct by interactive videoconferencing | II-B
Handschu, 2003 | Neurology | Agreement of stroke assessment via NIH Stroke Scale (NIHSS) | 41 patients receiving NIH Stroke Scale (NIHSS) in setting of acute stroke | NS | Diagnosis | Agreement on 13 elements varied from 0.44–0.89 on unweighted kappa and from 0.85–0.99 when weighted per accepted protocol | No | | II-B
Wang, 2003 | Neurology | Accuracy of stroke assessment using NIH Stroke Scale (NIHSS) | 20 patients receiving NIHSS in setting of acute stroke | 4 | Diagnosis | Correlation of score for TM vs. FTF was 0.96 | No | | II-B
Bowman, 2003 | Ophthalmology | Accuracy of eye injury assessment | 80 patients with eye injury (40 each for TM vs. FTF and FTF vs. FTF | 2 | Diagnosis | For TM vs. FTF, agreement was complete 58%, partial 37%, and not 5%. For FTF vs. FTF, agreement was complete 75%, partial 20%, and not 5%. Agreement better when slit lamp vs. ophthalmoscope used. | Yes | | I-B
Crowston, 2004 | Ophthalmology | Measurements in trabeculectomized eyes using telemedicine vs. in-person | 40 trabeculectomized eyes in 40 patients | 3 | Diagnosis | For 6 measures, agreement always higher in FTF vs. FTF than TM vs. FTF | Yes | | I-C
Dawson, 2002 | Ophthalmology | Assessment of strabismus | 30 patients with strabismus | 2 | Diagnosis | Agreement was complete 80%, partial 3%, and incomplete 17% | No | | II-B
Rayner, 2001 | Ophthalmology | Agreement of ophthalmic adnexal exam | 17 patients with adnexal (eye) conditions | 2 | Both | 58% had full agreement, 24% had diagnostic agreement but management disagreement, and 18% had incorrect TM diagnosis | No | | II-C
Smith, 2003 | Ophthalmology | Slit lamp assessment via telemedicine | 12 cataract and 10 control patients | 2 | Both | Agreement was 70–100% for control patients and 0–100% for cataract patients | No | | II-C
Givens, 2003 | Otolaryngology | Agreement in audiometry testing | 45 patients assessed with conventional and TM audiometer for air conduction, 25 of whom were also assessed for bone conduction | NA | Diagnosis | Correlation was 0.71–0.89 for different frequencies in air conduction, 0.79–0.94 for bone conduction | NA | | I-B
Ullah, 2002 | Otolaryngology | Accuracy of otolarynology consultation | Intraobserver concordance for assessment of 42 patients | 1 | Diagnosis | | | For first 20 patients, diagnosis incorrect in 8; for next 22 patients, all diagnoses correct | II-B
Menon, 2001 | Psychiatry | Psych assessment of depression and cognitive status using videophone | Administration of GDS, HAM-D, and SPMSE to 24 elderly patients | 2 | Diagnosis | Coefficient of variation for GDS was 20.7% FTF/27.9% TM (NS), for HAM-D was 27.7% FTF/30.8% TM (NS), and for SPMSE was 63.3% FTF/31.6% TM (p=.02) | No | | II-B
Shores, 2004 | Psychiatry | Neuropsychiatric evaluation via telemedicine | 16 patients screening positive for dementia on 7-minute screen | NS | Diagnosis | 100% agreement on presence of dementia (in 12 patients) | No | | II-B
Yoshino, 2001 | Psychiatry | Agreement in Brief Psychiatric Rating Scale administration | 42 patients with chronic schizophrenia interviewed by FTF and viewed by narrowband and broadband | NS | Diagnosis | Agreement was 87% FTF vs. FTF, 88% FTF vs. broadband TM, 44% FTF vs. narrowband TM (p<.05) | Yes | | I-A
Leggett, 2001 | Rheumatology | Accuracy of rheumatology consultation | 100 patients referred to a rheumatologist | 1 | Diagnosis | | | Accuracy of diagnosis was 97% for TM, 71% for telephone | I-B
Endean, 2001 | Vascular Surgery | Agreement of treatment recommendations for vascular surgery patients seen via telemedicine | 64 vascular abnormalities in 32 patients | 1 | Management | Agreement with treatment recommendations was 91% | No | | II-B

Evidence Table 6. Studies of health outcomes for office/hospital-based telemedicine

Source | Specialty | Question | Study type | Control | Sample | Results | Limitations | Study Class
Breslow, 2004 | Critical Care | Does supplemental remote ICU monitoring improve outcomes of care? | Pre-post | 1396 patients before telemedicine intervention | 744 patients after intervention | Telemedicine reduced mortality (RR=0.73), length of stay (3.63 days vs. 4.35 days), and variables costs per case | Pre-post design means factors other than telemedicine could have influenced outcome | II-B
Chua, 2001 | Neurology | Are new neurological referrals as effective via telemedicine as in-person as measured by number of tests, prescriptions, and disposition? | RCT | Rate of agreement of telemedicine vs. in-person | 76 patients evaluated by telemedicine, 65 patients evaluated by in-person care | In-person patients had fewer neuro (6/82 vs. 26/86) and non-neuro (5/82 vs. 20/86) tests but same amount of prescriptions and discharge after first consultation. | Focus mainly on process and not clinical outcomes. | II-C
Russell, 2003 | Orthopedics | Does telerehabilitation for total knee replacement have comparable outcomes? | RCT | 11 patients randomized to conventional care | 10 patients who had weekly treatment for 6 weeks | No difference in physical or functional measurements. | Small sample, short follow-up. | II-B
Vuolio, 2003 | Orthopedics | Is video-conferencing aided by GP and nurse as effective as traditional clinic? | RCT | 69 patients seen in outpatient clinic | 76 patients seen in health center by videoconference | Equal fulfillment of patient management plans. | Focus mainly on process and not clinical outcomes. | II-B
Mashima, 2003 | Otolarngology | Can voice therapy be delivered as effectively by telemedicine as in person? | RCT | 28 patients with conventional voice therapy | 23 patients with videoconference voice therapy | Both groups improved, with no differences between them. | | I-A
Bouchard, 2004 | Psychiatry | Can cognitive-behavior therapy for panic disorder be delivered via telemedicine? | Cohort | 11 patients with video-conferencing | 10 patients with face to face care | Both groups had comparable improvement in reduction in panic attacks and scores on Beck Depression Inventory. | Small sample, no randomization. | II-B
Kennedy, 2003 | Psychiatry | Do patients using telepsychiatry have comparable health outcomes to in-person care? | Cohort | 92 patients who did not have telepsychiatry | 32 patients who had telepsychiatry | No difference in Health of the Nation Outcome Scale or Mental Health Inventory. | No randomization, likely differences between experimental and control groups. | II-B
Ruskin, 2004 | Psychiatry | Is telepsychiatry treatment (medications, education, brief supportive counseling) comparable to face to face treatment? | RCT | 60 patients treated with face to face treatment | 59 patients treated with telepsychiatry | Equal outcomes in both groups for Hamiltion Depression Rating Scale and Beck Depression Inventory. | | I-A
Wilbright, 2004 | Wound Care | Is telemedicine treatment comparable to in-person treatment? | Cohort | 120 patients treated conventionally | 20 patients treated via interactive telemedicine | No differences in healing time or percent healed | No randomization, likely differences between experimental and control groups. | II-B

Evidence Table 7. Studies of access for office/hospital-based telemedicine

Source | Purpose/Design | Intervention | Control | Measure of access | Population/sample | Results | Limitations | Study class
LaMonte, 2003 | Evaluate system for screening patients with symptoms of stroke seen in emergency department 100 miles from stroke treatment center | 2-way audio-video link; consultant neurologist interviews and examines stroke patient by telemedicine. | Telephone discussion between emergency department physician and consultant neurologist. | Percentage of patients receiving fibrinolytic therapy for acute stroke | Patients presenting to hospital emergency department; no demographic data reported. | 22% of 23 telemedicine patients received fibrinolytic therapy, compared to 4% of 27 traditional consultations | An undetermined number of the control group patients were ineligible for fibrinolytic therapy. | III-B
| Comparison of telemedicine cases to concurrent cases managed by telephone consultation | | | | N=50
Woods, 2000 | Evaluate system for providing follow-up care to patients with sickle cell anemia living more than 100 miles from university clinic | 2-way audio-video link; consultant at university clinic interviews patient; on-site nurse assists with physical examination. | Rural outreach clinics; consultant travels to clinic for face-to-face patient encounters. | Annual number of patient encounters at rural sites | Adult patients with sickle cell anemia; 84% Medicaid insurance | 271 annual clinic visits in pre-telemedicine period (1996); 745 clinic visits in post-telemedicine period (1999) | Outreach clinics continued during telemedicine period. Of the 745 visits in 1999, 466 were by telemedicine and 279 were conventional outreach clinic visits. An additional staff member (physician assistant) was added in 1999. | II-B
| Before/after study of clinic workload | | | | N=128 in post-telemedicine period
Haukipuro, 2000 | Evaluate satisfaction with a system for routine orthopedic clinic visits | 2-way audio-video link; orthopedic specialist at university clinic interviews patient; primary care physician assists with physical examination at remote site. | Patient travels to university clinic for face-to-face encounter | Overall satisfaction of clinical quality of examination by orthopedic specialist | Orthopedic patients; mean age 56.7 years. | Overall satisfaction rated as very good or good in 80% or telemedicine encounters and 89% of conventional encounters | No measures of clinical outcomes | II-B
| Randomized trial of patients referred to a university orthopedic clinic in Finland | | | | N = 145
Vuolio, 2003 | Evaluate treatment plans of newly referred orthopedic patients examined via a telemedicine system | 2-way audio-video link; orthopedic specialist at university clinic interviews patient; primary care physician assists with physical examination at remote site. | Patient travels to university clinic for face-to-face encounter | Classification of management plans formulated by physician conducting the patient evaluation. | Orthopedic patients; mean age 56.7 years (same study subjects as reported in Haukipuro 2000) | Management plans (including rates of planned surgical procedures) were similar in the two groups. | No measures of actual clinical outcomes | I-B
| Randomized trial of patients referred to a university orthopedic clinic in Finland. | | | | N = 145
Wallace, 2002 | Measure whether a telemedicine system to conduct initial specialist evaluations reduces rates of diagnostic test utilization and subsequent face-to-face encounters | 2-way audio-video link; both general practitioner and specialist participate in teleconference with patient. | Face-to-face encounter between patient and specialist | Orders for follow-up face-to-face appointments and diagnostic tests | Patients seen in offices of general practitioners in UK; mean age 48 years | 52% of telemedicine patients and 41% of control group patients were offered follow-up appointments. Follow-up appointment rates were higher for surgical specialty consultations that for medical specialty consultations. Telemedicine patients had fewer tests ordered. | No measures of actual clinical outcomes | I-C
| Randomized trial of patients referred by general practitioners to specialists in London, UK | | | | N = 1939
Leggett, 2001 | Compare telephone-based consultation to video-based methods for providing rheumatologic consultations | Patient interview by rheumatologist using desktop videoconferencing system | Telephone conversation between general practitioner and rheumatologist | Physician opinion of need to see patient face-to-face following teleconsultation | Convenience sample of patients referred to a rheumatologist; mean age 48 years | Rheumatologist judged that 75% of patients needed to be seen following the telephone consultation but only 6% following the videoconference. | Only one rheumatologist studied; telephone and videoconference sessions were not blinded. | III-B
| Comparison of successive telephone and video-based consultations on same patients | | | | N = 100
Kennedy, 2003 | Compare psychiatric consultations delivered by videoconferencing to care of similar patients delivered face-to-face | Interview conducted by video- conferencing equipment | Conventional evaluations in psychiatry clinic | Mental health scales completed by clinician and patient at baseline and 12 months after initial evaluation | Australian adults referred by general practitioner for psychiatric consultation | Mean scores of the mental health scales improved over 12 months. No difference between groups in the mean size of the change scores. | Telepsychiatry patients had a higher rate of anxiety disorders, and conventional care patients had a higher rate of psychotic disorders. | II-B
| Non-randomized prospective control-group design | | | | N = 124
Chua, 2002 | Compare management plans of patients undergoing neurologic evaluation by teleconference or by face-to-face evaluation | Consulting neurologist interviewed patient and reviewed radiologic images placed on view box at telemedicine site. Physical examination conducted by assistant at the telemedicine site. | Conventional clinic visits staffed by neurologists or general practitioners | Percentage of patients receiving appointments for further testing or follow-up appointments | Adult patients presenting to general practitioners with neurologic complaints (mean age 34.8 years) | In the randomized trial, neurologists seeing patients face-to-face ordered tests for significantly fewer patients and showed no difference in the rate of follow-up appointments, when compared to the teleconsultation group. The non-randomized patients seen face-to-face by neurologists had similar rates of tests and follow-up appointments as the teleconsultation patients. The non-randomized patients seen face-to-face by general practitioners had significantly higher rates of tests and follow-up appointments when com-pared to the teleconsultation patients. | Comparability of patients seen by general practitioners is not well described. | II-C
| Prospective randomized trial of newly referred patients. Additional non-randomized comparison of 4 other patient cohorts. | | | | Randomized trial: N = 141; additional comparison groups: N = 252
Taylor, 2003 | Evaluate teleconsultation of South African patients having eye disease by British ophthalmologists | Local clinicians used a video slit lamp and presented case information by videoconferencing equipment | None | Judgment of consensus panel of ophthalmologists who conducted retrospective case reviews | Patients seen in eye department of single South African hospital. Average age = 26 years (range 2–70) | Teleconsultation judged to have definite effect on diagnosis in 24% and possible effect in 22%. Teleconsultation judged to have definitely improved visual health in 10% and possibly improved visual health in 53% of cases. | Limited follow-up information on cases | III-B
| Case series | | | | N = 90