# Appendix A: Exact Search Strings

Database: Ovid MEDLINE(R) Version: re l9.2.0

1 exp TELEMEDICINE
2 telemedicine.mp.
3 telehealth.mp.
4 remote consultation$.mp.
5 1 or 2 or 3 or 4
6 exp Home Care Services
7 Home Nursing
8 6 or 7
9 exp Therapy, Computer-Assisted
10 exp COMPUTERS
11 exp Computer Communication Networks
12 exp Medical Informatics
13 exp TELECOMMUNICATIONS
14 exp Monitoring, Physiologic
15 monitor$.mp.
16 blood glucose self-monitoring
17 Self-Examination
18 self exam$.mp.
19 self monitor$.mp.
20 self test$.mp.
21 14 or 15 or 16 or 17 or 18 or 19 or 20
22 tele$.mp.
23 (remote or offsite or distance).mp.
24 Rural Population
25 Rural Health Services
26 HOSPITALS, RURAL
27 rural.mp.
28 22 or 23 or 24 or 25 or 26 or 27
29 21 and 28
30 9 or 10 or 11 or 12 or 13 or 29
31 8 and 30
32 31 not 5
33 limit 32 to english language
34 32 not 33
35 limit 34 to abstracts
36 33 or 35
37 5 or 36
38 limit 37 to yr=2000-2004
39 exp Computer Communication Networks
40 Patient Participation
41 exp Consumer Satisfaction
42 “Delivery of Health Care”
43 exp Home Care Services
44 exp Home Nursing
45 house calls/ or house call$.mp. or housecall$.mp.
46 40 or 41 or 42 or 43 or 44 or 45
47 39 and 46
48 limit 47 to english language
49 limit 48 to yr=2000-2004
50 38 or 49