# Appendixes

Appendix A: Exact Search Strings

Appendix B: Sample Data Abstraction Forms

Appendix C: Evidence Tables

Appendix D: Listing of Excluded Studies

Appendix E: Peer Reviewers