# List of Acronyms/Abbreviations

2D | Two-dimensional
3D | Three-dimensional
ACOG | American College of Obstetricians and Gynecologists
ACR | American College of Radiology
AFP | Alpha-fetoprotein
AHRQ | Agency for Healthcare Research and Quality
AUC | Area under the curve
CA-125 | Cancer antigen 125
CDC | Centers for Disease Control and Prevention
CEA | Carcinoembryonic antigen
CI | Confidence interval
CMS | Centers for Medicaid and Medicare Services
CT | Computed tomography
FDG | 18-Fluorodeoxyglucose
FIGO | International Federation of Gynecology and Obstetrics
FNA | Fine needle aspiration
hCG | Human chorionic gonadotropin
ICD-9 | International Classification of Diseases, Ninth Revision
LDH | Lactate dehydrogenase
LMP | Low malignant potential
MeSH | Medical Subject Heading
MRI | Magnetic resonance imaging
NIS | Nationwide Inpatient Sample
NPV | Negative predictive value
PET | Positron emission tomography
PI | Pulsatility index
PPV | Positive predictive value
RI | Resistance index
RMI | Risk of Malignancy Index
ROC | Receiver operating characteristic
SEER | Surveillance, Epidemiology, and End Results
SGO | Society of Gynecologic Oncologists
TAG-72 | Tumor-associated glycoprotein 72
TVUS | Transvaginal ultrasound