# Executive Summary

## Introduction

Ovarian cancer is the leading cause of cancer death from gynecologic malignancies in the United States, with an annual incidence of over 25,000 and an annual mortality of approximately 14,000. Cancer incidence increases dramatically with age.

The high case-fatality rate has largely been attributed to the fact that most ovarian cancers are diagnosed in advanced stages (Stage III, where the cancer has spread beyond the pelvis to organs of the upper abdominal cavity, and Stage IV, where the cancer has spread outside of the peritoneal cavity), when survival is poor. Stage I cancer (limited to the ovaries) has a survival rate of over 90 percent. Thus, there has long been an emphasis on early detection of ovarian cancer in the belief that detection in early stages will lead to decreases in morbidity and mortality. The detection of a mass in the area of the ovaries and fallopian tubes (the uterine adnexae) raises the possibility of ovarian cancer, which necessitates further study to rule out malignancy.

There are two main clinical routes by which an adnexal mass may be detected: (1) women with symptoms may have an adnexal mass detected as part of their evaluation for those symptoms, either by physical exam or radiographic imaging; (2) the mass may be detected during bimanual pelvic examination or radiologic imaging as part of a routine health maintenance examination.

For the purposes of this evidence report, we define an adnexal mass as an enlarged structure in the uterine adnexa that can either be palpated on a bimanual pelvic examination or visualized using radiographic imaging.

There are a number of conditions that can be associated with an adnexal mass. These include malignancies arising from the ovary and fallopian tube, or metastatic disease from another site (such as the breast or gastrointestinal tract), as well as a wide range of benign conditions. For the purposes of this evidence report, “management” of the adnexal mass refers to the process by which a mass is ultimately classified as benign or malignant.

The clinical significance of discriminating benign from malignant masses differs depending on the clinical setting in which the mass is initially detected. For women with symptoms, in whom surgical management may be appropriate whether or not the mass is malignant, the main reason to discriminate between benign and malignant lesions is to facilitate referral and management by clinicians who have specialized training and experience in managing ovarian malignancy, with improved outcomes. For asymptomatic women, discriminating benign from malignant disease is important both to ensure appropriate management in the setting of malignancy, but also to avoid unnecessary diagnostic procedures, including surgery, in women with asymptomatic, nonmalignant conditions.

The prevalence of malignancy may differ between women with symptomatic and asymptomatic masses, which may in turn affect the positive and negative predictive value of a test, and, potentially, sensitivity and specificity as well. Prevalence also varies with age and with family history.

This report focuses on the evidence relevant to establishing the most appropriate way to distinguish benign from malignant adnexal masses in both symptomatic and asymptomatic women. A key consideration throughout the report will be the underlying likelihood of malignancy in the populations studied, and the impact of this prevalence on the interpretation of the results of the reviewed studies. The results of this report are intended primarily to (a) provide a resource for clinicians and policymakers developing guidelines on management of adnexal masses, and (b) provide a resource for researchers and funding agencies in identifying gaps in our knowledge and research priorities.

## Methods

Working with the Agency for Healthcare Research and Quality (AHRQ), the Centers for Disease Control and Prevention (CDC), and members of the technical expert panel, we developed seven questions to be addressed, using an analytic framework which incorporated prior probability of disease, test results, and outcomes of diagnostic surgery.

We searched MEDLINE^®^ (1966-September 2004) and the Cochrane Database of Systematic Reviews. Searches of these databases were supplemented by reviews of reference lists contained in all included articles and in relevant review articles and meta-analyses. The searches yielded a total of 1,023 citations. Pairs of readers reviewed each abstract and selected 445 articles for full text review. Specific inclusion criteria were developed for each question, and both readers were required to agree on inclusion.

We developed tables to abstract each article, and quality criteria for each question. For studies of diagnostic tests, 2-by-2 tables were constructed for each included article, and sensitivity, specificity, and positive and negative predictive values, with 95 percent confidence intervals (CIs) for each, were calculated. If not provided, we also calculated 95% CIs for articles about prevalence and adverse event rates during diagnostic surgery. For diagnostic tests, pooled estimates of sensitivity and specificity were calculated using a random-effects model.

We performed three supplemental analyses. First, we used the Nationwide Inpatient Sample (NIS), a nationally representative database containing discharge data from approximately 20 percent of U.S. hospitals. Using International Classification of Diseases, Ninth Revision (ICD-9) codes and the provided corrections for sample weighting, we estimated the number of cases of women 15 and older undergoing diagnostic laparoscopy and exploratory laparotomy in 2000 and 2001 for diagnoses consistent with an adnexal mass. Mortality and morbidity rates for each type of procedure within each diagnosis were also estimated.

Second, we performed a simple decision model based on serial or parallel testing using the pooled sensitivity and specificity of various tests to predict outcomes.

Finally, we used a previously developed Markov model of the natural history of ovarian cancer to explore the implications of alternative possible pathways in the development of advanced disease - specifically, that some cancers limited to the ovaries (Stage I) may spread to the upper abdomen (Stage III) without first spreading to other pelvic organs (Stage II).

## Results

Question 1: What is the prevalence of various tumor types among women with an adnexal mass, stratified by cancer status (malignant vs. benign), age, menopausal status, and size of tumor?

In a large screening study in Kentucky the prevalence of malignant masses was 0.09 to 0.18 percent, and of benign masses 0.8 to 1.8 percent. In 16 case series, the prevalence of malignancy ranged from 0 to 57 percent, reflecting differences in the referral patterns of the centers where the surgery was performed. The prevalences of specific types of masses also varied widely within studies. Six studies did not report the proportion of women who were postmenopausal, and none of them described whether patients were symptomatic or asymptomatic, or the type of evaluation they had undergone prior to surgery.

Question 2: What are the sensitivity, specificity, and reliability of the bimanual pelvic examination?

Pooled sensitivity in five studies for detection of an adnexal mass was 0.45, and pooled specificity 0.90. For distinguishing a benign from a malignant mass, pooled sensitivity in 10 studies was 0.72, specificity 0.92. When only screening studies were included, pooled sensitivity was 0.58, specificity 0.98.

Question 3: Among women with a palpable adnexal mass on exam or a mass identified by ultrasound/imaging, what is the sensitivity/specificity of various evaluation modalities including ultrasound (transvaginal ultrasound, transabdominal ultrasound, color Doppler, two-dimensional [2D] vs. three-dimensional [3D] ultrasound), computer tomography (CT) scan, magnetic resonance imaging (MRI) scan, and CA-125 levels for distinguishing benign from malignant masses?

A total of 153 articles were included. For morphologic appearance on ultrasound, pooled sensitivities for specific scoring systems ranged from 0.82 to 0.91, and specificities from 0.68 to 0.81. For Doppler ovarian blood flow studies, pooled (a) sensitivity and (b) specificity were: resistive index (a) 0.72, (b) 0.90; pulsatility index (a) 0.80, (b) 0.73 ; maximum systolic velocity (a) 0.74, (b) 0.81 ; presence of vessels (a) 0.88, (b) 0.78. The combination of morphology and Doppler had pooled sensitivity of 0.86 and specificity of 0.91.

Pooled (a) sensitivities and (b) specificities of other imaging modalities were: MRI (a) 0.91, (b) 0.88 ; CT (a) 0.90, (b) 0.75 ; and positron emission tomography using an 18-Fluorodeoxyglucose tracer (FDG-PET) (a) 0.67, (b) 0.79.

Pooled sensitivity and specificity for CA-125 at a threshold of 35 U/mL were 0.78 and 0.78, respectively. In studies that compared performance by menopausal status, both sensitivity and specificity were substantially better in postmenopausal women.

Characterization of the patient population with respect to presence or absence of symptoms, or previously performed tests, was uniformly poor among studies.

Question 4: What is the accuracy of explicit scoring systems which incorporate various combinations of imaging findings, patient risk factors, and/or CA-125 levels for detecting malignancy? Have these scoring systems been applied to a population of women before laparoscopy or laparotomy?

We identified 36 studies. Existing validated scoring systems were all developed in mixed pre- and postmenopausal populations. The highest demonstrated specificity obtained with these scoring systems appears to be in the range of 90 to 95 percent, and, at this range of specificity, the sensitivity appears to be in the range of 65 to 80 percent. Performance was consistently worse in validation studies (done to confirm the performance of the scoring system) than in development studies. Many of the studies were applied to patients immediately prior to surgery, but the clinical presentation and prior testing were not described.

Question 5: Among women with suspected benign masses on initial investigation, what are the sensitivity and specificity of monitoring with periodic CA-125 and/or interval ultrasound examinations for detecting malignant masses? How does the interval of testing/definition of change affect sensitivity and predictive value?

Nine studies were identified, and, because of variable definitions and methods, no definitive conclusions could be drawn. In one large study of over 15,000 postmenopausal women, no cancers were ultimately diagnosed in a unilocular cyst less than 10 cm (2,763 women) over a mean followup of 6.3 years, although three cancers developed after resolution of the cyst or in the contralateral ovary.

Question 6: Among women with adnexal masses, what are the morbidity and mortality from diagnostic surgery (laparoscopy or laparotomy)? At what point does the risk of surgery outweigh the risk of detecting malignancy?

In 15 series totaling 4,915 patients, there were three deaths. Morbidity rates were also low. Comparative studies suggest lower morbidity with laparoscopy, but there is potential confounding, even in randomized studies. None of the included studies provided sufficient clinical detail to determine whether risks differed based on ultimate diagnosis.

In the NIS, both morbidity and mortality were highest in cases with a cancer diagnosis, but available codes prevented direct comparisons. In addition, because outpatient laparoscopic procedures were not included, both numerators and denominators are likely to be underestimated.

Question 7: What are the estimated trade-offs resulting from various strategies for evaluation of the adnexal mass?

Given the summary findings, we were unable to construct comprehensive models to estimate the likely outcomes of different strategies. In a preliminary model, serial testing with the best imaging study (morphology plus Doppler), followed by CA-125, resulted in fewer missed cancers and fewer surgeries than either test alone in postmenopausal women. Parallel testing incorporated into a scoring system resulted in slightly fewer missed cancers, but more surgeries and twice as many tests.

Because comprehensive models should ultimately include the natural history of ovarian cancer and the possible effects of screening, we identified three articles that simulated this natural history. All three assumed that ovarian cancer necessarily progresses through all four stages. Using a similarly structured model, we were able to generate estimated incidence and stage distribution similar to reported data by allowing some Stage I cancers to progress directly to Stage III. By reducing the available detection time for Stage I cancers, this would adversely affect the potential effectiveness of screening.

## Discussion

### Limitations of the Literature

The main limitation in the literature was the failure to adequately describe relevant patient characteristics, including the presence or absence of symptoms, and variable reporting of menopausal status. Inadequate sample size, lack of blinding, and failure to account for observer variability were also common limitations.

### Limitations of the Report

The report did not include non-English publications. We did not include non-U.S. studies in our review of the prevalence of different types of adnexal mass. Given the heterogeneity of studies, pooled estimation of sensitivity and specificity may not be appropriate. The NIS does not include outpatient procedures, and our coding algorithm may have missed some complications.

## Future Research

Research priorities include: a minimal consensus data set on key patient characteristics (with results presented stratified by those characteristics); better estimates of prevalence and surgical outcomes using data sources that capture inpatient and outpatient encounters, such as Medicare or health maintenance organizations; better characterization of patient characteristics in all studies; better evidence on the value of the pelvic exam as part of routine health maintenance; and development of additional models for simulating the natural history of ovarian cancer and evaluating screening, diagnosis, and treatment strategies.

## Conclusions

Developing an effective and efficient algorithm for the evaluation of any condition requires good evidence on the prevalence of the condition at the first diagnostic encounter, and the sensitivity and specificity of the potential diagnostic tests to be used. Unfortunately, the overwhelming majority of the literature we reviewed did not provide sufficient detail on important patient characteristics to allow estimation of the outcomes of different diagnostic strategies, either in the context of detecting adnexal masses or distinguishing benign from malignant masses.

All of the diagnostic tests and scoring systems we evaluated exhibited a trade-off between sensitivity and specificity - studies of a given test that reported higher sensitivity had lower specificity, and vice versa. The bimanual pelvic examination has low sensitivity for both detection of adnexal masses and discriminating benign from malignant masses, raising doubts about its utility as a screening test in asymptomatic women. In pooled analysis, the combination of ultrasound morphology and Doppler blood flow had the best combination of sensitivity and specificity, with MRI comparable. In a preliminary model, serial testing with imaging followed by CA-125 was both more sensitive and more specific than either test alone; parallel testing using both tests incorporated into the Risk of Malignancy Index resulted in fewer missed cancers (greater sensitivity) but more surgeries (lower specificity), with twice as many tests.

Studies of surgical management suffered from the same limitations in terms of description of patient characteristics, making estimation of the risks of false positive diagnostic testing impossible.

Ultimately, evaluation of potential strategies for reducing morbidity and mortality from ovarian cancer may require use of simulation models, a technique that has proven helpful in evaluating prevention strategies for other cancers. Because the natural history of ovarian cancer is relatively unknown, testing of alternative models is critical. Although a few sophisticated models exist, development of additional models would be helpful, especially in the context of evaluating results from ongoing trials of screening. If any of these trials show a benefit from screening, then the need for better evidence on the diagnostic evaluation of adnexal masses will become even more critical.