# Acknowledgments

The authors gratefully acknowledge Jane Kolimaga and Alison Lee for assistance in study initiation; Margaret Jamison, PhD, for assistance with analysis of the Nationwide Inpatient Sample data set; and Karen Hoffman, MD, for initial work on developing the ovarian cancer natural history model. They also thank Mona Saraiya, MD, MPH, and Christie Eheman, PhD, from the Centers for Disease Control and Prevention for their valuable input.