# Conclusions

Developing an effective and efficient algorithm for the evaluation of any condition requires good evidence on the prevalence of the condition at the first diagnostic encounter, and the sensitivity and specificity of the potential diagnostic tests to be used. With this information, one can estimate the outcomes, in terms of true and false positive and negative results, of each test. Various combinations of tests can be compared, and, ideally, the consequences of each test's results in terms of benefits, harms, and costs can be estimated.

In the setting of an adnexal mass, the primary issue is discriminating benign from malignant masses; ideally, all women with an underlying ovarian malignancy would receive appropriate surgical management (perfect sensitivity), and no woman with an asymptomatic benign mass would undergo unnecessary surgery (perfect specificity). The optimal strategy may well differ based on whether or not the patient presents with symptoms, both because the prevalence of disease is likely to be higher in the patient with symptoms (making the positive predictive value higher and the negative predictive value lower), and because surgical management may ultimately be appropriate for a symptomatic patient, and some asymptomatic patients, even if the mass is benign. Age and/or menopausal status are also important considerations, primarily because ovarian cancer is rare prior to age 50, but also because some of the risks of surgery may increase with age.

Unfortunately, the overwhelming majority of the literature we reviewed did not provide sufficient detail on these important patient characteristics to allow confident estimation of the outcomes of different diagnostic strategies, so that we are unable to conclude that any of the strategies achieve the aims of maximizing appropriate treatment and minimizing unnecessary surgery. Outside of studies that were explicitly designed to evaluate screening, few articles described whether patients were symptomatic or asymptomatic, or testing done prior to the diagnostic test being evaluated. Surprisingly few studies reported results separately for premenopausal and postmenopausal women. Future studies need to provide this information.

All of the diagnostic tests and scoring systems we evaluated exhibited a trade-off between sensitivity and specificity - studies of a given test that reported higher sensitivity had lower specificity, and vice versa. In pooled analysis, either the combination of ultrasound morphology and Doppler blood flow, or magnetic resonance imaging (MRI), had the best combination of sensitivity and specificity. Simple modeling of series and parallel tests suggests that, in postmenopausal women, imaging using ultrasound morphology and Doppler blood flow, or MRI, followed by CA-125, is both more sensitive (misses fewer cancers) and more specific (avoids more surgery) than either test alone. A strategy in which both tests were performed and used in a scoring system, the Risk Malignancy Index, prevented additional cancers but with twice as many tests and more surgeries. More data on key parameters are needed to determine if, in certain settings, alternative combinations of tests, performed in parallel or series, might have better outcomes or be more efficient.

Studies of surgical management suffered from the same limitations in terms of description of patient characteristics, making estimation of the risks of false positive diagnostic testing impossible. Similarly, administrative data that only includes discharge information do not provide important clinical information.

The bimanual pelvic examination has low sensitivity for both detection of adnexal masses and discriminating benign from malignant masses, raising doubts about its utility as a screening test in asymptomatic women.

Ultimately, evaluation of potential strategies for reducing morbidity and mortality from ovarian cancer may require use of simulation models, a technique that has proven helpful in evaluating prevention strategies for other cancers. Because the natural history of ovarian cancer is relatively unknown, testing of alternative models is critical. Although a few sophisticated models exist, development of additional models would be helpful, especially in the context of evaluating results from ongoing trials of screening. If any of these trials show a benefit from screening, then the need for better evidence on the diagnostic evaluation of adnexal masses will become even more critical.