# Future Research

This section outlines research priorities identified through the review, both in terms of fundamental gaps in knowledge and in addressing methodological issues of existing studies.

## Minimal Data Reporting

Our ability to stratify results by relevant patient characteristics, or to compare the potential effect of patient characteristics on different results from different studies, was limited by the lack of information in most studies. We would suggest that future studies relevant to the diagnosis and management of adnexal masses provide data on, and present results stratified by, the following minimum characteristics:

- Patient age and/or menopausal status
- Patient body mass index
- Patient race and ethnicity
- Presence or absence of risk factors for ovarian cancer, particularly family history
- Means by which the adnexal mass was initially diagnosed—pelvic examination or imaging
- Reason for the initial examination which led to diagnosis of mass: symptoms referable to pelvic mass or ovarian cancer, examination for other symptoms, asymptomatic screening for ovarian cancer, or asymptomatic screening for other conditions

## Prevalence of Different Types of Adnexal Masses

- Large scale screening trials will provide some data on the prevalence of different types of masses.
- Administrative data from surgical procedures may provide crude estimates, but some important information (like stage and grade of cancer, or histologic subtype) will likely be missing. In addition, relevant clinical data on presence or absence of symptoms and the diagnostic pathway leading to diagnosis will likely be missing. The best resource for obtaining the necessary data would likely be a large health maintenance organization (HMO) or third-party payer, which would allow comparison of inpatient and outpatient records, and followup of patients after diagnosis. Medicare data would provide similar information for women 65 and older.
- Separate reporting of the prevalence of different types of masses among women with and without symptoms would be helpful for clinical decisionmaking.

## Diagnostic Testing

- Ideally, tests would be evaluated at the stage in the clinical pathway in which they are to be used.
- Since this means that many women who have a negative test will not undergo the reference standard, careful attention should be paid to development of alternative reference standards, including definitions of appropriate length of followup.
- More direct comparisons of alternative tests should be performed; existing studies are frequently underpowered to detect clinically meaningful differences, or to establish equivalence. Based on pooled analyses, either magnetic resonance imaging (MRI) or combined ultrasound evaluation of morphology and Doppler velocimetry have attractive sensitivity and specificity. Only two studies, with a total of 200 subjects, have directly compared these modalities in the same patient population. ^91,^ ^100^ In both of these studies, MRI was less sensitive but more specific than combined morphology/Doppler. More precise comparative estimates should be obtained.
- There is a paucity of studies on positron emission tomography (PET) compared to other imaging modalities. Given that the Centers for Medicaid and Medicare Services (CMS) is now reimbursing for PET scans done within the setting of a clinical trial, there is an excellent opportunity for high-quality studies which avoid the deficiencies outlined in this report.
- Although discriminating between benign and malignant lesions is the highest priority in most clinical situations, estimates of the sensitivity and specificity of various imaging modalities for specific nonmalignant lesions (endometriomas, mature teratomas, etc.) would be helpful for developing comprehensive management strategies, particularly in conjunction with good data on prevalence in premenopausal women. We identified multiple articles relevant to this question during our search, which were excluded because they were not relevant to the main study questions. Although many of the methodological issues identified here would be issues with these studies, a systematic review of this literature would have value.
- New tumor markers should continue to undergo evaluation as diagnostic tests as they are identified, using appropriate methodological standards.

## Scoring Systems

- Validation studies in new populations are needed.
- Attention should be paid to adequate sample size.

## Followup Studies

- Additional studies, with clear definitions for “benign” lesions and clear protocols for followup, with documentation of loss to followup, are needed. Because by definition these types of studies will not have histological confirmation of all test results, estimates of test performance from such studies may have some bias.

## Adverse Outcomes of Surgery

- As with studies of prevalence, both currently published studies (mostly case series) and administrative data have significant deficiencies. Case series would be improved by clearer description of the clinical pathway by which patients ended up undergoing surgery, as well as by providing relevant clinical data (such as body mass index, history of prior surgeries, and extent of disease).
- Data on outcomes from a variety of settings, including community settings, are needed.
- Again, as with studies of prevalence, data from sources able to provide both inpatient and outpatient data over time, such as HMOs, third-party payers, and Medicare, are likely to provide the best combination of sample size, generalizability, and clinical detail.

## Sensitivity and Specificity of the Pelvic Examination

- The annual bimanual pelvic examination appears to have little, if any, benefit for reducing ovarian cancer morbidity and mortality in asymptomatic women. Given that many organizations now recommend less frequent cervical cancer screening in many women, that no screening test has ever been shown to reduce morbidity and mortality from endometrial cancer, and that other gynecological cancers are too rare to justify population-based screening, it would appear that annual bimanual pelvic exams do not have a substantial benefit in reducing mortality. Therefore, evidence on the benefits of the exam would be helpful for patients, clinicians, and policymakers. Possible research areas include:
  - Many clinicians argue that the annual exam provides a “cue” for women to interact with a clinician and receive other preventive services.
    - Would women be less likely to see a health professional on a regular basis if they would not get a pelvic examination?
    - If the exam does provide a “cue” for some women, what is its effectiveness and cost-effectiveness compared to alternative methods of improving adherence to periodic health maintenance schedules?
    - Are there some women who do not regularly see a health professional because of embarrassment/fear/discomfort regarding a pelvic exam who would be more likely to see one if they could be assured they would not get an exam?
  - Others have argued that, after long experience, women expect to receive a pelvic examination (and Pap test) on an annual basis and will continue to demand the examination, despite evidence that the test has little benefit, or does not need to be performed on an annual basis.
    - How have patients reacted to other changes or paradigm shifts in medicine? Can patient expectations be changed in the face of new evidence? Do patient responses differ between changes in which one intervention is replaced by another, versus changes in which an intervention is no longer performed at all?
  - Although the pelvic examination does not appear to have significant benefit as a screening test, does it have more value as a diagnostic test?
  - Assuming the pelvic examination does have value as a diagnostic test, is there a relationship between volume/experience and test accuracy, as suggested by two of the studies we reviewed? If so, can routine examinations in asymptomatic women be justified as a method for maintaining exam skills?
  - If there is a relationship between volume and accuracy, what are the implications for the performance of diagnostic bimanual examinations by generalists (e.g., internists, pediatricians, family practitioners, generalist nurse practitioners) versus specialists (e.g., obstetrician/gynecologists, nurse-midwives, etc)

## Modeling the Outcomes of Different Screening Strategies

- Our modeling of the likely outcomes of different screening strategies was limited by the quantity and quality of data available for key parameters. Because this limited direct comparison of different testing strategies, we were not able to do a comprehensive comparison. The lack of data on patient characteristics, particularly symptom status, also prevented extensive analysis of the effects of different strategies in different clinical scenarios. Improving the evidence base for the other questions considered in the evidence report will make a substantial improvement in the ability to meaningfully model outcomes.
- Data on relevant patient preferences for different outcomes are needed.
- Data on relevant cost parameters are needed for cost-effectiveness analysis.
- Data on relative test reproducibility can help determine the effect of observer variability on effectiveness and cost-effectiveness.

## Modeling the Natural History of Ovarian Cancer

- We identified only three models, one of which was an updated version of another. Having several groups working on simulation modeling, using different assumptions, software, model structure, etc., has proven quite helpful in the case of cervical cancer. Additional work should be strongly encouraged.
- In particular, models should explore alternative disease natural history parameters, and the implications for various strategies, including screening and primary prevention.