# Discussion

## Limitations of the Report

There are several limitations to this evidence report:

- We did not review articles published in languages other than English because of a lack of resources for translation. It is possible that this led to the failure to include some relevant articles.
- For our review of prevalence studies (Question 1), we excluded studies performed outside the United States. Because the report was requested by the Centers for Disease Control and Prevention (CDC) to help with development of their policies and research agenda into ovarian cancer prevention strategies, we focused on U.S. populations and reasoned that the underlying prevalence of different conditions in women with adnexal masses could well differ in potentially important ways due to differences in racial/ethnic distribution and/or environmental exposures. As discussed in Chapter 2, this is supported by wide international variation in the incidence of cancer. Variations in screening, diagnosis, and surgical management could also lead to differences in the prevalence of various conditions among women with adnexal masses. It is possible that this reasoning was incorrect, and that some relevant articles were excluded. However, some non-U.S.-based articles were reviewed for other questions, and the majority shared the same biases as U.S.-based studies (i.e., most were done immediately preoperatively).
- There was considerable heterogeneity in design and patient populations among studies, and our use of a random-effects model to perform meta-analyses for some questions may have led to inaccurate estimates of pooled sensitivity and specificity. We also did not weight the results by anything other than sample size; it is possible that different results might have been obtained by weighting for study quality, for example.
- In our review of data from the Nationwide Inpatient Sample, we used only specific International Classification of Diseases, Ninth Revision (ICD-9) “E” class codes to identify complications. A more exhaustive strategy (e.g., identifying procedures not typically performed at the time of diagnostic surgery, identifying blood transfusions through procedure or charge codes, including patients with cancer who underwent hysterectomy) might have revealed more complications,^26^ but would have required additional assumptions about the original indication for the surgery and the likely potential contribution of different aspects of the procedure to the complication (e.g., hysterectomy vs. oophorectomy).
- Our exploration of alternative models for the natural history of ovarian cancer did not directly compare estimated outcomes of screening strategies to other models. However, a comprehensive evaluation of screening for ovarian cancer was beyond the scope of this report. We are currently developing the model further to conduct these analyses.

## Methodological Issues in the Literature

### Description of the Patient Population

The main shortcoming of many of the papers reviewed was a failure to adequately describe the patient population, including the manner in which the adnexal mass was originally detected and subsequent evaluation. In Chapter 1, we described the importance of understanding the clinical presentation of the subjects in studies of management of adnexal masses. Because prevalence directly affects predictive values and may indirectly affect estimates of sensitivity and specificity, the probability that a patient is a true or false positive, or true or false negative, is dependent on the prevalence. In addition, the presence or absence of symptoms can affect the probability that a patient will undergo surgery if test findings indicate a benign mass, since surgery may still be the treatment of choice for the underlying condition. We were disappointed that the overwhelming majority of the studies we reviewed, relevant to all of the questions, did not adequately describe their population, so that the proportions of patients who presented with asymptomatic masses versus those with symptoms could be compared.

To be fair, there is an inherent feasibility issue in studies of diagnostic test accuracy for ovarian cancer - the ideal reference standard is histological confirmation, yet this confirmation requires surgery. Although this is a limitation of all cancer screening tests, the surgery required for a definitive diagnosis of ovarian cancer is more extensive than that for many cancers (for example, cervical, breast, and colon cancer can all be diagnosed without a requirement for general anesthesia). Especially with screening, or early in the diagnostic evaluation, the risks of surgery may be difficult to justify (especially since the low prevalence of malignancy makes the positive predictive value of tests early in the diagnostic evaluation quite low). From a research ethics perspective, it is certainly reasonable to limit diagnostic test studies to patients already scheduled for surgery. However, readers of these studies should recognize that the prevalence of malignancy will be substantially higher in preoperative patients than in patients at the time of the initial diagnosis of adnexal mass. Because test performance may be affected by prevalence, the outcomes (in terms of true and false test results) may be quite different in these two patient populations.

The same caveats hold for studies of the outcomes of surgery. Morbidity and mortality related to surgical diagnosis are influenced by the underlying diagnosis, as well as the extent of the disease (such as size of the mass, presence of adhesions from the disease process or prior unrelated surgery, or cancer stage). Interpreting surgical outcomes from studies that do not provide relevant clinical information is difficult; at the least, generalizablity is a major concern. Lack of relevant clinical information is a particular problem with administrative databases, which otherwise have the attraction of large sample size and better generalizability.^26^

An even more basic shortcoming was the failure to describe potential differences in study results stratified by age or menopausal status. Given the clear and widely recognized relationship between age and ovarian cancer risk, all studies in this area should present results in a way that allows separate estimation of outcome by age/menopausal status.

### Sample Size

Few of the studies we reviewed included a priori sample size calculations. Use of confidence intervals for parameter estimates was uncommon. In studies of scoring systems, there were often too few cases of cancer for the number of variables included in the original models.

### Blinding

Relatively few of the diagnostic studies reported whether those interpreting test results were blinded to either clinical presentation or ultimate diagnosis. This could clearly have an impact, particularly in studies of the bimanual pelvic examination; the finding that specificity decreased as prevalence increased suggests that the threshold for identifying a mass as cancer is lower if the clinical suspicion - based on other factors such as patient age, menopausal status, or history - is higher. Although this may be appropriate clinically, it results in biased estimates of test performance.

### Observer Variability

Few studies addressed the potential impact of observer variability on the precision of test characteristics.

### Natural History of Ovarian Cancer

As discussed in more detail in the section on Question 7, ovarian cancer has been implicitly assumed to progress through a series of stages in a way analogous to cervical cancer. Alternative models are biologically plausible, and mathematical models can be “fitted” to match reported data under a variety of scenarios. Since existing models already show that the effectiveness of screening is dependent on assumptions about the length of Stage I, further exploration of the impact of varying assumptions about natural history is warranted.

The most important parameter in these models, stage duration, is inherently unknowable; however, the source for the parameter estimate in the two most sophisticated models were “personal communications” with two gynecologic oncologists. At the least, more formal methods of eliciting expert opinion are probably warranted for future modeling studies.

## Implications of Findings

### Question 1

The prevalence of malignancy, even in postmenopausal women, is low - approximately 0.1 percent (1 in 10,000) in large screening studies in the United States. The potential for screening to reduce morbidity and mortality is currently being tested in at least three large trials; these trials should also provide valuable data on disease prevalence and the effectiveness of various followup strategies.

### Question 2

Until the results of the large screening trials are available, many, if not most, women with asymptomatic adnexal masses will have had the mass detected as part of a routine health maintenance examination.

The bimanual pelvic examination appears to have a sensitivity of less than 60 percent, whether for detecting adnexal masses in general or for distinguishing benign from malignant masses. Based on the best pooled estimate of sensitivity (45 percent) and a prevalence of 0.1 percent, a normal risk, asymptomatic, postmenopausal woman with a normal pelvic examination has a 99.94 percent chance of not having cancer, even though over half of the cancers would be missed. This is due to the low prevalence of ovarian cancer, since, even without the test, her probability of not having cancer is 99.99 percent. Given these test characteristics, the value of the pelvic examination in reducing ovarian cancer morbidity and mortality appears to be extremely limited, at best. Although there may be some rationales for an annual bimanual examination (discussed in Chapter 5), ovarian cancer screening is not one of them.

### Question 3

Of the various diagnostic imaging modalities, either a combination of ultrasound morphology and Doppler velocimetry, or magnetic resonance imaging (MRI), had the best combination of sensitivity and specificity for distinguishing benign from malignant disease. If confirmed by direct comparison, cost-effectiveness might be the most important determinant of which would be the optimal diagnostic procedure. Because the specificity of cancer antigen 125 (CA-125) is high in postmenopausal women, it is helpful in ruling in disease.

### Question 4

Additional validation of scoring systems in new populations is required before widespread adaptation can be recommended.

### Question 5

The most effective and efficient method for following patients who have been classified as having a benign mass is unclear, although unilocular cysts less than 10 cm appear to have a very low risk of malignancy.

### Question 6

The risks of diagnostic laparoscopy or laparotomy, particularly in asymptomatic women who ultimately prove to have a benign lesion, are unclear. Overall morbidity appears to be low in reported series, but these are subject to numerous biases, particularly regarding selection for laparoscopy. Two small randomized trials suggest higher short-term morbidity with laparotomy compared to laparoscopy, but differences between the two groups raise the possibility of confounding.

### Question 7

Based on our pooled estimates of sensitivity and specificity, serial testing of postmenopausal women with an adnexal mass detected by pelvic examination with either ultrasound morphology plus Doppler imaging, or MRI (which had similar sensitivities and specificities), followed by CA-125, resulted in the most efficient combination of number of tests, missed cancers, and surgeries. Parallel testing and using a scoring system such as the Risk of Malignancy Index resulted in fewer missed cancers than serial testing, but more overall tests and more surgeries. Additional data are needed to refine these estimates, to include the morbidities of the tests and surgeries, and to perform cost-effectiveness analyses. Either combined strategy is preferable to using imaging alone or CA-125 alone.

We cannot directly compare these results to the joint guidelines of the Society of Gynecologic Oncologists (SGO) and American College of Obstetricians and Gynecologists (ACOG) on which patient to refer to a gynecologic oncologist^247^ because the data were not available to replicate their findings. However, our results are consistent with the guidelines, which recommend a CA-125 level above 35 for postmenopausal women, the presence of ascites, or evidence of adnexal or distant metastasis.

Alternative assumptions and parameter estimates can be used to generate predicted cancer incidences similar to those seen in published models of the natural history of ovarian cancer. In order to better estimate the potential impact of different strategies for ovarian cancer screening, and for managing masses detected through screening or presenting with symptoms, additional models that explore the implications for alternative natural history assumptions are needed. Data from ongoing screening trials may provide estimates of many of the currently unknown parameters.