# Results

## Question 1: Prevalence of Tumor Types

Question 1 is: What is the prevalence of various tumor types among women with an adnexal mass, stratified by cancer status (malignant vs. benign), age, menopausal status, and size of tumor?

### Approach

We included studies in the U.S. population with more than 50 women and limited the literature search to screening studies and case series where results were provided for all women with an undiagnosed mass, not just those with subsequent positive additional tests.^21^ Studies of adnexal mass in which the gold standard is applied only to those with positive tests results would underestimate the prevalence of disease and cause a substantial bias.

### Results

Twenty articles met the inclusion criteria and are described in the Evidence Table 1 (Appendix D *).^31^–^50^

* Appendixes cited in this report are provided electronically at http://www.ahrq.gov/downloads/pub/evidence/pdf/adnexal/adnexal.pdf.

Detailed prevalences for specific tumor types are provided in Evidence Table 1. The included studies can be divided into two groups. The first group includes four reports from a large screening study in Kentucky (Table 5). The prevalence of malignancy ranged from 0.09 to 0.18 percent. In postmenopausal women, the prevalence of malignancy was 0.09 to 0.18 percent, borderline tumors were not reported, and the prevalence of benign tumors was 0.08 to 1.3 percent. In a population that included either postmenopausal women or those with a family history of breast, ovarian, or colorectal cancer, the prevalence of malignancy was 0.10 to 0.11 percent, of borderline tumors 0.02 percent, and of benign tumors 1.1 to 1.2 percent.

Table 5 Prevalence of tumor types in screening studies*

Study | N | % Menopausal | Malignant | Borderline | Benign
DePriest et al.,1993^36^ | 3,220 | 100; most had positive family history of breast, ovarian, or colorectal cancer | 0.09% | Not reported | 1.3%
DePriest et al.,1997^34^ | 6,470 | Either menopausal or had positive family history of breast (30%), ovarian (24%), or colorectal cancer (15%) | 0.11% | Not reported | 1.2%
Modesitt et al., 2003^40^ | 15,106 | 100 | 0.18% | Not reported | 0.8%
Van Nagell et al., 2000^49^ | 14,469 | Either menopausal or had positive family history of breast (34%), ovarian (23%), or colorectal cancer (23%) | 0.1% | 0.02% | 1.1%

* Note: All four publications represent the same screening study at different times.

The most common malignant tumor types include primary ovarian carcinoma, such as serous and mucinous cystadenocarcinoma, granulosa cell tumors, and undifferentiated adenocarcinoma. Borderline tumors were less common, such as serous low malignant potential (0.02 percent). The most common benign tumors were serous cystadenoma (0.4 to 0.7 percent), paratubal cyst (0.1 to 0.16 percent), endometrioma (0.03 to 0.3 percent), and mature teratoma (0.02 to 0.08 percent).

The majority of U.S. studies with histological diagnosis of all masses (n = 16) were case series of women with undiagnosed adnexal mass undergoing laparotomy (Table 6). The prevalence of malignancy ranged from 5.7 to 57.5 percent, the range of borderline tumors was 1.4 to 11.2 percent, and the prevalence of benign tumors was 40 to 100 percent. All tumor types were over-represented because patients had an undiagnosed adnexal mass, and the clinical presentation was not well described in the majority of studies. Most studies included both premenopausal women and postmenopausal women and did not provide results separately. The one study that included only postmenopausal women^41^ found only benign tumors.

Table 6 Case series and retrospective medical record reviews

Study | Denominator | Location | Age, menopausal status, race | Malignant | Borderline | Benign
Childers et al.,1996^32^ | 138 | AZ | 52 | 13.8% | Not reported | 86.2%
Dottino et al.,1999^37^ | 160 | NY | 52.2 | 8.1% | 5% | 86.9%
| | | 53% post
| | | 91% white
Fleischer et al., 1996^38^ | 62 | TN | 50 | 50% | Not reported | 50%
| | | >50% post
Lin et al., 1993^39^ | 80 | NY | 56 | 57.5% | 2.5% | 40%
| | | 76% post
| | | 90% white
Parker et al., 1994^41^ | 61 | Multi-site | 65 | None | None | 100%
| | | 100% post
Roman et al., 1997^42^ | 226 | CA | 20% post | 11.5% | 7.5% | 81%
Schneider et al., 1993^43^ | 55 | AZ | 53 | 25.5% | 3.6% | 70.9%
| | | 60% post
Scoutt et al., 1994^44^ | 109 | CT | 40 | 20.2% | Not reported | 79.8%
Shen-Gunther et al., 2002^45^ | 125 | OK/NV | 58 | 44.8% | 9.6% | 45.6%
| | | 82% white
Smikle et al., 1995^46^ | 195 | TX | 40% post | 13.3% | Not reported | 86.7%
*Chalas et al., 1992^31^ | 241 | NY | Not reported | 50.2% | 7.5% | 42.3%
Cohen et al., 2001^33^ | 71 | IL | 22–80 | 18.3% | 1.4% | 80.3%
| | | 44% post
DePriest et al., 1993^35^ | 121 | KY | 3–74 | 10.7% | Not reported | 89.3%
| | | 49% post
Troiano, 1997^47^ | 144 | CT | 45 | 11.8% | 2.1% | 86.1%
| | | 29% post
Twickler et al., 1999^48^ | 244 | TX | 38.6 | 5.7% | 6.6% | 87.7%
Vasilev et al., 1988^50^ | 182 | CA | Not reported | 8.2% | 1.6% | 90.1%

* Retrospective chart review

### Discussion

Estimating the age-specific prevalence of specific adnexal tumor types from the available literature is difficult. The best data come from a series of reports from a large screening study; overall prevalence of masses was 1 to 2 percent, with benign masses outnumbering malignant by 4- to 10-fold. Because patients with negative screening test results did not undergo definitive diagnostic procedures in these studies, the prevalence estimates are dependent on the sensitivity of the screening tests used (and the completeness of followup among test negatives). In addition, there is a potential bias in that premenopausal women enrolling in the screening study were at higher risk than average because of family history; in addition, postmenopausal women may have been more likely to enroll because of concerns based on family history, vague symptoms, or other reasons which would affect relative prevalence compared to the general population.

Estimates of prevalence in studies with 100 percent histologic diagnosis are inevitably biased by the clinical factors that determine which patients ultimately undergo surgery. These can include the presence and nature of symptoms (patients with symptoms referable to a mass would likely undergo surgery sooner than those with asymptomatic masses, all other things being equal); other findings (for example, the presence of ascites); patient anxiety; the diagnostic algorithms used (for example, the duration of followup for persistence); and the nature of the practice (malignancies will be more frequent in a gynecologic oncology practice compared to a general gynecology practice).

As mentioned previously, we did not include studies from outside the United States. Given differences in ethnic backgrounds (affecting genetic risks), observed differences in cancer incidence, and differences in clinical practice between countries, and the almost universal failure of studies to describe the clinical history leading to the diagnosis of adnexal mass, inclusion of these studies would not have allowed a more precise estimate of prevalence of different types of adnexal masses in the U.S. population.

### Summary

In four reports from a large U.S. screening study, the prevalence of adnexal masses detected by ultrasound among postmenopausal women was 0.8 to 1.3 percent, and the prevalence of malignancy 0.09 to 0.18 percent (i.e., 9 to 18 per 10,000). Prevalence of different pathologies varies widely among case series. There are no data on the relative prevalence of different pathologies among women with asymptomatic masses compared to women with symptomatic masses.

## Question 2: Bimanual Pelvic Examination

Question 2 is: What are the sensitivity, specificity, and reliability of the bimanual pelvic examination?

### Approach

Articles were sought which evaluated the ability of the bimanual examination to detect adnexal masses, and/or to discriminate benign from malignant masses. Preference was given to studies where there was histological confirmation of the diagnosis, but an alternative reference standard (such as followup) was allowed for screening studies. Data allowing calculation of sensitivity and specificity had to be provided.

Our rationale for including the pelvic examination was based on its role in the initial evaluation of adnexal masses. Some asymptomatic women will have a mass detected as part of a “routine” physical examination; others will have a mass detected as part of an examination performed because of symptoms. The postexamination probability of malignancy is a function of the prevalence of cancer and the sensitivity and specificity of the bimanual examination; these probabilities, in turn, will affect the positive and negative predictive values of additional tests such as cancer antigen 125 (CA-125) and imaging studies. Because the pelvic examination will be the first test performed, either as a screening test or as a diagnostic test, knowledge of its test characteristics is important for evaluating subsequent diagnostic tests.

### Results of Literature Search and Screening

We identified 14 studies that met the inclusion criteria.^42,^ ^51^–^63^ Nine studies provided data on discrimination between benign and malignant masses,^42,^ ^51,^ ^53^–^57,^ ^62,^ ^63^, four on the ability of the bimanual examination to detect any adnexal mass,^52,^ ^59^–^61^ and one provided data on both discrimination between benign and malignant and ability to detect masses.^58^ All 14 studies are summarized in Evidence Table 2 (Appendix D *).

### Study Characteristics

Types of data incorporated. Two of the studies^54,^ ^56^ included history or clinical impression as part of the “test;” results were not provided separately for examination alone.

Types of study population. Ten of the 14 studies were performed prior to surgery for an adnexal mass, while four were from screening studies.^51,^ ^52,^ ^57,^ ^58^

Reporting of study populations. Of the screening studies, Andolf et al.^52^ was performed in women over 40 considered at high risk of ovarian cancer because of symptoms or risk factors; Grover and Quinn^57^ was performed in asymptomatic volunteers 25 and older, but described menopausal status; Adonakis et al.^51^ was performed in women over 45; and Jacobs et al.^58^ was done entirely in a postmenopausal population.

Seven of the 11 preoperative studies reported menopausal status, but only two reported on test characteristics specifically by menopausal status.^55,^ ^56^ None reported race/ethnicity, and none reported the clinical route by which patients had come to surgery (detection of an asymptomatic mass, symptoms, etc.).

Methodology. The methodological quality of the included studies was as follows:

Reference standard. Of the preoperative studies, all but one^42^ had operative confirmation of findings. Ultrasound was used as the reference standard in the four screening studies, with 12-month followup examinations or questionnaires.

Verification bias. In the study by Roman et al.,^42^ 26 women with non-palpable masses did not undergo definitive diagnosis.

Test reliability. Only one study^60^ provided direct data on test reliability. Grover and Quinn,^57^ Ong et al.,^59^ Schutter et al.,^63^ and Buckshee et al.^54^ used a single examiner. The other studies did not address the issue of test reliability.

Sample size. None of the reports had a priori sample size calculations.

Use of appropriate statistical tests. All reports used appropriate techniques for calculating test characteristics.

Blinding. Only two studies^54,^ ^60^ explicitly stated whether examiners were blinded to prior history or other findings.

Definition of positive and negative test. Nine of 14 studies reported their definitions of a positive test, although the precision of the definitions was quite variable (from “a mass 5 cm or more in diameter” to “larger than normal”); others relied on “clinical impression.”

### Results

Table 7 and Figure 4 present the results of studies that evaluated the sensitivity of the bimanual examination for detecting an adnexal mass. The studies of Padilla et al.^60,^ ^61^ are particularly striking for the low sensitivity, since the examinations were performed under anesthesia, when, presumably, patient discomfort would not be a limiting factor. Both studies suggested a relationship between experience and accuracy; medical students performed worse than residents, who performed worse than attending physicians. Although these differences were not statistically significant, the studies were underpowered to detect significant differences. Obesity, defined as a body mass index greater than 30, had a significant negative impact on sensitivity, while increasing uterine size increased sensitivity, possibly by elevating the adnexae out of the pelvis.

Table 7 Sensitivity and specificity of pelvic examination in detecting the presence of an adnexal mass

Study | N | Sensitivity (95% CI) | Specificity (95% CI) | % with confirmed mass | Notes
Jacobs et al., 1988^58^ | 1,010 | 84.6% (65.0 to 100%) | 98.3% (97.5 to 99.1%) | 1.3% (0.1% malignant) | Reference standard: ultrasound
| | | | | Screening study
Andolf et al., 1990^52^ | 801 | 33.7% (26.5 to 41.0%) | 92.0% (89.9 to 94.1%) | 20% (0.1% malignant) | Reference standard: ultrasound by midwife
| | | | | Screening in women considered at high risk for ovarian cancer; no ovarian cancers detected: 2 endometrial cancers, 1 LMP detected
Padilla et al., 2005^61^ | 252 | 15.6% (8.1 to 23.0%) | 93.8% (90.1 to 97.5%) | 35.7% (unclear if any malignacies) | Exam under anesthesia prior to surgery for pelvic mass; examiners blinded to radiology findings
| | | | | Likelihood of not detecting an adnexal mass increased with less experience (OR for resident 1.13, student 1.36 compared to attending, although 95% CIs cross 1).
| | | | | Statistically significant increase in missed diagnosis if subject with BMI > 30 (OR 2.57; 95% CI, 1.36 to 4.87), and significant decrease in presence of enlarged uterus (OR 0.48; 95% CI, 0.25 to 0.93).
| | | | | Final diagnoses not presented, reasons for surgery not systematically presented
Padilla et al., 2000^60^ | 140 (82 masses) | Left adnexa (attending exam): 32.7% (19.5 to 45.8%) | Left adnexa (attending exam): 88.5% (81.4 to 95.6%) | 58% (0 malignancies) | Exam under anesthesia prior to surgery for pelvic mass; examiners blinded to radiology findings; no clear relationship to experience
| | Right adnexa (attending exam): 21.2% (7.3 to 35.2%) | Right adnexa (attending exam): 78.7% (70.4 to 87.0%)
Ong et al., 1996^59^ | 86 | 71.9% (60.9 to 82.9%) | 59.1% (38.5 to 78.6%) | 74.4% (0 malignant) | Pre-surgical exam

Abbreviations: BMI = body mass index; CI = confidence interval; LMP = low malignant potential tumor; OR = odds ratio

Figure 4. Performance of bimanual pelvic examination for detecting the presence of an adnexal mass

Key to Figure 4: 1 = Jacobs et al., 1988;^58^ 2 = Andolf et al., 1990;^52^ 3 = Padilla et al., 2005;^61^ 4 = Roman et al., 1997;^42^ 5 = Padilla et al., 2000;^60^ 6 = Ong et al., 1996^59^

When sensitivity and specificity were combined separately using a random-effects model, the pooled sensitivity was 0.45 (95% confidence interval [CI], 0.28 to 0.68), and the pooled specificity was 0.90 (0.80 to 0.96).

Table 8 and Figure 5 show the test characteristics for discriminating benign from malignant masses. Using a random-effects model, pooled sensitivity was 0.72 (95% CI, 0.49 to 0.88) and specificity was 0.92 (0.80 to 0.97). When only the three screening studies were included, pooled sensitivity was 0.58 (95% CI, 0.21 to 0.88), pooled specificity 0.98 (0.97 to 0.98).

Table 8 Sensitivity and specificity of pelvic examination in discriminating benign from malignant adnexal masses

Study | N | Sensitivity (95% CI) | Specificity (95% CI) | % Malignant | Notes
Adonakis et al., 1996^51^ | 2,000 | 66.7% (13.3 to 100%) | 97.2% (96.5 to 97.9%) | 0.15% | Screening study; threshold of “abnormal or ambiguous exam;” CA-125 used in conjunction to proceed to ultrasound
Grover et al., 1995^57^ | 2,623 | 0% (0 to 100%) | 98.5% (98.0 to 98.9%) | 0.05% | Screening study; ultrasound and clinical followup
Jacobs et al., 1988^58^ | 1,010 | 100% (0 to 100%) | 97.3% (96.3 to 98.3%) | 0.1% | Screening study; followup with ultrasound
Roman et al., 1997^42^ | 200 | 51.2% (36.3 to 66.1%) | 83.6% (77.8 to 89.4%) | 21% | Results for 26 patients with non-palpable masses not included; no substantial difference based on menopausal status
Buckshee et al., 1998^54^ | 34 | 77.8 % (50.6 to 100%) | 88.9% (77.0 to 100%) | 25% | One examiner; non-consecutive patients prior to surgery
Balbi et al., 2001^53^ | 72 | 90% (77.5 to 100%) | 74% (61.8 to 86.2%) | 31% | 18 patients with “clearly benign masses” and 2 with “clearly malignant” excluded; clinical impression
Finkler et al., 1988^56^ | 106 | 43.2% (27.3 to 59.2%) | 90.8% (83.7 to 97.8%) | 36% | “Clinical impression” included exam plus history; results not calculated for exam alone
| | Premenopausal: 16.7% (0 to 33.9%) | Premenopausal: 92.3% (85.1 to 99.6%) | Premenopausal: 26%
| | Postmenopausal: 68.4% (47.5 to 89.3%) | Postmenopausal: 84.6% (65.0 to 100%) | Postmenopausal: 59%
Schutter et al., 1998^63^ | 155 | 91.5% (84.4 to 98.6%) | 73.9% (64.9 to 82.9%) | 39% | All postmenopausal; high prevalence of cancer; single examiner; inclusion/exclusion criteria not described
Schutter et al., 1994^62^ | 222 | 92.6% (87.4 to 97.9%) | 63.0% (54.6 to 71.4%) | 43% | Preoperative patients
Dowd et al., 1993^55^ | 225 | 51.0% (41.7 to 60.3%) | 87.0% (80.8 to 93.2%) | 49% | Preoperative patients
| | Premenopausal: 31% | Premenopausal: 95%
| | Postmenopausal 59% | Postmenopausal: 75%

Abbreviations: CA-125 = cancer antigen 125; CI = confidence interval

Figure 5. Performance of bimanual pelvic exam for distinguishing benign from malignant adnexal masses

Key to Figure 5: 1 = Grover and Quinn, 1995;^57^ 2 = Adonakis et al., 1996;^51^ 3 = Jacobs et al., 1988;^58^ 4 = Dowd et al., 1993;^55^ 5 = Schutter et al., 1994;^62^ 6 = Finkler et al., 1988;^56^ 7 = Balbi et al., 2001;^53^ 8 = Buckshee et al., 1998^54^

For both types of studies, there appears to be a trend towards decreased specificity as prevalence increases, although the number of studies is small and the confidence intervals are wide. The extreme differences in sensitivity in the two largest studies (0 and 100 percent) prevent even a qualitative assessment of any relationship between prevalence and sensitivity.

The two studies that stratified results by menopausal status^55,^ ^56^ found lower sensitivity and higher specificity for discriminating benign from malignant masses in premenopausal women compared to postmenopausal women (Table 8).

### Discussion

Despite the common recommendation for routine pelvic examination, we found surprisingly little literature on its accuracy. Based on the literature we did identify, its sensitivity for detecting adnexal masses appears fairly low. Sensitivity for detecting normal adnexa is also low, as demonstrated in a recent study of examinations under anesthesia.^64^ Although sensitivity for distinguishing a malignant mass from a benign one is somewhat better, these results need to be interpreted with caution, since most of the studies were done in preoperative patients, who would already have a higher probability of having a malignancy. In the four large screening studies, there was a total of only five malignancies, with the bimanual detecting 0 percent, 66 percent, and 100 percent in the three individual studies where ovarian cancer was detected; the fourth had one case of a low malignant potential tumor and two endometrial cancers. Pooled sensitivity for the three screening studies that addressed discrimination between benign and malignant masses was considerably lower than for all studies combined (and was similar to the pooled sensitivity of the studies that examined the ability to detect any adnexal mass).

Both types of studies show a trend toward decreased specificity as the prevalence of abnormality increases - this may reflect a greater degree of suspicion on the part of the examiner, based on other findings, and a greater likelihood of calling an examination abnormal. This is supported by the finding of the two studies which stratified results by menopausal status, which found higher sensitivity and lower specificity in postmenopausal women compared to premenopausal women.^55,^ ^56^ Because examiners were unblinded, and were likely aware of the higher prevalence of malignancy among postmenopausal women, they may have been more likely to assign a diagnosis of malignancy among those patients. Future studies need to pay stricter attention to blinding examiners to other information. In theory, this bias should also result in higher sensitivity as prevalence increases, although, because of the small number of studies, the small numbers of subjects in most studies, and the diametrically opposed findings of the two largest studies, we were unable to recognize any relationship.

In the two studies that addressed the effect of experience on test characteristics,^60,^ ^61^ there appeared to be a relationship between increasing experience and increased sensitivity (specificity did not change); however, even attending physicians achieved a sensitivity of only 28 percent. Based upon the available literature, the bimanual examination does not appear to be a sensitive test for detecting the presence of adnexal masses and appears to have limited ability to discriminate benign from malignant masses. Although specificity was somewhat better, positive predictive values will still be quite low in low prevalence settings, as discussed under Question 7. This will, in turn, lower the positive predictive value of diagnostic tests performed in patients referred on the basis of a pelvic examination. These tests are discussed in detail in the next section.

## Question 3: Single Modality Tests

Question 3 is: Among women with a palpable adnexal mass on exam or a mass identified by ultrasound/imaging, what is the sensitivity/specificity of various evaluation modalities including ultrasound (transvaginal ultrasound [TVUS], transabdominal ultrasound, color Doppler, two-dimensional [2D] versus three-dimensional [3D] ultrasound), computer tomography (CT) scan, magnetic resonance imaging (MRI) scan, and CA-125 levels for distinguishing benign from malignant masses?

### Approach

This section considers the various evaluation modalities that are described in the literature and would be available to a clinician to aid in the work-up of an adnexal mass after it has been diagnosed. We focused our search on articles whose primary reference standard was histopathology. Ideally this reference standard would be applied to all test negatives. However, we accepted a repeat negative test (such as imaging) conducted at least 6 months later as an acceptable alternative. We did include some studies that were from population-based screening samples, and these will be considered in a separate section below. The evaluation modalities investigated can be divided into several general categories. Imaging studies will be divided by technological mode (ultrasound, MRI, etc.). Ultrasound studies will be divided into those that evaluate adnexal morphology (either by an explicit scoring system or by descriptive standards), those that measure vascular flow in the mass (Doppler), and those that evaluate these modalities in combination. Serum studies will focus primarily on CA-125, as this is the most common marker in both the literature and in clinical practice. However, other serum markers will be discussed as well. Finally, the studies for which it was possible to stratify by menopausal status will be discussed where appropriate.

### Results of Literature Search and Screening

Two hundred and five articles were identified for abstraction. Of these, 153 met the inclusion criteria and were abstracted into Evidence Table 2 (Appendix D *).^31,^ ^33^–^36,^ ^39,^ ^42^–^44,^ ^46,^ ^47,^ ^49^–^56,^ ^58,^ ^62,^ ^63,^ ^65^–^195^

### Ultrasound Morphology

Conventional grey scale ultrasonography is the most common imaging modality used to differentiate benign from malignant adnexal masses. Especially with the advent of high-frequency transvaginal probes, the quality of the images allows description of the gross anatomic features of the lesion. This is, however, limited by the great variability of macroscopic characteristics of both benign and malignant masses. Furthermore, the technique is operator dependent. To overcome these limitations, morphologic scoring systems have been developed. Such scoring systems are based on specific ultrasound parameters each with several scores according to determined features and with a cutoff value to categorize masses as either malignant or benign.

Table 9 describes the details of the most commonly used scoring systems. Briefly, the following scores are suggestive of malignancy: Sassone^159^ greater than 9, DePriest^36^ greater than or equal to 5, Ferrazzi^93^ greater than 9, and for Lerner^131^ greater than or equal to 3. Although the development of all the scoring systems was motivated to improve the reproducibility of morphological measurements, only the scoring system by Lerner et al. based the categories on a multivariate logistic analysis.

Table 9 Detailed description of ultrasound scoring systems

Scoring system | Score
Sassone et al., 1991 ^159^
Morphology | 1 | 2 | 3 | 4 | 5
Inner wall structure | Smooth | Irregularities ≤ 3 mm | Papillarities > 3 mm | Not applicable, mostly solid | -
Wall thickness (mm) | Thin (≤ 3) | Thick (> 3) | Not applicable, mostly solid | - | -
Septa (mm) | None | Thin (≤ 3) | Thick (> 3) | -
Echogenicity | Sonolucent | Low echogenicity | Low echogenicity with ochogenic core; mixed echogenicity | - | High echogenicity
DePriest et al., 1993 ^36^
Morphology | 0 | 1 | 2 | 3 | 4
Cystic wall structure | Smooth (< 3 mm thick) | Smooth (> 3 mm thick) | Papillary projection (< 3 mm) | Papillary projection (≥ 3 mm) | Predominately solid
Volume (cm3) | < 10 | 10–50 | > 50–200 | > 200–500 | > 500
Septum structure | No septa | Thin septa (< 3 mm) | Thick septa (3 mm to 1 cm) | Solid area (≥ 1 cm) | Predominately solid
Ferrazzi et al., 1997 ^93^
Morphology | 1 | 2 | 3 | 4 | 5
Wall | ≤ 3 mm | > 3 mm | - | Irregular, mostly solid | Irregular, not applicable
Septa | None | ≤ 3 mm | > 3 mm
Vegetations | None | - | - | ≤ 3 mm | > 3 mm
Echogenicity | Sonolucent | Low echogenicity | - | With echogenic areas | With heterogeneous echogenic areas, solid
Lerner et al., 1994 ^131^
Morphology | 0 | 1 | 2 | 3
Wall structure | Smooth or small irregularities < 3 mm | - | Solid or not applicable | Papillarities ≥ 3 mm
Shadowing | Yes | No | - | -
Septa | None or thin (< 3 mm) | Thick (≥ 3 mm) | - | -
Echogenicity | Sonolucent or low-level echo or echogenic core | - | - | Mixed or high

Reproducibility of tests. Timmerman et al.^196^ evaluated the subjective assessment of ultrasonographic images for discriminating between malignant and benign masses. Three hundred consecutive patients were evaluated with TVUS by six different operators, and both diagnostic accuracy and interassessor agreement were calculated. The operators had varied experience in TVUS - from approximately 300 to 15,000 scans. The two most experienced operators agreed 92 percent of the time. The accuracy of the least experienced operators ranged from 82 to 87 percent (p = 0.0001). Overall, 65 percent of all the masses were correctly classified by all six operators. Interassessor agreement was greater between the most experienced operators as well (kappa = 0.852). When comparing experienced with less experienced operators, the kappa ranged from 0.581 to 0.737. This is similar to the kappa reported by Yamashita et al.^192^ among five operators, 0.62 (± 0.02) with TVUS. Interassessor agreement was not calculated between the less experienced operators. None of the included articles described operator experience, and only a few addressed interobserver variability. Although operator experience appears to correlate with accuracy, the specialty training of the unltrasonographer does not. In a meta-analysis of both morphologic and color Doppler tests in the evaluation of adnexal masses, Kinkel et al.^197^ found no difference between radiologists and gynecologists in the performance of ultrasound.

TVUS versus abdominal ultrasound. Of the 122 articles that evaluated adnexal masses via ultrasound (through either ultrasound morphology or Doppler measurements), only five articles exclusively used transabdominal imaging.^52,^ ^58,^ ^116,^ ^133,^ ^198^ Fifty-nine articles used TVUS exclusively and 51 used a combination of TVUS and abdominal ultrasound. There were seven articles for which the ultrasound modality was unknown. In the majority of the articles that used a combination of TVUS and abdominal ultrasound, TVUS was the “method of choice.” The most common reasons cited for also including abdominal ultrasound were patient refusal of transvaginal scans, virginity, poor image quality, and very large masses. Although a few articles reported how many women had which type of ultrasound, none of the articles reported their results such as to permit a stratification by TVUS or abdominal ultrasound. We therefore elected to group all ultrasound studies together regardless of TVUS or abdominal imaging.

Trials identified. We identified 69 articles comprising 73 ultrasound morphology assessments. Despite the availability of published scoring systems, most of the studies based their diagnoses on either descriptive assessments of adnexal masses or used a modified or unique scoring system. Only 13 studies explicitly used Sassone's criteria, six used DePriest's, and three used Ferrazzi's, Finkler's, Lerner's, and Valentin's respectively. When a scoring system other than an established criterion was used, it was not always clear how it had been developed or modified. Details of the tests and their evaluative performance are provided in Table 10. Assessments of adnexal morphology by ultrasound which were either a unique or modified or unclear scoring system are labeled “other” with a brief description when possible. It is also important to note that not all of the established scoring systems were employed using the original cutpoints. For example, Caruso et al.^83^ and Itakure et al.^115^ both used a cutpoint of > 7 for the DePriest scoring system, where the original description used ≥ 5.

Table 10 Sensitivity and specificity of ultrasound morphology

Scoring system | Pooled sensitivity (95% CI) | Pooled specificity (95% CI) | Range of sensitivity in individual studies | Range of specificity in individual studies | References
Sassone | 0.86 (0.79 to 0.91) | 0.77 (0.73 to 0.81) | 0.65 to 1.00 | 0.65 to 0.93 | ^43,^ ^54,^ ^68,^ ^69,^ ^83,^ ^93,^ ^130,^ ^131,^ ^154,^ ^159,^ ^160,^ ^163,^ ^179,^ ^193,^ ^199^
DePriest | 0.91 (0.84 to 0.95) | 0.68 (0.49 to 0.82) | 0.88 to 1.00 | 0.40 to 0.81 | ^35,^ ^36,^ ^69,^ ^83,^ ^93,^ ^115^
Ferrazzi | 0.87 (0.80 to 0.92) | 0.81 (0.62 to 0.91) | 0.84 to 0.87 | 0.67 to 0.88 | ^69^ ^75^ ^93^
Finkler | 0.82 (0.65 to 0.91) | 0.78 (0.59 to 0.91) | 0.52 to 0.88 | 0.55 to 0.70 | ^56,^ ^62,^ ^63^
Other (note: significant heterogeneity in criteria used for diagnosis - see ROC curve) | 0.86 (0.82 to 0.89) | 0.83 (0.76 to 0.88) | 0.43 to 1.00 | 0.29 to 1.00 | ^33,^ ^34,^ ^39,^ ^42,^ ^43,^ ^67,^ ^69,^ ^74,^ ^76^–^80,^ ^87,^ ^90,^ ^95,^ ^97,^ ^101,^ ^102,^ ^104,^ ^106,^ ^108,^ ^112,^ ^117,^ ^118,^ ^122,^ ^124^–^127,^ ^133^–^135,^ ^138^–^140,^ ^142,^ ^144,^ ^146,^ ^147,^ ^155,^ ^161,^ ^166,^ ^168,^ ^169,^ ^171,^ ^180,^ ^181,^ ^185,^ ^187,^ ^188,^ ^192,^ ^195^

Abbreviations: CI = confidence interval; ROC = receiver operating characteristic

Results. The results of pooled sensitivity and specificity using a random-effects model, along with the range of sensitivity and specificity reported in individual studies, are shown in Table 10. Included studies are shown in Figures 6–10. There was a great range in test results, especially in the studies not using established scoring systems. This most likely reflects the heterogeneity of the tests themselves. There was little concrete difference among the established scoring systems. Overall the tests achieved relatively higher levels of sensitivity and negative predictive value (NPV) in the diagnosis of malignancy than specificity or positive predictive value (PPV). With the exception of four studies, the NPV was above 0.80, with the majority of tests above 0.90. The PPV in the majority of studies was below 0.50. In general, there was a trade-off between sensitivity and specificity, both in the individual studies of a specific scoring system, and in pooled results of all studies of a scoring system - as sensitivity increases, specificity decreases.

Figure 8. Performance of ultrasound scoring according to Ferrazzi's criteria (1997)

Key to Figure 8: 1 = Ferrazzi et al., 1997;^93^ 2 = Berlanda et al., 2002;^75^ 3 = Alcazar et al., 2003^69^

Figure 9. Performance of ultrasound scoring according to Finkler's criteria (1988)

Key to Figure 9: 1 = Schutter et al., 1994;^62^ 2 = Schutter et al., 1998;^63^ 3 = Finkler et al., 1988^56^

Figure 6. Performance of ultrasound scoring according to Sassone's criteria (1991)

Key to Figure 6: 1 = Lerner et al., 1994;^131^ 2 = Ferrazzi et al., 1997;^93^ 3 = Sawicki et al., 2001;^160^ 4 = Rehn et al., 1996;^154^ 5 = Sassone et al., 1991;^159^ 6 = Caruso et al., 1996;^83^ 7 = Leeners et al., 1996;^130^ 8 = Alcazar and Lopez-Garcia, 2001;^68^ 9 = Alcazar et al., 2003;^69^ 10 = Timor-Tritsch et al., 1993;^179^ 11 = Zanetta et al., 1994;^193^ 12 = Alcazar et al., 1996;^199^ 13 = Schneider et al., 1993;^43^ 14 = Buckshee et al., 1998;^54^ 15 = Sengoku et al., 1994^163^

Figure 10. Performance of ultrasound scoring according to various other unvalidated criteria

Key to Figure 10: 1 = DePriest et al., 1997;^34^ 2 = Marchetti et al., 2002;^140^ 3 = Tailor et al., 2003;^171^ 4 = Ekerhovd et al., 2001;^90^ 5 = Canis et al., 1997;^80^ 6 = Wakahara et al., 2001;^187^ 7 = Maggino et al., 1994;^135^ 8 = Schelling et al., 2000;^161^ 9 = Roman et al., 1997;^42^ 10 = Brown et al., 1998;^77^ 11 = Granberg et al., 1990;^101^ 12 = Hermann et al., 1987;^108^ 13 = Kurjak and Predanic, 1992;^125^ 14 = Tingulstad et al., 1996;^180^ 15 = Stein et al., 1995;^168^ 16 = Torres et al., 2002;^181^ 17 = Manjunath et al., 2001;^139^ 18 = Ma et al., 2003;^134^ 19 = Valentin et al., 2001;^185^ 20 = Franchi et al., 1995;^95^ 21 = Merce et al., 1998;^146^ 22 = Davies et al., 1993;^87^ 23 = Morgante et al., 1999;^147^ 24 = Benjapibal et al., 2003;^74^ 25 = Gadducci et al., 1988;^97^ 26 = Buy et al., 1996;^79^ 27 = Strigini et al., 1996;^169^ 28 = Luxman et al., 1991;^133^ 29 = Kurjak et al., 1994;^127^ 30 = Huber et al., 2002;^112^ 21 = Reles et al., 1997;^155^ 32 = Mancuso et al., 2004;^138^ 33 = Kurjak et al., 2000;^124^ 34 = Alcazar et al., 2003;^69^ 35 = Kurjak et al., 1992;^126^ 36 = Komatsu et al., 1996;^122^ 37 = Yamashita et al., 1995;^192^ 38 = Sohaib et al., 2005^166^ 39 = Cohen et al., 2001;^33^ 40 = Medl et al., 1995;^144^ 41 = Hata et al., 1992;^106^ 42 = Schneider et al., 1993;^43^ 43 = Weiner et al., 1992;^188^ 44 = Jain = 1994^117^ 45 = Buist et al., 1994^78^ 46 = Alcazar et al., 2003^67^ 47 = Lin et al., 1993^39^ 48 = Jain et al., 1993;^118^ = Bromley et al., 1994;^76^ 50 = Zimmer et al., 2003^195^

Comparing the figures, studies using the Sassone criteria show greater variability in sensitivity compared to variability in specificity (Figure 6), while those using the DePriest criteria (Figure 7) show greater variability in specificity and a relatively narrow range of sensitivity. Figure 10, which depicts a variety of other studies, suggests trade-offs between sensitivity and specificity; different morphology methods for discriminating benign from malignant have different thresholds, resulting in the sensitivity/specificity trade-off.

Figure 7. Performance of ultrasound scoring according to DePriest's criteria (1993)

Key to Figure 7: 1 = Ferrazi et al., 1997;^93^ 2 = Caruso et al., 1996;^83^ 3 = DePriest et al., 1993;^35^ 4 = Alcazar et al., 2003;^69^ 5 = Itakura et al., 2003;^115^ 6 = DePriest et al., 1993^36^

Three articles compared different scoring systems within the same study population. Caruso et al.^83^ examined 112 women with adnexal masses comparing Sassone, DePriest, and Valentin scores. All performed similarly, displaying a sensitivity and NPV of 1.00, a range of specificity of 0.61 to 0.75, and a range of PPV of 0.35 to 0.48. Alcazar et al.^69^ also compared the performance of Sassone, DePriest, and Ferrazzi. There were no significant differences between these scoring systems when receiver operating characteristic (ROC) curves were compared. The area under the curve (AUC) was 0.89 for Sassone, 0.92 for DePriest, and 0.90 for Ferrazzi. Ferrazzi et al.^93^ evaluated 261 masses collected in three different centers. They compared ROC curves for scores based on Sassone, Granberg, DePriest, and Lerner's criteria and compared it with a scoring system they developed. The AUC ranged from 0.72 to 0.75 for the previously established systems. Their new scoring system (Ferrazzi) performed better, with an AUC of 0.84 (p < 0.0001). However, subsequent comparisons have not reaffirmed its superior functioning. When the Ferrazzi scoring system was compared to both Sassone and DePriest,^69^ its performance was almost identical.

In spite of different designs, all the scoring systems performed similarly when compared within the same study population. It has been suggested that the poor performance of scoring systems with regard to their PPV is due to the misclassification of dermoid tumors.^197^ Dermoids share many of the features that are characterized as “malignant” in scoring systems. The Alcazar study proposes a scoring system that was developed in part to correct this. Although this scoring system does perform well in its initial application, it has not been independently verified. The authors conclude, “a completely reliable differentiation of malignant masses cannot be obtained by sonographic imaging alone.”^69^

Stratification by menopausal status. Of the 69 articles identified that addressed the assessment of adnexal morphology by ultrasound, only 13 contained data that either directly reported test characteristics by menopausal status or contained enough information to enable the stratification of results. Six were studies in a 100 percent postmenopausal patient population. Seven were studies that allowed comparison by menopausal status within the study population. They are presented in Table 11. The only significant difference in test performance appears to be in regards to the PPV. With the exception of Roman et al.,^42^ the PPV is slightly higher in postmenopausal women. This likely reflects the higher prevalence of ovarian malignancy after menopause. Aside from the PPV, the performance of ultrasound in the morphological assessment of adnexal masses does not appear to be significantly changed by menopausal status.

Table 11 Ultrasound morphology assessment comparing pre- and postmenopausal status

Study | Scoring System | Premenopausal | | | | Postmenopausal
| | Sens | Spec | PPV | NPV | Sens | Spec | PPV | NPV
Finkler et al., 1988^56^ | Finkler | 0.50 | 0.96 | 0.50 | 0.77 | 0.78 | 0.92 | 0.94 | 0.75
Franchi et al., 1995^95^ | Descriptive | 0.73 | 0.86 | 0.44 | 0.95 | 0.89 | 0.75 | 0.82 | 0.83
Guerriero et al., 2002^105^ | Descriptive | 0.98 | 0.89 | 0.44 | 1.00 | 1.00 | 0.51 | 0.52 | 1.00
Reles et al., 1997^155^ | Modified score | 1.00 | 0.79 | 0.46 | 1.00 | 0.87 | 0.89 | 0.77 | 0.94
Roman et al., 1997^42^ | Descriptive | 0.93 | 0.92 | 0.66 | 0.99 | 0.81 | 0.62 | 0.54 | 0.86
Schelling et al., 2000^161^ | Descriptive | 0.91 | 0.84 | 0.29 | 0.99 | 1.00 | 0.73 | 0.62 | 1.00
Alcazar et al., 2003^69^ | Sassone | 1.00 | 0.88 | 0.50 | 1.00 | 0.61 | 0.88 | 0.81 | 0.73
| DePriest | 1.00 | 0.80 | 0.38 | 1.00 | 1.00 | 0.82 | 0.82 | 1.00
| Ferrazzi | 1.00 | 0.84 | 0.43 | 1.00 | 0.82 | 0.82 | 0.79 | 0.85
| Alcazar | 1.00 | 0.96 | 0.75 | 1.00 | 1.00 | 0.94 | 0.93 | 1.00
Menon et al., 2000^145^ | Descriptive | - | - | - | - | 1.00 | 0.94 | 0.24 | 1.00
Schutter et al., 1994^62^ | Finkler | - | - | - | - | 0.88 | 0.64 | 0.65 | 0.88
Bromley et al., 1994^76^ | Unique scoring | - | - | - | - | 0.91 | 0.52 | 0.52 | 0.92
Schutter et al., 1998^63^ | Finkler | - | - | - | - | 0.86 | 0.70 | 0.65 | 0.89
Luxman et al., 1991^133^ | Descriptive | - | - | - | - | 0.93 | 0.55 | 0.45 | 0.95
Kuriak et al., 1992^126^ | Unique scoring | - | - | - | - | 0.48 | 0.98 | 0.93 | 0.78

Abbreviations: NPV = negative predictive value; PPV = positive predictive value; Sens = sensitivity; Spec = specificity

### Ultrasound Doppler Studies

Color Doppler scanning allows the assessment of tumor vascularity. Malignant neoplasms have active blood vessel creation (angiogenesis) compared to normal or benign neoplasms due, in part, to their increased metabolic activity. Overall, malignancies display an increased vascularity with decreased peripheral blood flow resistance and increased blood flow velocity compared with benign tissue.^152,^ ^200^ Doppler signal analysis can separate high-resistance and low-resistance vessels and has therefore been investigated as a separate test modality, as well as in combination with ultrasound morphological evaluation in the evaluation of adnexal masses.

The most common flow criteria are the resistance index (RI), the pulsatility index (PI), and the maximum systolic velocity. RI is defined as the difference between peak systolic and maximum enddiastolic flow velocity, divided by peak systolic flow velocity. Usually the lowest measured RI from a series of measurements is reported from different arteries. PI is defined as the difference between peak systolic and enddiastolic flow velocity, divided by the time-averaged flow velocity. The maximum systolic velocity is the maximum flow recorded in any visualized artery.

In order to make a measurement of either RI or PI or maximum systolic velocity, an artery must be identified on ultrasound. The inability to identify an artery in the mass means that the test cannot be performed. Therefore, not every individual included in the study population is captured with the assessment of these color Doppler modalities. Another limitation of these measurements is that the range observed in malignant masses overlaps with that observed in benign masses. For example, in Lin et al.,^132^ discussed in more detail below, the RI for malignant masses ranged from 0.23 to 0.82. Although they did not report a range for the benign masses, there were eight benign tumors with a RI < 0.4. This overlap limits the effectiveness of any threshold and, perhaps, contributes to the different thresholds reported in the literature.

Reproducibility of tests. Timmerman et al.^196^ (discussed above under ultrasound morphology) included Doppler measurements in its analysis of interobserver variability and experience. In short, operators with more experience (300 versus 15,000 scans) had greater accuracy (92 percent versus 82 to 87 percent, p = 0.0001). Interassessor agreement was also greater between the most experienced operators (kappa = 0.852) compared with the less experienced operators (range 0.581 to 0.737). None of the articles evaluating color Doppler described operator experience, nor did any address interobserver variability specifically in regards to Doppler measurement.

Trials identified. Fifty-six articles were identified that described color Doppler analysis, comprising a description of 65 tests. Thirty-two articles evaluated RI, 20 PI, and six the maximum systolic velocity. These are the most common flow criteria measured in the literature and presumably in clinical practice as well. Other Doppler parameters were described in the literature sometimes in conjunction with either RI or PI or maximum systolic velocity but were not included in this table. The other articles included 10 that involved the visualization of flow within the mass,^70,^ ^71,^ ^104,^ ^105,^ ^119,^ ^137,^ ^160,^ ^161,^ ^168,^ ^182^ two that involved counting the total number of arteries (either > 4^152^ or > 3^199^), and one that measured the absence of a diastolic notch.^137^

Results. Table 12 details the test characteristics of RI, PI, and the maximum systolic velocity in the evaluation of an adnexal mass, again using pooled values from a random-effects model. For RI the range reported was from ≤ 0.8 to < 0.4, with < 0.4 being the most common. For PI the range was relatively narrower from < 1.5 to < 1.0 with the majority of studies using either ≤ 1.0 or < 1.0. The reported range was greatest in the assessment of maximum systolic velocity, where there were also the fewest studies from > 30 cm/second to > 10 cm/second. As the threshold for RI decreases from ≤ 0.8 to < 0.4, the sensitivity and NPV decrease, and the specificity and PPV increase. This is seen most clearly in studies that evaluated a series of RI cutpoints with the same study population.^132,^ ^176^

Table 12 Sensitivity and specificity of Doppler studies

Doppler method | Pooled sensitivity (95% CI) | Pooled specificity (95% CI) | Range of sensitivity in individual studies | Range of specificity in individual studies | References
Resistance index | 0.76 (0.68 to 0.73) | 0.89 (0.84 to 0.92) | 0.19 to 1.00 | 0.53 to 1.00 | ^43,^ ^68,^ ^70,^ ^75,^ ^76,^ ^79,^ ^81,^ ^86,^ ^88,^ ^95,^ ^106,^ ^107,^ ^117,^ ^124^–^126,^ ^128,^ ^130,^ ^132,^ ^141,^ ^146,^ ^152,^ ^168,^ ^172,^ ^175,^ ^176,^ ^179,^ ^184,^ ^190,^ ^193,^ ^199,^ ^201,^
Pulsatility index | 0.79 (0.73 to 0.83) | 0.74 (0.64 to 0.81) | 0.57 to 0.95 | 0.32 to 0.97 | ^73,^ ^79,^ ^81,^ ^94,^ ^103,^ ^109,^ ^115,^ ^120,^ ^154,^ ^155,^ ^158,^ ^163,^ ^168,^ ^169,^ ^179,^ ^182,^ ^184,^ ^188,^ ^199,^ ^201^
Maximum systolic velocity | 0.76 (0.61 to 0.86) | 0.83 (0.66 to 0.93) | 0.48 to 0.94 | 0.43 to 0.97 | ^68,^ ^79,^ ^107,^ ^109,^ ^152,^ ^199^

Lin et al.^132^ evaluated 370 women with adnexal masses who were scheduled for surgery at a single institution. They reported outcomes based on RI cutpoints of 0.4, 0.5, and 0.6. For RI < 0.4, the sensitivity, specificity, PPV, and NPV were 0.69, 0.97, 0.89, and 0.91, respectively. For RI < 0.5, they were 0.79, 0.92, 0.77, and 0.93. And for < 0.6, they were 0.91, 0.86, 0.68, and 0.98. The authors conclude that the 0.4 cutpoint yields the highest concordance rate between Doppler prediction and histopathologic diagnosis. This conclusion, however, is based more on clinical impression, as ROC curve analysis was not performed.

The range of Doppler study performance is listed in Table 12 and shown in Figures 11–13. Overall there was great heterogeneity of performance results. The range of sensitivity was largest for RI. This range did not appear to be secondary to differences in RI thresholds; however, the < 0.4 threshold did appear to narrow specificity results. In spite of the large variation in thresholds described for maximum systolic velocity, the range of test characteristics was somewhat narrower than that for RI, probably because there were fewer studies identified that used this measurement. Again, there is a trade-off between sensitivity and specificity, although this appears greatest for maximum velocity.

Figure 12. Performance of Doppler ultrasound pulsatility index

Key to Figure 12: 1 = Rehn et al., 1996;^154^ 2 = Guerriero et al., 1998;^103^ 3 = Valentin, 2000;^184^ 4 = Stein et al., 1995;^168^ 5 = Itakure et al., 2003;^115^ 6 = Valentin, 1999;^201^ 7 = Valentin, 1997^182^ 8 = Carter et al., 1995^81^ 9 = Buy et al., 1996;^79^ 10 = Benjapibal et al., 2002;^73^ 11 = Kawai et al., 1994;^120^ 12 = Strigini et al., 1996;^169^ 13 = Hillaby et al., 2004;^109^ 14 = Salem et al., 1994;^158^ 15 = Timor-Tritsch et al., 1993;^179^ 16 = Reles et al., 1997;^155^ 17 = Alcazar et al., 1996;^199^ 18 = Fleischer et al., 1992;^94^ 19 = Weiner et al., 1992;^188^ 20 = Sengoku et al., 1994^163^

Figure 11. Performance of Doppler ultrasound resistance index

Key to Figure 11: 1 = Kurjak et al., 1991;^128^ 2 = Wu et al., 1994;^190^ 3 = Lin et al., 1993;^132^ 4 = DePriest et al., 1994;^88^ 5 = Prompeler et al., 1996;^152^ 6 = Tepper et al., 1995;^176^ 7 = Kurjak and Predanic, 1992;^125^ 8 = Valentin, 2000;^184^ 9 = Stein et al., 1995;^168^ 10 = Anandakumar et al., 1996;^70^ 11 = Valentin, 1996^201^ 12 = Franchi et al., 1995;^95^ 13 = Merce et al., 1998;^146^ 14 = Carter et al., 1995;^81^ 15 = Takac, 1998;^172^ 16 = Buy et al., 1996;^79^ 17 = Leeners et al., 1996;^130^ 18 = Chou et al., 1994;^86^ 19 = Hata et al., 1995;^107^ 20 = Marret et al., 2004;^141^ 21 = Kurjak et al., 2000;^124^ 22 = Kurjak et al., 1992;^126^ 23 = Timor-Tritsch et al., 1993;^179^ 24 = Zanetta et al., 1994;^193^ 25 = Tekay and Jouppila, 1992;^175^ 26 = Alcazar et al., 1996;^199^ 27 = Hata et al., 1992;^106^ 28 = Schneider et al., 1993;^43^ 29 = Berland et al., 2002;^75^ 30 = Alcazar and Lopez-Garcia, 2001;^68^ 31 = Jain, 1994;^117^ 32 = Bromley et al., 1994^76^

Figure 13. Performance of Doppler ultrasound velocity indices

Key to Figure 13: 1 = Prompeler et al., 1996;^152^ 2 = Buy et al., 1996;^79^ 3 = Hillaby et al., 2004;^109^ 4 = Alcazar et al., 1996;^199^ 5 = Alcazar and Lopez-Garcia, 2001^68^

Table 13 compares the characteristics of Doppler studies that did not use measurement or calculation of Doppler waveforms. They relied instead on either the presence of vascularity within the mass (yes/no) or on a direct count of vessels seen. These tests seem to perform as well as the RI or PI in terms of sensitivity, although specificity varies quite widely (Figure 13). Valentin^182^ measured both the PI (< 1.0) and the presence of color lakes visible on Doppler in the same study population. Of 151 patients, PI was measured in 135, indicating that for 16 individuals, no artery was visualized within the mass. The sensitivity reported for the PI was 0.83, specificity 0.34, PPV 0.20, and NPV 0.91. Simply documenting the presence or absence of visible color lakes on Doppler yielded a sensitivity of 0.88, a specificity of 0.67, a PPV of 0.33, and a NPV of 0.97. Not only did the direct visualization test perform better, but because its outcome was a simple binary outcome (present or absent), the results included the entire study population (n = 151). Prompeler et al.^152^ measured RI, maximum systolic velocity, as well as the number of arteries visualized in the mass. Their data for the simple counting of arteries also performs as well if not better than the calculated tests such as RI or PI. In a random-effects model, pooled sensitivity for the presence or absence of blood flow within a mass was 0.88 (95% CI, 0.80 to 0.92) and pooled specificity 0.78 (95% CI, 0.65 to 0.87)

Table 13 Study characteristics of simple Doppler visualization

Study (N) | Test | Sensitivity | Specificity
Prompeler et al., 1996^152^ (212) | Total number of arteries > 4 (postmenopausal women only) | 0.82 | 0.92
Valentin, 1997^182^ (151) | Color lakes visible on Doppler | 0.88 | 0.67
Maly et al., 1995^137^ (102) | Demonstrable blood vessels | 0.95 | 0.30
Schelling et al., 2000^161^ (257) | Central vascularity on Doppler in solid component | 0.93 | 0.94
Stein et al., 1995^168^ (170 masses) | Internal flow within solid component or septation | 0.77 | 0.69
Guerriero et al., 2002^105^ (826 masses) | Arterial flow visualized in an echogenic structure or irregular solid portion | 0.95 | 0.92
Anandakumar et al., 1996^70^ (146) | “Continuously fluctuating” vessels with turbulent flow | 0.77 | 0.68
Antonic and Rakar, 1995^71^ (71) | Color flow present | 0.89 | 0.47
Guerriero et al., 2005^104^ (424) | Color flow present in “echogenic structure” | 1.00 | 0.91
Juhasz et al., 1990^119^ (147) | Color flow present in mass | 0.96 | 0.84

Figure 14. Performance of Doppler ultrasound for intratumoral blood flow

Key to Figure 14: 1 = Guerriero et al., 2005;^104^ 2 = Schelling et al., 2000;^161^ 3 = Prompeler et al., 1996;^152^ 4 = Stein et al., 1995;^168^ 5 = Valentin, 1997;^182^ 6 = Maly et al., 1995;^137^ 7 = Anandakumar et al., 1996;^70^ 8 = Antonic and Rakar, 1995^71^

Stratification by menopausal status. Out of a total of 56 studies identified that evaluated color Doppler, only 11 contained data that either directly reported test characteristics by menopausal status or contained enough information to enable the stratification of results. Two of these studies were in a 100 percent postmenopausal population, and nine enabled comparison by menopausal status within the same study population (Table 14). When comparing test performance within the same study population stratified by menopausal status, the PPV of the test is significantly increased in the postmenopausal group. In Salem et al.,^158^ the PPV increased only from 0.20 in the premenopausal group to only 0.47 in the peri- and postmenopausal group. This may be a reflection of how they defined peri- and postmenopause (which was not clearly stated by the authors). After stratifying the reported results by age (> 45), the PPV is 0.73. This increase in PPV among postmenopausal women appears to be greater in the context of Doppler studies than that observed with ultrasound morphology. This finding differs from the one meta-analysis on the subject. Kinkel et al.^197^ did a systematic review of both ultrasound morphology and Doppler in the detection of malignant masses. Although they noted a difference in outcomes dependent on menopausal status, this difference did not reach statistical significance. Interestingly, there was a difference in terms of Doppler test performance by year of publication with better results demonstrated by earlier studies (p = 0.005), a result that was independent of sample size.

Table 14 Doppler studies stratified by menopausal status

Study (N) | Test | Premenopausal | | | | Postmenopausal
| | Sens | Spec | PPV | NPV | Sens | Spec | PPV | NPV
Franchi et al., 1995^95^ (129) | RI < 0.65 | 0.82 | 0.72 | 0.31 | 0.96 | 0.86 | 0.75 | 0.82 | 0.83
Guerriero et al., 2002^105^ (826 masses) | Arterial flow visualized in echogenic structure or irregular solid portion | 0.94 | 0.96 | 0.67 | 1.00 | 0.96 | 0.77 | 0.69 | 0.97
Reles et al., 1997^155^ (98) | PI ≤ 1.1 | 0.80 | 0.67 | 0.36 | 0.93 | 0.93 | 0.83 | 0.76 | 0.91
Schelling et al., 2000^161^ (257) | Presence of central vascularization on Doppler | 0.91 | 0.94 | 0.53 | 0.99 | 0.93 | 0.92 | 0.84 | 0.97
Prompeler et al., 1996^152^ (212) | Total number of arteries > 4 | 0.85 | 0.71 | 0.36 | 0.96 | 0.82 | 0.82 | 0.76 | 0.86
| RI > 0.5 | 0.84 | 0.47 | 0.23 | 0.94 | 0.82 | 0.69 | 0.66 | 0.84
| Maximum systolic velocity > 30cm/s | 0.92 | 0.65 | 0.33 | 0.98 | 0.76 | 0.88 | 0.82 | 0.84
Strigini et al., 1996^169^ (109) | PI < 1 | 0.83 | 0.73 | 0.21 | 0.98 | 0.85 | 0.81 | 0.73 | 0.90
Salem et al., 1994^158^ (109 masses) | PI < 1 | 1.00 | 0.84 | 0.20 | 1.00 | 0.73 | 0.71 | 0.47 | 0.88
Szpurek et al., 2004^170^ (464) | Doppler subjective index ≥ 4 | 0.82 | 0.93 | 0.79 | 0.94 | 0.92 | 1.00 | 1.00 | 0.82
Kurjak et al., 1992^126^ (83) | RI < 0.41 | - | - | - | - | 0.96 | 0.95 | 0.90 | 0.98
| randomly separate vessels | - | - | - | - | 0.90 | 0.98 | 0.96 | 0.95
Bromley et al., 1994^76^ (33) | RI < 0.6 | - | - | - | - | 0.66 | 0.81 | 0.67 | 0.81
Antonic and Rakar, 1995^71^ (71) | Presence of color flow | 1.00 | 0.36 | 0.11 | 1.00 | 0.87 | 0.79 | 0.81 | 0.85
Guerriero et al., 1998^103^ (192 masses) | PI ≤ 1 | 0.86 | 0.46 | 0.08 | 0.98 | 0.88 | 0.52 | 0.66 | 0.81

Abbreviations: NPV = negative predictive value; PI = pulsatility index; PPV = positive predictive value; RI = resistance index; Sens = sensitivity; Spec = specificity

### Combined Ultrasound Morphology and Doppler

A limiting feature of ultrasound morphologic assessments has been felt to be the high rate of false positive test results.^196^ Color Doppler, in contrast, has displayed a slightly higher PPV, especially in the earlier studies.^197^ There have, therefore, been attempts to combine ultrasound morphology and Doppler studies in a single test.

Trials identified. Of all the articles that investigated the use of either ultrasound morphology or color Doppler in the evaluation of an adnexal mass, nine articles containing a total of 13 tests described a combination ultrasound morphology and Doppler modality.^65,^ ^79,^ ^91,^ ^100,^ ^123^–^125,^ ^130,^ ^201^

Results. There is a large range in the reported study performance (sensitivity ranges from 0.71 to 0.98, specificity from 0.6 to 1.0. The relevant studies are shown in Figure 15; all but two had both sensitivity and specificity above 0.80. Pooled sensitivity in a random-effects model was 0.89 (95% CI, 0.81 to 0.93) and pooled specificity 0.91 (0.80 to 0.96). Both of these values were higher than the pooled values for any morphology or Doppler method alone.

Figure 15. Performance of combined ultrasound morphology and color Doppler

Key to Figure 15: 1 =Kurjak and Predanic, 1992;^125^ 2 =Valentin, 1999;^201^ 3 =Kurjak and Kupesic, 1999;^123^ 4 =Buy et al., 1996;^79^ 5 =Leeners et al., 1996;^130^ 6 =Grab et al., 2000;^100^ 7 =Fenchel et al., 2002;^91^ 8 =Kurjak et al., 2000;^124^ 9 = Alcazar and Castillo, 2005^65^

Stratification by menopausal status. There were two studies that analyzed combined ultrasound morphology and Doppler in 100 percent post menopausal patient populations. Kurjak et al.^126^ reported a combined sensitivity, specificity, PPV, and NPV of 0.90, 0.94, 0.90, and 0.94, respectively. Their combined test consisted of RI < 0.41 and an ultrasound morphology scoring system unique to them. Veunto et al.^186^ in a population-based screening study reported a sensitivity, specificity, PPV, and NPV of 1.00, 0.83, 0.006, and 1.00, respectively. Given that these two studies are of greatly different design, it is hard to compare them directly. Comparing Kurjak et al. to the range of combined ultrasound and Dopper studies, it appears that in the postmenopausal group, the test has a better performance. However, this test performance may reflect patient selection criteria for the study that was not clearly explained. Combination modalities as a screening tool for ovarian cancer had a high false positive rate (as seen in the PPV of 0.006^186^).

### 3D Versus 2D Ultrasound

We identified five studies that analyzed 3D ultrasound. Four are listed in Table 15. The fifth, by Cohen et al.,^33^ was not included because it compared 2D ultrasound with 2D plus some component of a 3D exam (possibly 3D Doppler) that was not clearly stated in the article. Overall, 3D ultrasound appears superior to 2D especially in regards to sensitivity and PPV performance. We were unable to stratify these results by menopausal status. Test reliability and variability were not addressed specifically in terms of 3D ultrasound.

Table 15 3D versus 2D ultrasound

Study (number of persons) | Test | Sensitivity | Specificity | PPV | NPV
Alcazar et al., 2003^67^ (41 masses) | 2D | 0.90 | 0.61 | 0.68 | 0.88
| 3D | 1.00 | 0.78 | 0.81 | 1.00
| Presence of one of the following fulfilled criteria for mass: > 3 mm wall, > 3 mm septum, > 3 mm papillary projections, solid areas or echogenicity
Kurjak and Kupesic, 1999^123^ (120) | 2D | 0.91 | 0.97 | 0.77 | 0.99
| 3D | 1.00 | 0.99 | 0.92 | 1.00
| Both used a unique scoring system that included Doppler measurements
Kurjak et al., 2000^124^ (90) | 2D morphology | 0.67 | 0.94 | 0.55 | 0.96
| 2D Doppler | 0.89 | 0.95 | 0.67 | 0.99
| 2D combined | 0.89 | 0.98 | 0.80 | 0.99
| 3D morphology | 0.78 | 0.98 | 0.78 | 0.98
| 3D Doppler | 0.89 | 0.98 | 0.80 | 0.99
| 3D combined | 1.00 | 0.99 | 0.99 | 1.00
| Both used a unique scoring system for morphological assessment. Doppler for 2D was RI ≤ 0.42, for 3D it was “complex” “chaotic” vessel arrangement
Alcazar and Castillo, 2005^65^ (69 masses) | 2D | 0.98 | 0.88 | 0.94 | 0.96
| 3D | 0.98 | 0.79 | 0.90 | 0.95
| Presence of at least one of the following fulfilled criteria for “complex mass”: >3mm wall, > 3 mm papillary projection, solid areas or purely solid echogenicity Doppler flow in mass also used in test but unclear how

Abbreviations: 2D = two-dimensional; 3D = three-dimensional; NPV = negative predictive value; PPV = positive predictive value

### Other Imaging Modalities

Although ultrasound remains the most common imaging modality in the evaluation and diagnosis of adnexal masses, newer technologies such as MRI, CT, and positron emission tomography (PET) have been studied as well. These modalities may not be as readily available to the clinician as ultrasound, and there is less literature devoted to them than to ultrasound; however, they are included in this review because of growing interest both clinical and research in their use. Further, despite refinements in ultrasound morphology scoring systems or Doppler measurements, the overall performance of ultrasound in the evaluation of the adnexal mass may be relatively fixed by the technology itself. Therefore it is necessary to investigate other imaging modalities and see how they compare with ultrasound.

Reproducibility of tests. Unlike ultrasound, MRI, CT, and PET images are not operator dependent in terms of obtaining the images. There is, however, the potential for interobserver variability in their analysis. There are no standardized morphological scoring systems for any imaging modality other than ultrasound. We identified two articles that directly addressed the issue of test reproducibility for either MRI and/or CT in the evaluation of adnexal masses. Buist et al.,^78^ however, reported a series of 64 women who were evaluated by both MRI and CT and reviewed by two different radiologists. They reported a kappa value for the interobserver reliability for distinguishing between benign and malignant disease of 0.28 for CT and 0.41 for MRI. Yamashita et al.^192^ also calculated kappa values for interobserver variability among five radiologists. They showed far greater agreement: for precontrast MRI, kappa = 0.71 (± 0.02); for contrast-enhanced MRI, kappa = 0.73 (± 0.02).

Trials identified. We identified 17 articles comprising 22 tests. There were 15 articles for MRI, three for CT, and three for PET and one that used a combined CT/MRI test. There were two articles that investigated nuclear medicine technologies in the evaluation of adnexal masses. These, however, were not included in the review given the experimental nature of such tests at this time. The PET studies were all performed also using tracer 18-Fluorodeoxyglucose (FDG) with the test measuring uptake of FDG in the lesion.

Results. The results of MRI, CT, and PET modalities are summarized in Table 16. All of the articles describing CT and PET and most of the articles describing MRI either used descriptive criteria for differentiating malignant from benign appearing lesions or did not report the criteria used. Only two articles for MRI used a scoring system, slightly different from each other, which increases the difficulty in comparing studies. To date, there are no standardized scoring systems for any imaging modality other than ultrasound.

Table 16 Sensitivity and specificity of other imaging modalities

Imaging modality | Pooled sensitivity (95% CI) | Pooled specificity (95% CI) | Range of sensitivity in individual studies | Range of specificity in individual studies | References
MRI | 0.91 (0.86 to 0.94) | 0.87 (0.83 to 0.90) | 0.67 to 1.00 | 0.77 to 1.00 | ^44,^ ^78,^ ^91,^ ^100,^ ^106,^ ^111,^ ^112,^ ^118,^ ^121,^ ^122,^ ^129,^ ^144,^ ^156,^ ^166,^ ^192,^
CT | 0.90 (0.83 to 0.94) | 0.75 (0.36 to 0.94) | 0.86 to 0.96 | 0.35 to 0.89 | ^39,^ ^78,^ ^129^
FDG-PET | 0.67 (0.52 to 0.79) | 0.79 (0.70 to 0.85) | 0.58 to 0.78 | 0.76 to 1.00 | ^91,^ ^100,^ ^121^

Abbreviations: CI = confidence interval; CT = computed tomography; FDG = 18-Fluorodeoxyglucose; MRI = magnetic resonance imaging; PET = positron emission tomography

The range of test performance of MRI, CT, and PET are shown in Table 16. Table 17 includes, for comparison, the test performance for ultrasound morphology, color Doppler (all the modalities), and ultrasound morphology and Doppler combined. Tian et al.^177^ was excluded from this table because there was no description how CT and MRI were combined for a single test result (in series versus in parallel). Overall the sensitivity for MRI, CT, and PET are similar to that of combined ultrasound morphology and Doppler and less heterogenous than either modality separate. The specificity, however, is equivalent to either test separate and wider than the tests combined, with the exception of FDG-PET. However, the comparatively narrow range of both CT and PET results could be secondary to the relatively few studies that use these modalities. There is a large range of results for PET PPVs and a small range for CT, again possibly reflecting the paucity of studies. The range of NPVs for MRI is comparable to that for combined ultrasound morphology and Doppler and better than either CT or PET. Overall MRI appears similar in performance to combined ultrasound. More research is needed to accurately assess the performance range of CT and PET.

Table 17 Comparison of MRI, CT, FDG-PET, and ultrasound

Study (N) | Test | Sensitivity | Specificity | PPV | NPV
Medl et al., 1995^144^ (73) | Ultrasound morphology (descriptive) | 0.81 | 0.73 | 0.79 | 0.76
| MRI descriptive | 0.97 | 0.83 | 0.88 | 0.96
Yamashita et al., 1995^192^ (72 women 80 masses) | Ultrasound morphology (unique score) | 0.89 | 0.84 | 0.63 | 0.96
| MRI precontrast | 0.78 | 0.93 | 0.79 | 0.93
| MRI contrast enhanced | 0.91 | 0.93 | 0.81 | 0.97
Fenchel et al., 2002^91^(99) | Ultrasound combined morphology and Doppler | 0.92 | 0.60 | 0.24 | 0.98
| MRI | 0.83 | 0.83 | 0.40 | 0.97
| FDG-PET | 0.58 | 0.76 | 0.25 | 0.93
Jain et al., 1993^118^ (32) | Ultrasound morphology (descriptive) | 1.00 | 0.60 | 0.18 | 1.00
| MRI | 0.67 | 1.00 | 1.00 | 0.97
Kawahara et al., 2004^121^ (38) | MRI descriptive | 0.91 | 0.87 | 0.91 | 0.87
| FDG-PET | 0.78 | 1.00 | 1.00 | 0.75
Komatsu et al., 1996^122^ (82) | Ultrasound morphology (unique score) | 1.00 | 0.46 | 0.57 | 1.00
| MRI descriptive (n = 59) | 0.91 | 0.88 | 0.91 | 0.88
Lin et al., 1993^39^ (80) | Ultrasound morphology (descriptive) | 0.83 | 0.50 | 0.58 | 0.79
| CT descriptive | 0.86 | 0.36 | 0.74 | 0.56
Buist et al., 1994^78^ (64) | CT reviewer a | 0.96 | 0.44 | 0.72 | 0.89
| CT reviewer b | 0.89 | 0.83 | 0.89 | 0.83
| MRI reviewer a | 0.96 | 0.33 | 0.68 | 0.86
| MRI reviewer b | 0.96 | 0.94 | 0.96 | 0.94
| Ultrasound morphology (NR) | 0.89 | 0.44 | 0.71 | 0.73
Grab et al., 2000^100^ (101) | Ultrasound combination morphology and Doppler | 0.92 | 0.60 | 0.23 | 0.98
| MRI descriptive | 0.83 | 0.84 | 0.42 | 0.97
| FDG-PET | 0.58 | 0.80 | 0.28 | 0.93
Hata et al., 1992^106^ (63) | Ultrasound (NR) | 0.85 | 0.69 | 0.68 | 0.86
| MRI score | 0.67 | 0.97 | 0.95 | 0.80
Huber et al., 2002^112^ (93) | Ultrasound morphology (descriptive) | 0.85 | 0.73 | 0.87 | 0.71
| MRI descriptive | 0.89 | 0.86 | 0.93 | 0.79
Reuter et al., 1998^156^ (65) | Ultrasound morphology (descriptive) | 1.00 | 0.66 | 0.40 | 1.00
| MRI descriptive | 1.00 | 0.78 | 0.50 | 1.00
Sohaib et al., 2005^166^ (72) | Ultrasound morphology (descriptive) | 1.00 | 0.40 | 0.53 | 1.00
| MRI descriptive | 0.97 | 0.84 | 0.80 | 0.97

Abbreviations: CT = computed tomography; FDG = 18-Fluorodeoxyglucose; MRI = magnetic resonance imaging; NR = not reported; PET = positron emission tomography

Another way to compare imaging modalities is by looking at studies that compare imaging modalities within the same study population. These are listed in Table 17. There may be a small benefit in performance of MRI over ultrasound, especially in terms of PPV. There is no evidence to support the superiority of any single modality, although FDG-PET appears inferior to the rest.

Only two studies compared pre- and postcontrast enhancement with MRI.^111,^ ^192^ Contrast enhancement improved evaluative performance in both studies, particularly sensitivity. In Hricak et al. the sensitivity increased from 0.87 to 0.95, specificity from 0.75 to 0.79, PPV from 0.78 to 0.83, and NPV 0.84 to 0.94.^111^ These results are similar to those of Yamashita et al.^192^ in Table 17.

Stratification by menopausal status. None of the studies describing MRI, CT, or PET reported results either by menopausal status or in data that would allow menopausal status to be stratified.

### Serum Markers: CA-125

The concept of using tumor markers as either screening or diagnostic tests for ovarian cancer is dependent upon identifying an abnormal level of a particular marker in serum, reflecting a systemic effect of disease in the ovary. The most extensively investigated ovarian cancer associated antigen is CA-125. This antigen is recognized by a murine monoclonal antibody produced using an ovarian cancer cell line as an immunogen. Elevated levels are detected in approximately 80 percent of ovarian carcinomas at the time of diagnosis;^136,^ ^167^ however, elevated serum levels have also been reported in a variety of benign conditions, potentially affecting specificity. In addition, CA-125 is not as commonly elevated in non-epithelial ovarian cancers. Because these stromal and germ cell tumors are proportionately more common in pre-menopausal women, the sensitivity of CA-125 may it is not as sensitive in premenopausal women.^3^

Reproducibility of tests. Only one study included specific information regarding the inter- and intra-assay coefficients of variation.^66^ They were < 7.5 percent and < 5.3 percent, respectively. The sensitivity of the assay in this study was < 5 U/ml.

Trials identified. We identified 66 studies that investigated the use of CA-125 as a serum marker in the evaluation of an adnexal mass. One study was a population-based screening study that employed CA-125 as part of the screening triage.^51^ Forty-six studies in total used 35 U/ml as a threshold - in 37 it was the only threshold used, whereas in five, both 35 U/ml and another threshold were reported for the same patient population. There were 24 studies that reported a threshold other than 35 U/ml ranging from >20 U/ml to >100 U/ml. In addition to the five studies that reported 35 U/ml and an additional level, there were four other studies that reported two threshold levels within the same study population. All but one of the studies were case series. Although there were a few studies that compared CA-125 results from operative cases with normal controls, only the data from the operative series were included in the 2-by-2 tables. The clinical presentation of the cases was rarely described. Some of the series were drawn from oncology clinics

Results. At the most commonly used threshold of 35 U/mL, the pooled sensitivity of CA-125 for discriminating benign from malignant lesions was 0.78 (95% CI, 0.75 to 0.81), and the pooled specificity 0.78 (95% CI, 0.71 to 0.82). Individual study sensitivities ranged from 0.45 to 1.0, and specificities from 0.46 to 0.99; see Figure 16, where the trade-off between sensitivity and specificity resulting from different thresholds is clearly seen. Not including the one screening study in this series,^51^ the studies ranged in size from 52 to 429 individuals. Unlike ultrasound morphology assessments, the range of CA-125 performance is not influenced by the heterogeneity of evaluative modalities. However, the results of performance have, overall, a similarly broad range. This most likely reflects heterogeneity of study populations. As very few studies actually reported how patients were diagnosed with masses, it is impossible to accurately stratify these results by patient characteristics. As with ultrasound measurements (both morphology and Doppler), the narrowest range of CA-125 test performance was with NPV, making this, perhaps, the most reliable part of the test itself.

Figure 16. Performance of CA-125

Key to Figure 16: 1 = Adonakis et al., 1996;^51^ 2 = Woolas et al., 1995;^189^ 3 = Gadducci et al., 1992;^98^ 4 = Wakahara et al., 2001;^187^ 5 = Maggino et al., 1994;^135^ 6 = Dowd et al., 1993;^55^ 7 = Schutter et al., 2002;^162^ 8 = Patsner and Mann, 1988;^151^ 9 = Roman et al., 1997;^42^ 10 = Schutter et al., 1994;^62^ 11 = Gadducci et al., 1991;^99^ 12 = Chen et al., 1988;^85^ 13 = Vasilev et al., 1988;^50^ 14 = Timmerman et al., 1999;^178^ 15 = Hogdall et al., 2000;^110^ 16 = Malkasian et al., 1988;^136^ 17 = Torres et al., 2002;^181^ 18 = Schutter et al., 1998;^63^ 19 = Manjunath et al., 2001;^139^ 20 = Troiano et al., 1997;^47^ 21 = Chalas et al., 1992;^31^ 22 = Mancuso et al., 2004;^138^ 23 = Gadducci et al., 1988;^97^ 24 = Finkler et al., 1988;^56^ 25 = Tay and Chua, 1994;^174^ 26 = Soper et al., 1990;^167^ 27 = Smikle et al., 1995;^46^ 28 = Hurteau et al., 1995;^113^ 29 = Asif et al., 2004;^72^ 30 = Einhorn et al., 1986;^89^ 31 = Hillaby et al., 2004;^109^ 32 = Alcazar et al., 1999;^66^ 33 = Balbi et al., 2001;^53^ 34 = Antoni and Rakar, 1995;^71^ 35 = Hata et al., 1992;^106^ 36 = O'Connell et al., 1987;^148^ 37 = Schneider et al., 1993;^43^ 38 = Weiner et al., 1992;^188^ 39 = Tian et al., 2000;^177^ 40 = Berlanda et al., 2002;^75^ 41 = Sengoku et al., 1994^163^

The only screening study identified for CA-125 in our literature search^51^ included 2000 women. The sensitivity in this study was 1.00, specificity 0.99, PPV 0.17, and NPV 1.00. Few of the other studies achieved this degree of sensitivity, specificity, or NPV, although overall the PPV was higher. In the presence of an adnexal mass, the false negative rate increases compared with a screened population reflecting the fact that benign gynecologic disease can cause elevation of CA-125.

The most common threshold other than 35 U/ml was 65 U/ml. Most of the studies using 65 U/ml as a threshold were from Asia. The probable heterogeneity of study populations makes comparisons between these levels limited. Looking at the studies that reported results for different levels of CA-125 for within the same study population,^87,^ ^98,^ ^134,^ ^136,^ ^147,^ ^148,^ ^162,^ ^167,^ ^180^ in the higher threshold measurement, the specificity and PPV are higher, the sensitivity is lower, and the NPV is only slightly lower.

Stratification by menopausal status. Of the 59 studies we identified that examined CA-125, only nine contained data that either directly reported test characteristic by menopausal status or contained enough information to enable the stratification of results. One study was conducted exclusively in a postmenopausal population.^63^ The studies are listed in Table 18.

Table 18 CA-125 results stratified by menopausal status

Study | Threshold | Premenopausal | | | | Postmenopausal
| | Sens | Spec | PPV | NPV | Sens | Spec | PPV | NPV
Malkasian et al., 1988^136^ | > 100 | 0.60 | 0.95 | 0.67 | 0.93 | 0.77 | 0.97 | 0.98 | 0.72
| > 35 | 0.60 | 0.73 | 0.29 | 0.91 | 0.81 | 0.91 | 0.94 | 0.74
Gadducci et al., 1996^96^ | > 65 | 0.67 | 0.91 | 0.67 | 0.91 | 0.80 | 1.00 | 1.00 | 0.69
Gadducci et al., 1992^98^ | > 64 | 0.50 | 0.26 | 0.05 | 0.86 | 0.81 | 0.86 | 0.88 | 0.78
Franchi et al., 1995^95^ | > 39 | 0.73 | 0.64 | 0.24 | 0.94 | 0.77 | 0.85 | 0.87 | 0.74
Patsner and Mann, 1988^151^ | > 35 | 0.63 | 0.78 | 0.66 | 0.76 | 0.77 | 0.81 | 0.85 | 0.72
Dowd et al., 1993^55^ | > 35 | 0.74 | 0.73 | 0.60 | 0.84 | 0.86 | 0.82 | 0.90 | 0.76
Finkler et al., 1988^56^ | > 35 | 0.50 | 0.69 | 0.35 | 0.81 | 0.84 | 0.92 | 0.94 | 0.80
Schutter et al., 1998^63^ | > 35 | — | — | — | — | 0.69 | 0.84 | 0.73 | 0.81
Antonic and Rakar, 1995^71^ | > 35 | 0.67 | 0.92 | 0.40 | 0.97 | 0.87 | 0.93 | 0.93 | 0.87

Abbreviations: CA-125 = cancer antigen 125; NPV = negative predictive value; PPV = positive predictive value; Sens = sensitivity; Spec = specificity

The incidence of ovarian cancer is higher in postmenopausal women relative to benign gynecologic conditions, which also increase CA-125 levels. This should translate into a greater accuracy of CA-125 test performance in this population. Indeed, all test parameters except NPV are both higher and the range narrower in postmenopausal women. The lowest PPV was 0.73, with the remaining above 0.85, which is significantly higher than the range of PPV observed in studies that did not stratify their results by menopausal status. The NPV is lower in the postmenopausal population, despite the higher sensitivity, because of a greater prevalence of cancer in this population. CA-125 is consistently more helpful in discriminating benign from malignant lesions in postmenopausal women compared with premenopausal women.

### Other Serum Markers

The fact that CA-125 is < 35 U/ml in 20 percent of women with early stage ovarian cancer, has motivated research into other serum based tests. We identified 13 articles that described a total of 17 different sera studies in women with an adnexal mass. Some studies investigated the performance of other tumor-associated antigens such as tumor-associated glycoprotein 72 (TAG-72) or CA-19-9. Although most of the tumor-associated antigens achieved specificities of approximately 0.82 to 0.92, the sensitivity, PPV, and NPV were overall lower than those reported for CA-125. Two studies investigated carcinoembryonic antigen (CEA),^114,^ ^157^ and although they employed slightly different thresholds, the sensitivity reported in both (0.16 and 0.22) are so poor as to lead both authors to conclude that assessment of CEA in the evaluation of an adnexal mass is not helpful. Roman et al.^42^ investigated whether the addition of human chorionic gonadotropin (hCG), alpha-fetoprotein (AFP), and lactate dehydrogenase (LDH) to CA-125 improved the test performance. In their series the sensitivity of CA-125 alone was 0.67, the specificity was 0.71, PPV 0.35, and NPV 0.90. The addition of the other three tests did not change the test results very much. The combined test (defined as any of the markers positive) sensitivity was 0.72, its specificity was 0.70, PPV 0.36, and NPV 0.94. AFP, hCG, and LDH do not appear to improve the diagnostic performance of CA-125.

Gadducci et al. investigated the role of D-Dimer in a series of 121 women with adnexal masses.^96^ The sensitivity for D-Dimer alone was 0.91, the specificity was 0.83, the PPV 0.82, and the NPV 0.92 - making D-Dimer one of the best performing tests identified in our review. Stratifying by menopausal status showed a greater performance in premenopausal women where the sensitivity, specificity, PPV and NPV were 1.00, 0.91, 0.75, and 1.00 respectively (n = 57). For postmenopausal women they were 0.89, 0.65, 0.85, and 0.72, respectively. Chalas et al. investigated the role of elevated platelets in 241 women.^31^ The specificity and PPV were similar to that reported for D-Dimer (0.84 and 0.83, respectively), but the sensitivity and NPV were significantly lower (0.56 and 0.59). These two studies are intriguing, but the results need to be established in future studies to better assess their possible contribution to the evaluation of adnexal masses.

Aside from D-Dimer, none of the studies contained information making stratification by menopausal status possible. In conclusion, none of the sera markers investigated in this review appears to perform better than CA-125, with the possible exception of D-Dimer in the premenopausal population.

### Population-based Studies

Almost all of the studies identified were case series. There were, however, 13 population-based screening studies included in this review. They are listed in Table 19. Although all of the women included in these studies did not have a diagnosis of an adnexal mass at the time of enrollment, these studies are included here because they highlight some important issues about test performance. The strongest studies from a methodological perspective were those by Marchetti et al.,^140^ Vuento et al.,^186^ DePriest et al.,^34^ Adonakis et al.,^51^ and Tailor et al.^171^ Marchetti, Vuento, Tailor and DePriest all used ultrasound as a screening modality. In all of these studies, the PPV was low, ranging between 0.006 to 0.07. Screening with CA-125 yielded a slightly higher PPV of 0.17.^51^ Tailor et al.^171^ offered followup screening within the same populations. In the first screening episode, which captured the total study population of 2,500 women, the test characteristics were similar to those reported in the other screening studies. The test characteristics improved, however, with subsequent screening. Women who had a negative screen were offered either a 12- or 6-month repeat ultrasound (depending on individual risk factors). Nine hundred and ninety-eight women received a second ultrasound screening. For this subset, the PPV improved to 0.21. For women screened greater than two times, the PPV was 0.25. However, not all women offered additional screening returned for the ultrasound. This potential bias was not discussed by the authors, and it is unclear how it may have influenced the performance of repeat screening. The three studies by Kurjak et al. each had various biases that could have accounted for their markedly different reported test performances. One did not report followup on test negatives and therefore included no false negative in the series,^126^ another study population was an undescribed subset of a larger still incomplete screening series,^127^ and the last study did not describe inclusion criteria.^128^ Van Nagell et al.^49^ screened 14,469 women with ultrasound. They reported their results 12 months from the time of screening. However they note that four women were diagnosed with cancer greater than 12 months after screening. These women had all screened negative and were included in their analysis as true negatives. Reclassifying these individuals as false negatives changes the sensitivity from 0.81 to 0.68.

Table 19 Population-based screening studies

Study | N | Test | Sensitivity | Specificity | PPV | NPV
Marchetti et al., 2002^140^ | 4350 | Ultrasound screening: criteria
| | NR | 1.00 | 0.37 | 0.07 | 1.00
| | Operative cases only (n = 45)
| | Assuming all negatives were truly negative (n = 4359) | 1.00 | 0.96 | 0.01 | 1.00
Menon et al., 2000^145^ | 1027 | Ultrasound
| | Volume > 8.8 ml | 0.90 | 0.94 | 0.21 | 1.00
| | Abnormal morphology | 1.00 | 0.94 | 0.24 | 1.00
| | Complex morphology | 0.84 | 0.97 | 0.37 | 0.98
Vuento et al., 1995^186^ | 1364 | Combined ultrasound morphology and Doppler (PI < 1.0) | 1.00 | 0.88 | 0.006 | 1.00
DePriest et al., 1993^36^ | 24/3220 | Ultrasound morphology (DePriest) | 1.00 | 0.71 | 0.33 | 1.00
| | Operative cases only (n = 24)
Kurjak et al., 1992^126^ | 83/1000 | RI < 0.41 | 0.96 | 0.95 | 0.90 | 0.98
| | Ultrasound morphology (unique score) | 0.48 | 0.98 | 0.93 | 0.78
| | Presence of random vessels | 0.90 | 0.98 | 0.96 | 0.95
| | Combined ultrasound and Doppler | 0.90 | 0.94 | 0.90 | 0.94
Kurjak et al., 1994^127^ | 32/5013 | Ultrasound “persistent mass” | 1.00 | 0.97 | 0.80 | 1.00
| | Ultrasound assuming all test negatives true negatives | 1.00 | 0.99 | 0.80 | 1.00
Kurjak et al., 1991^128^ | 680/ 8620 | RI < 0.4 | 0.96 | 0.99 | 0.98 | 1.00
DePriest et al., 1997^34^ | 90/6470 | Ultrasound morphology (DePriest) (n = 90) | 1.00 | 0.59 | 0.17 | 1.00
| | Assuming all test negatives true negatives (n = 6470) | 0.86 | 0.99 | 0.07 | 1.00
Adonakis et al., 1996^51^ | 2000/ 2000 | CA-125 > 35 | 1.00 | 0.99 | 0.17 | 1.00
| | PE “palpable mass” | 0.67 | 0.97 | 0.03 | 1.00
Andolf et al., 1990^52^ | 801 | Combined ultrasound and BME (both positive for test to be positive) | 1.00 | 0.94 | 0.11 | 1.00
| | Ultrasound and BME criteria not well described
Jacobs et al., 1988^58^ | 1010 | CA-125 > 30 U/ml | 1.00 | 0.97 | 0.03 | 1.00
| | BME | 1.00 | 0.97 | 0.04 | 1.00
| | Ultrasound (ovarian volume > 8.8ml) (n = 58 for ultrasound) | 1.00 | 0.74 | 0.08 | 1.00
Tailor et al., 2003^171^ | 2500 | Ultrasound morphology (descriptive) | 0.86 | 0.97 | 0.07 | 1.00
| | N = 2500 | 1.00 | 0.99 | 0.21 | 1.00
| | Ultrasound for second screening episode (n = 998) | 1.00 | 0.99 | 0.25 | 1.00
| | Ultrasound for >= third screening episode (n = 733)
van Nagell et al., 2000^49^ | 14469 | Ultrasound (ovarian volume > 20 cm^3^ for premenopausal women, > 10 cm^3^ for postmenopausal women) | 0.81 | 0.99 | 0.09 | 1.00

Abbreviations: BME = bimanual examination; CA-125 = cancer antigen 125; NR = not reported; PE = pelvic examination; PI = pulsatility index

### Methodological Issues

In reviewing the literature on evaluation modalities, numerous methodological problems consistently reduced our ability to draw conclusions about the performance of various tests both individually and in comparison with each other. Some of these problems concerned study design, others related to statistical issues.

Patient population. With the exception of the 13 population-based screening studies, all of the articles were case series. Some were consecutive and others non-consecutive. Some were based on operative cases within a specific time frame at one or several institutions, whereas others were referral series, often located in oncology clinics. The path to diagnosis was almost never described, making it difficult to asses the generalizability of the results. Further, age was the only patient characteristic that was reliably documented. Other characteristics, such as family history, were almost never included. This has several implications. The overrepresentation of operative cases especially from academic facilities, likely overrepresents the prevalence of malignancy in the study populations when compared with the population of women with adnexal masses in general. It also exaggerates the performance of the evaluative modalities, especially in regards to sensitivity and PPV. Finally, it limits the generalizability of the evidence.

Definition of malignant. There was inconsistency between studies regarding whether the malignant classification included any malignancy or whether it included only ovarian malignancies. The inclusion of all malignancies would exaggerate the test's specificity and PPV at the expense of its sensitivity and NPV. From a practical standpoint, this difference may not be that problematic, as all malignancies are important. However, this classification bias increased the heterogeneity of test performance and limits generalizability. Finally, almost all of the articles that reported series containing tumors of low malignant potential (LMP) (also called borderline) classified these tumors as malignant. This changes the reported performance of the various evaluative modalities in these studies. There were three studies identified where stratification by LMP was possible. These are listed in Table 20. Classifying LMP tumors as malignant increases the specificity and PPV relative to classifying them as benign, while decreasing the specificity and NPV. Overall, PPV tended be somewhat low (even in populations with high prevalences of disease). The inclusion of LMP tumors into the malignant category inflated this measurement somewhat. Obviously, because of uncertainty about the natural history of LMP tumors, the most appropriate way of classifying them as part of diagnostic test evaluation is also uncertain. Given this uncertainty, ideally investigators would report results using alternative methods of classifying LMP tumors.

Table 20 Effect of classification of LMP tumors as malignant or benign on diagnostic test characteristics

Study | Test | LMP classified as malignant | | | | LMP classified as benign
| | Sens | Spec | PPV | NPV | Sens | Spec | PPV | NPV
Roman et al., 1998^157^ | CEA | 0.16 | 0.93 | 0.35 | 0.83 | 0.19 | 0.93 | 0.25 | 0.90
Wakahara et al., 2001^187^ | Ultrasound morphology | 0.82 | 0.82 | 0.65 | 0.92 | 0.86 | 0.78 | 0.54 | 0.95
| CA-125 | 0.45 | 0.86 | 0.74 | 0.63 | 0.77 | 0.61 | 0.37 | 0.90
Timmerman et al., 1999^178^ | CA-125 | 0.80 | 0.82 | 0.63 | 0.91 | 0.77 | 0.79 | 0.56 | 0.91

Abbreviations: CA-125 = cancer antigen 125; CEA = carcinoembryonic antigen; LMP = low malignant potential (tumors); NPV = negative predictive value; PPV = positive predictive value; Sens = sensitivity; Spec = specificity

Variability in test criteria. Of the 69 articles that evaluated ultrasound morphology, only 31 used established scoring criteria; 38 used a novel method. This resulted in a great heterogeneity of tests for ultrasound morphology and contributed to the range in performance noted. Many of the studies employed purely descriptive analysis to arrive at a benign versus malignant diagnosis. This limits the reproducibility of those results. Many of the scoring systems and descriptive categories had never been independently verified, and the paucity of details regarding what constituted a positive test makes such verification impossible. In terms of ultrasound evaluation by color Doppler, there was also a range of reported thresholds. Some of the variability in test criteria reflects the limitations of ultrasound technology. However, such differences limited the comparability between studies.

Masses as numerator. While most studies examined persons as the unit of 2-by-2 analysis, there were many studies that analyzed their data by masses. Even though the number of persons in the study was usually reported, it was often impossible to reconfigure the 2-by-2 table to refer to persons not masses. This was especially true in the radiology literature. This influenced the comparability between studies.

Menopausal status. Most of the studies did describe the patient population in terms of age. We were able to calculate the proportion of menopausal patients in most studies. However, the results were rarely reported in a way that allowed stratification by menopausal status. Where stratification was possible, a difference in test performance was seen. The heterogeneity in test performances was magnified by the different proportions of pre- and postmenopause in the different study populations.

Sample size. Few studies discussed sample size issues, potentially leading to inappropriate conclusions, especially regarding comparability of test characteristics.

Failure to account for observer variability. No studies attempted to account for the effects of observer variation on the precision of estimates, although a few did calculate interobserver coefficients. For tests where the thresholds for normal and abnormal were based on either qualitative assessments (such as descriptions of ultrasound morphology) or quantitative measures (such as ultrasound morphology scores), this variability will have implications for the precision of sensitivity and specificity.

Prevalence and predictive value. We did not limit our analysis of test characteristics to studies from the United States. As the incidence of ovarian cancer is different in different countries, this influences the range of predictive values reported in the literature. Locations with low disease prevalence will have low PPVs compared with higher prevalence areas. The heterogeneity of study locations influenced the range of reported test characteristics and somewhat limits the comparability of the results.

### Summary

Table 21 summarizes the pooled sensitivity and specificity estimates for CA-125 and the various imaging modalities.

Table 21 Pooled sensitivity and specificity estimates

Diagnostic Test | Pooled Sensitivity (95% CI) | Pooled Specificity (95% CI)
ULTRASOUND: MORPHOLOGY
Scoring system: Sassone | 0.86 (0.79 to 0.91) | 0.77 (0.73 to 0.81)
Scoring system: DePriest | 0.91 (0.84 to 0.95) | 0.68 (0.49 to 0.82)
Scoring system: Ferrazzi | 0.87 (0.80 to 0.92) | 0.81 (0.62 to 0.91)
Scoring system: Finkler | 0.82 (0.65 to 0.91) | 0.78 (0.59 to 0.91)
Other | 0.86 (0.82 to 0.89) | 0.83 (0.76 to 0.88)
ULTRASOUND: DOPPLER
Resistive index | 0.72 (0.61 to 0.82) | 0.90 (0.84 to 0.94)
Pulsatility index | 0.80 (0.74 to 0.85) | 0.73 (0.62 to 0.81)
Maximum systolic velocity | 0.74 (0.56 to 0.86) | 0.81 (0.59 to 0.83)
Presence of vessels | 0.88 (0.80 to 0.92) | 0.78 (0.65 to 0.87)
MORPHOLOGY PLUS DOPPLER | 0.86 (0.79 to 0.91) | 0.91 (0.80 to 0.97)
MRI | 0.91 (0.86 to 0.94) | 0.87 (0.83 to 0.90)
CT | 0.90 (0.83 to 0.94) | 0.75 (0.36 to 0.94)
FDG-PET | 0.67 (0.52 to 0.79) | 0.79 (0.70 to 0.85)
CA-125 (threshold > 35) | 0.78 (0.75 to 0.81) | 0.78 (0.71 to 0.82)

Abbreviations: CA-125 = cancer antigen 125; CI = confidence interval; CT = computed tomography; FDG = 18-Fluorodeoxyglucose; MRI = magnetic resonance imaging; PET = positron emission tomography

The use of established scoring systems in the evaluation of an adnexal mass by ultrasound morphology appears to perform slightly better than simple descriptive assessment. However, there does not appear to be a benefit of one scoring system over another. Based on small numbers of studies, 3D ultrasound shows some improvement over 2D. Although the pooled sensitivity and specificity of MRI was the highest of any imaging modality, its performance was less consistent in studies where it was directly compared to other modalities such as CT and ultrasound.

Color Doppler assessment by RI, PI, and maximum systolic velocity are not superior to the more simple assessment of the presence or absence of arterial vessels within the mass. The efficacy of RI, PI, and maximum systolic velocity are hampered by the overlap in values of these measurements between benign and malignant masses.

Combined ultrasound morphology and color Doppler assessments have higher sensitivity and specificity compared to either alone. Although ultrasound morphologic evaluation by a gynecologist appears to be as reliable as that performed by a radiologist, there was no evidence of Doppler measurements done outside of the context of a radiology referral.

In postmenopausal women, an elevated CA-125 is useful for helping rule in ovarian cancer.

Qualitatively, there was a consistent trade-off across all tests between sensitivity and specificity.

The relatively low PPVs in all of the tests are particularly striking given that many of the included studies were done in preoperative patients; the likely “screening” done prior to a decision for surgery suggests that the PPV of a particular test in the initial evaluation of an adnexal mass is likely to be even lower.

## Question 4: Explicit Scoring Systems

Question 4 is: What is the accuracy of explicit scoring systems which incorporate various combinations of imaging findings, patient risk factors, and/or CA-125 levels for detecting malignancy? Have these scoring systems been applied to a population of women before laparoscopy or laparotomy?

### Approach

Explicit scoring systems were sought in the medical literature from among all studies of diagnostic assessment of adnexal or pelvic masses. We considered only scoring systems that combined data from more than one category of the following types of information: (1) imaging findings; (2) patient risk factors; and (3) laboratory data. Clinical prediction rules that utilized data entirely from only one category (for example, ultrasound based morphological indices^56^) are described as part of Question 3.

Imaging findings could include: (1) ultrasound based tests, such as transabdominal or transvaginal 2D ultrasound or Doppler ultrasound; (2) radiographic tests, such as CT; or (3) other imaging studies, such as MRI or PET scans.

Patient risk factors include menopausal status, age, or other risk factors.

Laboratory data was primarily CA-125, but we recorded data on other serum tumor markers as well.

### Results of Literature Search and Screening

We identified 36 studies that met the inclusion criteria.^42,^ ^48,^ ^51^–^53,^ ^55,^ ^62,^ ^63,^ ^66,^ ^72,^ ^86,^ ^87,^ ^97,^ ^103,^ ^105,^ ^116,^ ^134,^ ^135,^ ^138,^ ^139,^ ^147,^ ^169,^ ^178,^ ^180,^ ^181,^ ^185,^ ^202^–^211^ These are described in Evidence Table 4 (Appendix D *).

### Study Characteristics

Scoring systems identified. The scoring systems were of several types. The most common were models developed using statistical modeling techniques such as logistic regression (or artificial neural networks) to develop estimates for predicted probability of malignancy. Such estimates were then used to construct clinical prediction rules (e.g., the Risk of Malignancy Index [RMI], which calculates a numeric score based on CA-125 level multiplied by a menopausal score and an ultrasound morphology score) and decision thresholds (e.g., for RMI, the most common threshold is 200). Other scoring systems used simple combinations of criteria based on individual modalities, which were then combined using Boolean and or or (e.g. CA-125 > 65 U/ml and ultrasound morphology score > 10 points). Some models were validated in separate populations from the data set used to develop the scoring systems either described as part of its initial development, or in subsequent publications by the original developers or others.

Types of data incorporated. The most common scoring systems used ultrasound, CA-125 and menopausal status. Some type of ultrasound data was used in all 36 publications; studies varied with regard to the type of ultrasound technology that was used. All used 2D ultrasound to evaluate morphology, some using transabdominal and many using transvaginal probes. Studies that used Doppler ultrasound used a variety of parameters, including measures as simple as detection of flow, or as complex as specific indices derived from Doppler-measured flow rates, such as the RI or PI. Many described scoring rules based on combinations of features of morphology (Finkler score) or combined morphology and blood flow.

CA-125 was a component of the scoring system in 30 reports; other serum tumor markers included CA-72-4, incorporated into two reports,^53,^ ^63^ and the markers AFP, LDH, and hCG, were used in one report.^42^ All studies that used these other serum markers also used CA-125.

Menopausal status was incorporated into scoring systems of 19 reports. The definition of menopausal status varied across studies, and in a few cases age was used as a proxy for clinically determined menopausal status. Three studies included only postmenopausal women,^62,^ ^63,^ ^135^ and thus could not use this variable in the scoring system.

Physical examination was a component of scoring systems in six reports.^42,^ ^51^–^53,^ ^62,^ ^63^

Type of study populations. Most study populations were case series assembled at the time of referral for surgery and collected either at the point of preoperative ultrasound imaging or preoperative surgical evaluation. No studies were based in primary care clinical populations. One study described evaluation of adnexal masses detected during an ovarian cancer screening program.^51^

Reporting of study populations. Menopausal status of the study populations was described in 28 of the 36 reports; three reports included only postmenopausal women.^62,^ ^63,^ ^135^

Age was reported for the study population as a mean or median in 18 of 36 studies; it was reported in categories in one additional study. Symptom status was seldom described in the candidate reports.

Race/ethnicity was not reported in any of the studies.

Risk factors for ovarian cancer (besides menopausal status and age, describe above) were not reported, except in one study that reported the proportion of the study population that was nulliparous versus multiparous.^138^

Methodology. The methodological quality of the included studies may be described as follows:

Reference standard (handling of borderline). Some studies, particularly those assembled at the time of ultrasound investigation rather than surgery, encountered women with masses due to simple cysts with low risk of malignancy. Two studies allowed use of an operative report in lieu of histopathology as a reference standard,^87,^ ^116^ and one used clinical followup without surgery as an alternate reference standard.^48^

Verification bias. Fourteen studies failed to verify disease status for all or a significant sample of test-negative women.

Test reliability. Only nine studies provided data on the reliability of test assessments.

Sample size. Only 11 of the reports described a priori recruitment targets or sample size calculations. We excluded studies with fewer than 50 women; however, some studies report subgroup analyses with fewer than 50 women, for example, the subset of postmenopausal women in Strigini et al.^169^

Use of appropriate statistical tests. The majority of reports (n = 28) used appropriate statistical analysis of the diagnostic data; however seven reports reported inadequate analyses.

Blinding. None of the reports described the use of techniques to blind investigators to the disease status of study patients.

Definition of positive and negative test. Most studies (n = 24) provided a priori definitions of a positive and negative test result; studies failed to meet this criterion most often when no explicit threshold was set a priori, but it was set based on study data.

Explicit validation method. Half of the reports (18/36) used some explicit validation method; many of the reports replicated previously described scoring systems in a new population. In many cases, these studies described new scoring systems which were not always validated.

The most common validation method was replication in a separate population. Two studies used validation techniques within a single study population: one split-sample,^209^ and one bootstrap.^205^

### Diagnostic Accuracy of Scoring Systems

This section considers the diagnostic accuracy of the RMI (Jacobs 1990) and subsequent replications and refinements (RMI2, RMI3, Jacobs 1993, and Timmerman models).

RMI. The first scoring system based on a statistical model was published in 1990;^116^ it has been replicated in 11 subsequent clinical populations.^55,^ ^72,^ ^87,^ ^139,^ ^147,^ ^180,^ ^204,^ ^206^–^208,^ ^210^ The diagnostic performance in these 12 studies is shown in Figure 17.

Figure 17. Performance of RMI model of Jacobs et al. (1990)^116^ in development set (study 6) and subsequent validation studies using cutoff score of 200

Key to Figure 17: 1 = Tingulstad et al., 1996;^180^ 2 = Timmerman et al., 1999;^210^ 3 = Mol et al., 2001;^207^ 4 = Lu et al., 2003;^206^ 5 = Manjunath et al., 2001;^139^ 6 = Jacobs et al., 1990;^116^ 7 = Davies et al., 1993;^87^ 8 = Morgante et al., 1999;^147^ 9 = Obeidat et al., 2004;^208^ 10 = Asif et al., 2004;^72^ 11 = Aslam et al., 2000;^203^ 12 = Dowd et al., 1993^55^

The RMI is a clinical prediction rule based on ultrasound, CA-125, and menopausal status data defined as follows:

RMI = U × M × CA-125

where ultrasound (transabdominal) is scored 1 point for each of the following characteristics: multilocular cyst, evidence of solid areas, evidence of metastases, presence of ascites, and bilateral lesions.

U = 0 for ultrasound score of 0

= 1 for ultrasound score of 1

= 3 for ultrasound score ≥ 2

CA-125 = Serum CA-125 in U/ml

Menopausal status

M = 1 if premenopausal

= 3 if postmenopausal

In the initial report, Jacobs et al.^116^ used the cutoff value of 200. At this cutpoint, sensitivity was 85 percent and specificity was 97 percent among a population of 143 women undergoing surgical investigation for an adnexal mass. The performance of the initial model (study 6 in Figure 17) has, in most studies, failed to be equaled in subsequent attempts at validation. Three of the subsequent 11 studies have similar performance (studies 7, 9, 10 in Figure 17).^72,^ ^87,^ ^208^ It is notable that these three studies have fewer quality features (n ≤ 4) than the other eight studies (n ≥ 5 of 7 quality features).

When sensitivity and specificity are combined separately using a random-effects model, the pooled sensitivity is 0.78 (95% CI, 0.72 to 0.84) and the pooled specificity is 0.90 (0.81 to 0.95).

RMI2. In 1996, Tingulstad et al.^180^ reported a refinement to the original RMI scoring system, commonly referred to as RMI2. RMI2 is defined identically to RMI except that new weights were used for the ultrasound and menopause components as follows:

U = 1 for ultrasound score of 0–1

= 4 for ultrasound score ≥ 2

M = 1 if premenopausal

= 4 if postmenopausal

A cutoff value of 200 was also recommended for RMI2. Like the RMI, the RMI2 scoring system has been replicated.^134,^ ^139,^ ^147,^ ^207^ The original report of RMI2 found sensitivity of 0.8 and specificity of 0.92. Subsequent validation studies have performed no better. These validation studies all exhibited five or more quality features. The pooled sensitivity of all five studies is 0.77 (0.71 to 0.82), and pooled specificity 0.89 (0.85 to 0.91). The summary ROC curve is shown in Figure 18.

Figure 18. Performance of RMI2 model of Tingulstad et al. (1996)^180^ in development set (2) and subsequent validation studies using cutoff score of 200

Key to Figure 18: 1 = Andersen et al., 2003;^202^ 2 = Tingulstad et al., 1996;^180^ 3 = Manjunath et al., 2001;^139^ 4 = Ma et al., 2003;^134^ 5 = Morgante et al., 1999;^147^ 6 = Aslam et al., 2000^203^

RMI3. Subsequently, a further refinement to the RMI and RMI2 was reported by Tingulstad et al.^211^ This third scoring system is defined identically to RMI and RMI2 except that new weights were used for the ultrasound and menopause components as follows:

U = 1 for ultrasound score of 0–1

= 3 for ultrasound score ≥ 2

M = 1 if premenopausal

= 3 if postmenopausal

A cutoff value of 200 was also recommended for RMI3. The RMI3 scoring system has been replicated in one additional study.^139^ The original report of RMI3 found sensitivity of 0.71 and specificity of 0.92, while the validation study reported very similar performance, with sensitivity of 0.74 (0.65 to 0.83) and specificity of 0.91 (0.83 to 0.99).

Tailor and subsequent replications. Tailor et al.^209^ reported a scoring system based on an artificial neural network method that was based on a small population of 67 women total, 15 of whom had malignancies. Unlike the RMI family of systems described above, this system did not include CA-125, but considered age, menopausal status, and a variety of ultrasound morphological features and Doppler indices. While this system reported using 52 cases as a training set and 15 cases as a test set, the performance of the system was reported only for the study population as a whole: sensitivity 0.93 (95% CI, 0.81 to 1.0) and specificity 1.0 (0.94 to 1.0). Subsequently four studies have replicated this system showing markedly poorer diagnostic performance (Figure 19) when applied to separate populations, consistent with over-fitting in the initial model development.^185,^ ^203,^ ^204,^ ^207^

Figure 19. Performance of model of Tailor et al. (1999)^209^ in development set (4) and subsequent validation studies

Key to Figure 19: 1 = Mol et al., 2001;^207^ 2 = Valentin et al., 2001;^185^ 3 = Aslam et al., 2000;^203^ 4 = Tailor et al., 1999;^209^ 5 = Aslam et al., 2000^204^

Twenty other scoring systems have been described, none of which has been as extensively replicated as the systems described above. Five of these other scoring systems have been validated in one other population as shown in Table 22; each of the systems was based on ultrasound morphology, CA-125, Doppler, and menopausal status. The models were: Timmerman LR1,^178,^ ^210^ Timmerman AAN1,^178,^ ^207^ Timmerman AAN2,^178,^ ^207^ Timmerman LR2,^178,^ ^207^ and Jacobs 1993.^207,^ ^212^

Table 22 Performance of other scoring systems at initial derivation and subsequent replication in another population

Initial description | Subsequent validation | Sensitivity (95% CI) | | Specificity (95% CI)
| | Initial development | Replication | Initial estimate | Replication
Timmerman LR1^210^ | Valentin 2001^185^ | 0.87 (0.79 to 0.97) | 0.62 (0.44 to 0.80) | 0.92 (0.87 to 0.97) | 0.79 (0.68 to 0.90)
Timmerman AAN1^178^ | Mol et al. 2001^207^ | 0.94 (0.87 to 1.0) | 0.90 (0.79 to 1.0) | 0.90 (0.85 to 0.96) | 0.60 (0.52 to 0.68)
Timmerman AAN2^178^ | Mol et al. 2001^207^ | 0.96 (0.90 to 1.0) | 0.90 (0.79 to 1.0) | 0.94 (0.89 to 0.98) | 0.46 (0.38 to 0.54)
Timmerman LR2^178^ | Mol et al. 2001^207^ | 0.96 (0.90 to 1.0) | 0.90 (0.79 to 1.0) | 0.86 (0.79 to 0.92) | 0.56 (0.48 to 0.64)
Jacobs 1993^212^ | Mol et al. 2001^207^ | 0.85 (0.74 to 0.96) | 0.90 (0.79 to 1.0) | 0.97 (0.94 to 1.0) | 0.61 (0.53 to 0.69)

In each case, the initial diagnostic performance described by the system significantly degrades on replication in another population (Figure 20).

Figure 20. Performance of various other scoring systems in development and validation studies in separate populations

Arrows indicate change in performance estimate from development (start of arrow) to validation (end of arrow) for paired studies of each scoring system.

Key to Figure 20: 1–4 = Timmerman et al., 1999;^210^ 5–8 = Mol et al., 2001;^207^ 9 = Jacobs et al., 1993;^212^ 10 = Valentin et al., 2001^185^

Ten additional systems were described in seven reports.^42,^ ^48,^ ^53,^ ^63,^ ^181,^ ^203,^ ^205^ Most of these studies used logistic regression or artificial neural network modeling methods to derive a new model. One used bootstrap validation techniques,^205^ but none was validated in another study population. One of these studies^203^ reported on newly fitted logistic regression models created by forcing variables that were include in previously described scoring systems.^178,^ ^209,^ ^213^ Aslam et al.^204^ constructed three separate models based on each possible pairwise combination of the three previously described models. The diagnostic performance of these miscellaneous unvalidated models is shown in Figure 21.

Figure 21. Performance of various other unvalidated models

Key to Figure 21: 1 = Twickler et al., 1999;^48^ 2–3 = Biagiotti et al., 1999;^205^ 4 = Torres et al., 2002;^181^ 5 = Schutter et al., 1998;^63^ 6 = Balbi et al., 2001;^53^ 7 = Roman et al., 1997^42^

Thirteen further reports describe the diagnostic performance of simple rules for combining single test or single modalities into a decision rule.^42,^ ^51,^ ^52,^ ^62,^ ^63,^ ^66,^ ^86,^ ^97,^ ^103,^ ^105,^ ^135,^ ^138,^ ^169^ None of these criteria has been validated in another population. Each of these studies used dichotomous rules for two or more tests (or modalities) and then combined them using a simple rule like “malignant if any test positive” (Boolean or) or “malignant if all tests positive” (Boolean and). Some of the studies reported diagnostic performance of several different simple rules.

Twelve of these studies used ultrasound and CA-125, five incorporated physical exam, two included other serum tumor markers^42,^ ^63^ and one used age over 50 years.^138^

Six of these studies reported results for postmenopausal women separately: in three studies, the entire study population was postmenopausal^62,^ ^63,^ ^135^ while three studies reported diagnostic performance for the postmenopausal subgroup separately.^103,^ ^105,^ ^169^ The diagnostic performance of 18 simple combination rules in these six studies is shown in Figure 22.

Figure 22. Performance of unvalidated simple combination rules in postmenopausal women only

Key to Figure 22: 1–4 = Maggino et al., 1994;^135^ 5–8 = Schutter et al., 1998;^63^ 9–11 = Schutter et al., 1994;^62^ 12–13 = Strigini et al., 1996;^169^ 14–17 = Guerriero et al., 1998;^103^ 18–19 = Guerriero et al., 2002^105^

In contrast, the diagnostic performances of 17 simple combination rules in studies that include both premenopausal and postmenopausal women in the study population are shown in Figure 23.

Figure 23. Performance of unvalidated simple combination rules in mixed pre- and postmenopausal populations

Key to Figure 23: 1–2 = Andolf et al., 1990;^52^ 3–4 = Adonakis et al., 1996;^51^ 5–9 = Mancuso et al., 2004;^138^ 10 = Gadducci et al., 1988;^97^ 11–12 = Chou et al., 1994;^86^ 13 = Alcazar et al., 1999;^66^ 14–15 = Roman et al., 1997;^42^ 16–17 = Strigini et al., 1996^169^

The results show a wide range of sensitivity and specificity. This variation reflects differences in decision thresholds (e.g., CA-125 > 35 U/ml versus CA-125 > 65 U/ml) and in the rules for combining tests (e.g., use of Boolean or versus and when combining results of two or more tests).

### Discussion

No scoring systems were both developed and validated expressly for evaluating adnexal masses in postmenopausal women. Existing scoring systems that have been validated have all been developed in mixed pre- and postmenopausal populations. Those scoring systems that have been described in populations of postmenopausal women were neither rigorously developed (they consist of simple combination rules) nor validated in other populations.

The highest demonstrated specificity obtained with these scoring systems appears to be in the range of 90 to 95 percent and, at this range of specificity, the sensitivity appears to be in the range of 65 to 80 percent. However, as suggested by the performance in the few populations of postmenopausal women studied, the same degree of sensitivity and specificity is unlikely to be possible. Reliable estimates of the diagnostic performance of scoring systems cannot be determined from these studies.

This review of scoring systems demonstrates several important limitations of predictive models and has important implications for the clinical usefulness of these models and the future research in this area of inquiry. First, validation in an external population is critical to obtain accurate estimates of diagnostic performance, because all modeling techniques lead to overestimation of diagnostic performance in the data from which it was derived. This overestimation of diagnostic performance is clearly demonstrated by comparing the development and validation studies described for RMI, Tailor, and other scoring systems (Figures 17–20). The studies described here suffer from being relatively small for modeling; reliable variable selection and parameter estimation requires at least 10 to 15 cases (in this case, ovarian malignancies) for every term selected in a predictive model. Few, if any, met this statistical rule of thumb. This limitation is particularly apparent in the case of the Tailor model, where subsequent studies demonstrated a high degree of overestimation of the original model. Third, these studies used populations that were identified following referral for surgery in most cases, after some filtering had already occurred. Furthermore, these studies failed to describe the initial presentation (symptomatic or asymptomatic, palpable or non-palpable mass) of women eventually enrolled. Thus, the applicability of these studies to women in primary care, where an adnexal mass is often first noted, is uncertain.

## Question 5: Monitoring Women with Suspected Benign Masses

Question 5 is: Among women with suspected benign masses on initial investigation, what are the sensitivity and specificity of monitoring with periodic CA-125 and/or interval ultrasound examinations for detecting malignant masses? How does the interval of testing/definition of change affect sensitivity and predictive value?

### Approach

For each study we sought to identify a population of patients with a screening abnormality which was “probably benign” and which the authors felt did not meet criteria for immediate surgical intervention. We then attempted to define the outcomes of further testing in the defined population, including the results of subsequent testing and final clinical outcome as defined by a pathology report or extended clinical followup. The interpretation of results is limited by the narrow scope of Question 5. Specifically, it is often difficult to identify a subgroup of patients with a screening abnormality which could be defined as a “suspected benign lesion” within larger screening studies. Often, results are not stratified with respect to these sub-populations, making it difficult to calculate sensitivity and specificity of the followup testing. In addition, by definition, it is also difficult to estimate the “sensitivity” of a followup regimen. We assumed that this refers to detection of cancer as part of the followup regimen, and that women with cancer diagnosed outside of the followup were “false negatives.”

### Results

We identified nine articles meeting the criteria for this question;^40,^ ^127,^ ^135,^ ^145,^ ^214^–^218^ these are summarized in Table 23, with details in Evidence Table 5 (Appendix D *). Five were population-based screening studies of asymptomatic, postmenopausal patients without known ovarian masses;^40,^ ^127,^ ^145,^ ^214,^ ^217^ one was a voluntary screening program.^216^ All addressed to some degree the use of interval ultrasound for detecting malignant masses. Although several used CA-125 as part of their followup, none reported any results based on the use of interval CA-125 in a population with adnexal lesions. None addressed the effects of changing the interval of testing on sensitivity and predictive value; the disparate nature of the studies prohibited any inferences on the effect of test interval on sensitivity.

Table 23 Studies of followup regimens for benign-appearing lesions

Study | Population | N | Followup interval | Length of followup | Loss to followup | True/false positivesdetected during followup | Cancers missed
Population-based studies (followup of “benign” masses identified in screening)
Menon et al., 200^145^ | Followup of scans considered “equivocal” | 17 | “Equivocal” scans followed every 6 weeks until clearly normal or abnormal; normal scans followed with CA-125 every 3 months | Median 6.8 years | Not reported | 1 cancer/5 benign lesions | 0 (1 within 6 weeks of initial test, before first followup scan)
Modesitt et al., 2003^40^ | Followup of simple cysts < 10 cm | 2,763 | TVUS every 3–6 months for simple cysts | Mean 6.3 years | Not reported | 7 cancers/0 benign lesions | 3 cancers, none developed in the original cyst
Schin-caglia et al., 1994^217^ | Followup of post-menopausal ovaries > 9 cc, or with simple cyst | 347 | If cyst: followed with ultrasound every 6 months; if change, referred; others: referral if unchanged at 3 and 6 months | “At least” 1 year | Not reported, but all had “at least 1 year” | 2 cancers/96 benign lesions | None in 249 not referred
Kurjak et al., 1994^127^ | Followup of post-menopausal women with simple cyst > 2.5 cm but < 5 cm, resistive index ≥ 4.1) | 88 (of 404 with simple cysts) | Repeat ultrasound every 6 months | 6 months | Not reported | 1/17 with benign lesions | 0
Castillo et al., 2004^214^ | Followup of post-menopausal women with simple cyst < 10 cm | 215 | Repeat ultrasound and CA-125 in 3 months, then every 6 months | Median 27 months | 30.6% | 0/44 benign masses | 1
Case series (clinical history prior to identification of mass not routinely described)
Valentin and Akrawi, 2002^218^ | Followup of post-menopausal women with low score on ultrasound malignancy risk scale | 162 | Repeat ultrasound 3, 6, 9, and 12 months, then every 12 months; test positive if increase in size or cyst more complex | Median 3 years | 0 (cancer and mortality tracked through registry) | 0 cancers/7 patients underwent surgery for change | 0
Maggino et al., 1994^135^ | Followup of post-menopausal women with cysts < 5 cm, thin wall, no septae, no free fluid | 45 | Details on followup strategy not reported | Not reported | 4.4% | 0/0 | 0
Levine et al., 1992^216^ | Followup of voluntary screening of post-menopausal women with unilocular simple cyst | 32 | Repeat ultrasound every 3 months × 1 year, then every 6 months | “Over half at least one year” | 22.2% | 0/0 | 0
Goldstein et al., 1989^215^ | Followup of post-menopausal women with simple cysts ≤ 5 cm | 16 | Repeat ultrasound (abdominal) | Mean 29 months | 6 (12% of original 48) | 0/2 with benign lesions | 0

Abbreviations: CA-125 = cancer antigen 125; TVUS = transvaginal ultrasound

Menon et al.^145^ performed a large prospective screening study of 22,000 postmenopausal women older than 45 years. Initial screening consisted of CA-125; patients with CA-125 ≥ 30 underwent endovaginal ultrasound evaluation. Results were interpreted as normal (ovarian volume < 8.8 ml/normal morphology), equivocal (volume < 8.8 ml, abnormal morphology), or abnormal (volume ≥ 8.8 ml). Normal morphology was defined as uniform hypoechogenicity and smooth outline. Abnormal morphology was defined as simple cysts or complex lesions. Patients with normal scans were triaged to repeat CA-125 every 3 months for a year and subsequently returned to yearly screening; median followup was 6.8 years, with loss to followup not reported. Patients with abnormal scans were referred to a gynecologist for consideration of surgical intervention. Patients with equivocal scans were triaged to repeat ultrasound at 6-week intervals until a scan could be classified as normal or abnormal. Of 741 patients who were triaged to ultrasound, 20 (2.7 percent) index cancers were identified. We focused on the group of patients with “equivocal” scans who were triaged to interval testing in an attempt to answer the study question. There were 17 equivocal scans. Of these, nine had simple cysts which were followed and did not result in a cancer diagnosis (true negatives). One patient died of pneumonia prior to her first repeat ultrasound, and one died of advanced ovarian cancer prior to her first repeat ultrasound; this cancer death could possibly be considered a false negative for the followup strategy, although it could also be considered a false negative from the original study since the death occurred within 6 weeks of the initial scan. Six patients were scheduled for surgery following an equivocal scan, presumably due to abnormal followup ultrasound. One of these had ovarian cancer (true positive), and the other five had benign disease (false positive). Because the number of equivocal scans was so small, and because the classification “equivocal” does not necessarily imply that the lesions were felt to be “suspected benign” as designated in Question 5, it is not possible to calculate the sensitivity and specificity of prolonged monitoring strategies using this study. The authors do not draw any conclusions regarding the appropriateness of interval testing.

Modesitt et al.^40^ performed a large screening study of 15,106 asymptomatic women at least 50 years old without a history of ovarian cancer. Patients were screened with TVUS. Criteria for abnormality were ovarian volume > 10 ml and any morphologic abnormality, including simple or complex cysts. Patients with abnormal TVUS were triaged to repeat TVUS in 4 to 6 weeks, with Doppler flow ultrasound, CA-125 level, and tumor morphology indexing performed at the second visit. Patients with simple unilocular cysts which were considered likely benign were triaged to repeat TVUS every 3 to 6 months. Mean followup was 6.3 years. Two thousand and seven hundred and sixty-three (2,763) women were diagnosed with 3,259 unilocular cysts. Spontaneous resolution of unilocular cysts occurred in 2,261 (69.4 percent) of lesions. Ten patients subsequently developed ovarian cancer. Seven of these had additional abnormal areas which subsequently developed on TVUS (considered true positives because they were subsequently identified by interval testing). Two developed ovarian cancer after the cyst in question had resolved on sonographic followup (these might be considered false negatives). One patient developed cancer in the ovary opposite the cyst being followed (this might also be considered a false negative). Calculated on a per-patient basis, the sensitivity and specificity of followup testing in the population with a simple unilocular ovarian cyst are 70 percent (95% CI, 41.6 to 98.4 percent) and 100 percent (99.9 to 100 percent), respectively. Because none of the unilocular cysts subsequently developed into a cancer, the sensitivity and specificity improve to 100 percent (57.1 to 100 percent) and 100 percent (99.9 to100 percent), respectively, when calculated on a per-lesion basis. Followup time is a major strength of this study. The authors conclude that unilocular ovarian cysts are associated with a very low risk of malignancy and can be safely followed with serial ultrasound.

Schincaglia et al.^217^ performed a screening study of 3,541 asymptomatic postmenopausal patients. All patients underwent transabdominal ultrasonography with assessment of ovarian volume and morphology. Patients were divided into four groups based on the results of the initial ultrasound. All patients with ovarian volume > 15 ml (Group 4) were referred for repeat “level II” ultrasonography for morphologic assessment and fine needle aspiration (FNA) when feasible. Patients with ovarian volume between 9 and 15 ml (Group 3) were triaged to followup ultrasound at 3 and 6 months. Patients with ovarian volume < 9 cm but a cystic appearance (Group 2) were triaged to followup ultrasound in 6 months. Patients with ovarian volume < 9 ml and homogeneous appearance (Group 1) were considered negative and had no further intervention. Clinical followup at 1 year and pathology results if surgery was performed were considered the reference standard. Two hundred and eighty-three (283) patients (Groups 2 and 3) were deemed appropriate for followup using repeat ultrasound at 3- to 6-month intervals without the need for immediate referral for FNA/surgery. Of these 283 patients, 34 subsequently developed concerning ultrasound findings and were referred for a level II scan and/or possible FNA. The clinical results of this group of 34 are not given separately. Of the 249 who had non-concerning followup scans, none developed cancer with followup of at least 1 year (“true negatives”). Therefore, the specificity of ultrasound followup is 100 percent (95% CI, 98.8 to 100 percent) for patients with an initial abnormal but “probably benign” ultrasound. Sensitivity within this group cannot be calculated with the information given in the publication. The ability to answer Question 5 would be enhanced if specific outcomes of each of the four groups defined by the authors had been given. The study was also limited by the fairly short followup interval and the lack of prior or concurrent validation of the ultrasonographic groups defined in the study.

Kurjak et al.^127^ screened 5,013 women 40 years old or older (30.6% postmenopausal), of whom 404 had simple cysts with a diameter between 2.5 and 5 cm and a resistive index greater or equal to 0.41. These women received a followup scan in 6 months. Investigators reported the results of 88 women for whom the 6-month scan results were available. The definition of change prompting further diagnosis was not explicitly described. Of the 88 women, 18 ultimately underwent surgery based on the findings at 6 months, with one cancer detected and 17 benign lesions. Results stratified by menopausal status were not provided. This study was limited by lack of details on clinical decision rules, and short followup.

Castillo et al.^214^ screened 8,794 postmenopausal women; 215 had simple unilocular cysts less than 10 cm in diameter. Twelve percent of these masses were asymptomatic. These women underwent repeat ultrasound and CA-125 in 3 months, with subsequent followup studies every 6 months. Progression was defined as an increase in diameter of 1 cm or more, regression as a decrease of 1 cm, and resolution as absence of the cyst at 2 consecutive visits 6 months apart. Median followup was 27 months. There was one interval ovarian cancer between studies, and 44 women had benign masses removed. Although this study was among the highest quality studies in terms of reporting of relevant data, it is limited by the relatively small size and the high loss to followup (30.6%).

The remaining four studies^135,^ ^215,^ ^216,^ ^218^ were all small (less than 200 patients), and of variable quality (Table 23). None reported any interval cancers in patients receiving followup, or cancers detected during followup. The study of Valentin et al.^218^ was notable for length of followup (median 3 years) and complete ascertainment of followup status using Swedish cancer and death registry data.

### Discussion

There are limited data available to support a global definition of “probably benign” ovarian lesions or to support a specific method of interval testing to identify ovarian malignancy among patients in whom such lesions have been identified. For the most part, studies are limited by small size, variable length of followup, variable definitions of significant change and thresholds for intervention, and methods for followup.

The question of how best to define and evaluate “sensitivity” of followup regimens is a difficult one. Several factors need to be considered. First, interval cancers presenting between the initial study and the first followup visit may well be considered false negatives of the initial study; alternatively, they may reflect a too-long followup interval. Second, given the lack of data on the natural history of ovarian cancer, it is unclear whether cancers developing in benign-appearing lesions represent subclinical cancers present at the time of the initial diagnosis, or new cancers representing malignant transformation of a benign cyst. If the latter, then the ultimate success of any followup regimen may depend as much on the natural history of a given malignancy as on the sensitivity and specificity of the tests used for followup. Finally, cancers identified during followup should ideally have high survival rates (although whether such high survival rates would reflect the efficacy of the followup or the biology of cancers which are associated with benign-appearing cysts is unclear). The number of cancers identified in the reviewed studies was too small to draw any inferences about relative survival.

Overall, only two interval cancers occurred during followup in the studies identified (one prior to the first followup scan), and 10 cancers were identified during followup. As noted, an additional three cancers developed after resolution of a cyst or in the contralateral ovary. The highest quality study^40^ provides good evidence for the safety of prolonged followup with interval TVUS at 3- to 6-month intervals for patients with unilocular ovarian cysts of up to 10 cm in diameter, and the findings of the other studies are consistent with this conclusion.

## Question 6: Surgical Morbidity and Mortality

Question 6 is: Among women with adnexal masses, what are the morbidity and mortality from diagnostic surgery (laparoscopy or laparotomy)? At what point does the risk of surgery outweigh the risk of detecting malignancy?

### Approach

We searched the literature for studies that reported the morbidity and mortality of surgical management of adnexal masses. We also used the Nationwide Inpatient Sample (NIS) discharge database, maintained by the Agency for Healthcare Research and Quality (AHRQ), to obtain estimates of morbidity and mortality associated with diagnostic laparoscopy or exploratory laparotomy for a range of diagnoses associated with adnexal masses. The NIS is limited to inpatient procedures and does not cover ambulatory surgical centers, where some adnexal masses are likely to be managed, especially those masses thought to have a low likelihood of cancer. In addition to surgical complications, we also examined articles that provided data on the test characteristics of frozen section pathologic diagnosis; especially in the setting of minimally invasive procedures, false negative results on frozen section might lead to suboptimal surgical management and delayed therapy, while false positive results might lead to more extensive surgery than necessary, with possible implications for increased surgical morbidity and affects on ovarian function.

### Results of Literature Search and Screening

We identified 24 articles that met our inclusion criteria;^32,^ ^37,^ ^41,^ ^219^–^239^ these are summarized in Evidence Table 6 (Appendix D *). Twenty-two articles reported on the morbidity and mortality of surgical management of adnexal masses.^32,^ ^37,^ ^41,^ ^219^–^234,^ ^237^–^239^ In addition, two of the included articles reported on the sensitivity and specificity of frozen section;^220,^ ^236^ false negative frozen section results could lead to inadequate surgical management and delayed treatment, while false positive results could lead to more extensive surgery than necessary. Finally, one of the included articles addressed the potential effect of conservative surgery for removal of an ovarian cyst resulting from endometriosis (endometrioma) on subsequent fertility.^235^

### Methodological Quality of Included Studies

Size of population. None of the papers provided a description of the referral base; two^32,^ ^37^ were limited to gynecologic oncology practices. Lack of information on the referral base prevents assessment of generalizability. Since all of these studies were performed in centers experienced in laparoscopic surgery, the generalizability may well be limited.

Number of cases. Five studies had fewer than 200 cases, with correspondingly wide confidence intervals for reported event rates. Two studies had larger numbers of cases, 683^230^ and 757.^219^ However, the study by Marana et al.^230^ was limited to women under 40.

Patient selection. None of the studies reported how patients were referred to the surgical practices. All provided criteria for laparoscopic management of masses, based on various criteria to suggest high or low risk of malignancy. We found two trials where patients were randomized to laparoscopy or laparotomy,^224,^ ^225^ but randomization methods were not well described.

Application of reference standard. In this sense, “reference standard” refers to the method by which a complication was diagnosed. Only two studies described followup beyond 8 weeks, but they did not detail whether all patients underwent similar followup protocols.

### Results

There were three deaths in one study of 146 patients (all undergoing laparoscopy), and none in any of the other studies (a total of 5,599 patients). Pooling all patients, the mortality was 0.05 percent, with a 95% CI of 0.01 to 0.17 percent.

Table 24 shows the results from individual studies. The two randomized studies^224,^ ^225^ both showed lower morbidity with laparoscopy compared to laparotomy, although only one of them^224^ had sufficient power to show a statistically significant difference. Although the study of Deckardt and colleagues^224^ was randomized, there were substantial differences in the procedures performed in each arm. Laparoscopy patients tended to undergo more conservative procedures: they were significantly more likely to have cystectomy (60.0 vs. 20.2 percent), less likely to have oophorectomy (0.8 vs. 20.2 percent), and less likely to have bilateral salphingo-oophorectomy (4.0 vs. 21.4 percent). Both studies where laparoscopy was directly compared to laparotomy showed increased complication rates (primarily postoperative complications) among the laparotomy patients. The four non-randomized studies all showed higher morbidity rates with laparoscopy, but there were substantial differences in patient selection criteria.

Table 24 Morbidity in series of patients undergoing surgical management of adnexal masses

Study | N | Patient population | Complication rate (95% CI) | Notes
Randomized trials of laparoscopy versus laparotomy
Deckardt et al., 1994^224^ | 192 | 22.4% laparoscopy, | Laparotomy: 30.3% (21.8 to 42.3%) | “Randomized,” but some differences between two arms
| | 26.4% laparotomy postmenopausal | Laparoscopy: 11.2% (6.8 to 18.7%) | 3.5% conversion
Fanfani et al., 2004^225^ | 100 | Laparoscopy: 10% postmenopausal | Laparotomy 6% (1.8 to 17.5%) | No malignancies
| | Laparotomy: 20% postmenopausal | Laparoscopy 0% (0 to 10.6%) | Small sample size
Non-randomized comparisons
Hidlebaugh et al., 1997^227^ | 405 | 199 laparoscopy | Laparotomy 27.2% (21.8 to 34.0%) | Selection criteria for laparoscopy not defined
| | 206 laparotomy | Laparoscopy 2.5% (1.0 to 6.0%) | Potential other risk factors for complications not described
| | 20.2% postmenopausal
Yuen et al., 1997^239^ | 110 | Laparotomy: 6% postmenopausal | Laparotomy 28% (18.5 to 43.1%) | Difference between complication rates attributable to higher number of postoperative complications in laparotomy group
| | Laparoscopy: 3.8% postmenopausal | Laparoscopy: 9.6% (4.2 to 21.8%)
Carley et al., 2002^221^ | 106 | 44 laparotomy | Laparotomy 4.6% (0.7 to 16.7%)
| | 62 laparoscopy | Laparoscopy 0% (0 to 8.6%)
| | Menopausal status not reported
Chapron et al., 1997^222^ | 186 | 121 laparoscopy, | Laparotomy: 15.4% (8.9 to 27.0%) | Patients with high suspicion of malignancy went directly to laparotomy
| | 65 laparotomy | Laparoscopy: 8.3% (4.6 to 15.0%) | Results not analyzed by “intention to treat”—19 of laparotomy patients started as laparoscopy
| | 43% postmenopausal | | 13.6% of laparoscopies converted to laparotomy
Laparoscopy only
Childers et al., 1996^32^ | 138 | Not described in detail; age range 9–91 | 10.1% (6.2 to 16.7%) | Length of followup not given for benign cases
| | | | Gynecologic oncology service
| | | | Results not stratified by age or menopausal status
| | | | 8.0% conversion to laparotomy
Canis et al., 1994^219^ | 757 | 11.4% postmenopausal | 1.1% (0.53 to 2.1%) | Mean followup 42 months (range 3–153 months)
Dottino et al., 1999^37^ | 160 | 53% postmenopausal | 7.5% (4.3 to 12.9%) | Gynecologic oncology service
Marana et al., 2004^230^ | 620 | All less than 40 years old | 0.9% (0.4 to 2.0%) | Mean followup 30 months
| | | | Single surgeon
Parker et al., 1994^41^ | 61 | 100% postmenopausal | 3.3% (0.4 to 12.3%) | Masses “presumptively benign” based on imaging, exam, clinical history
| | | | 4.9% conversion
Sadik et al., 1999^232^ | 220 | 3.2% postmenopausal | 0.9% (0.06 to 3.5%) | Malignant masses “excluded from study”
Chi et al., 2004^223^ | 146 | Menopausal status not reported; median age 54 | Mortality 2.5% (0.5 to 6.3%) | Clinical history not described—not clear if other conditions besides adnexal mass included
| | | Morbidity 22.1% (15.1 to 32.7%)
Havrilesky et al., 2003^226^ | 396 | 37.2% postmenopausal | Laparoscopy 8.3% (6.0 to 11.6%) | Risk of complication increased with concurrent hysterectomy
Lok et al., 2000^228^ | 513 | 5.5% postmenopausal | Laparoscopy 13.3% (10.6 to 16.6%) | No malignancies 75.% symptomatic
Mann and Reich, 1992^229^ | 44 | 100% postmenopausal | Laparoscopy 4.6% (0.7 to 16.7%) | 1/44 had cancer
Parker and Proietto, 1997^231^ | 86 | Menopausal status not reported | Laparoscopy 22.1% (15.1 to 32.7%) | 1/86 had cancer
Serur et al., 2001^233^ | 100 | 49% postmenopausal | Laparoscopy 10% (5.6 to 19.0%) | -
Shalev et al., 1994^234^ | 55 | 100% postmenopausal | Laparoscopy 10.9% (5.2 to 22.9%) | -
Tarik and Fehmi, 2004^237^ | 1478 | Menopausal status not reported (but mean age 30) | Laparoscopy: Diagnostic procedures 1.8% (0.8 to 3.8%) | Proportion with preoperative diagnosis of adnexal mass not reported
| | | Minor procedures: 1.4% (0.8 to 2.3%)
Van Herendael et al., 1995^238^ | 121 | Menopausal status not reported | Laparoscopy: 1.7% (0.1 to 6.4%) | -

Abbreviation: CI = confidence interval

In series of laparoscopy cases, morbidity rates ranged from 0.9 percent to 22.1 percent (Table 24); series differed widely in their selection criteria for laparoscopic management of the mass. Few stratified results based on menopausal status; in some cases, postmenopausal patients were explicitly excluded. In one study where multivariate analysis was performed to assess for risks of morbidity, performance of additional procedures (hysterectomy) significantly increased the risk of morbidity, while a history of hysterectomy increased the likelihood of conversion to laparotomy (presumably because of increased technical difficulty secondary to postoperative adhesions).^226^

### Nationwide Inpatient Sample

Table 25 shows the estimated numbers of discharges in the United States in 2000-2001 under each diagnostic class and procedure (standard errors not shown for simplicity). The results illustrate the difficulty in using discharge data to attempt to estimate morbidity and mortality rates for surgical procedures. Both morbidity and mortality are highest for cancer diagnoses, but there is no way to determine the extent to which the underlying disease process contributed to either complications or death; for example, “exploratory laparotomy” or “diagnostic laparoscopy” in many ovarian cancer patients likely represents a “second-look” procedure done to determine response to chemotherapy. Outcomes of these procedures are not relevant to estimating the risks of a primary diagnostic procedure. The laparoscopies that are included in the NIS are likely not representative of all laparoscopies for adnexal masses; since the NIS does not capture surgeries performed at ambulatory surgery centers, the cases within the NIS may represent those for which surgeons had a higher index of suspicion of malignancy, or anticipated higher technical difficulty. Another major limitation is the inability to distinguish between the initial indication for surgery and the final diagnosis. Finally, in order to try to eliminate confounding by additional procedures, we excluded cases in which hysterectomy was performed - however, because hysterectomy is part of the standard initial surgical treatment of ovarian cancer, many cases of initial management are excluded.

Table 25 Estimated U.S. discharges for exploratory laparotomy and diagnostic laparoscopy with discharge diagnoses consistent with adnexal mass, with mortality and complication rates

| Number of discharges | Died | Mortality rate | Complications | Complication rate
OVARIAN CANCER | 118,042 | 7099 | 6.0% | 515 | 0.4%
Laparoscopy (no ovarian procedures) | 222 | 5 | 2.3% | 0 | 0.0%
Laparoscopy plus conservative ovarian procedure | 27 | 0 | 0.0% | 0 | 0.0%
Laparoscopy plus oophorectomy | 16 | 0 | 0.0% | 0 | 0.0%
Laparotomy (no ovarian procedure) | 566 | 11 | 1.9% | 5 | 0.9%
Laparotomy plus conservative ovarian procedure | 68 | 0 | 0.0% | 0 | 0.0%
Laparotomy plus oophorectomy | 36 | 0 | 0.0% | 0 | 0.0%
OTHER ADNEXAL CANCER | 780 | 15 | 1.9% | 5 | 0.6%
Laparoscopy (no ovarian procedures) | 0 | 0 | 0.0% | 0 | 0.0%
Laparoscopy plus conservative ovarian procedure | 0 | 0 | 0.0% | 0 | 0.0%
Laparoscopy plus oophorectomy | 0 | 0 | 0.0% | 0
Laparotomy (no ovarian procedure) | 15 | 15 | 100.0% | 0 | 0.0%
Laparotomy plus conservative ovarian procedure | 0 | 0 | 0% | 0
Laparotomy plus oophorectomy | 0 | 0 | 0% | 0
BENIGN OVARIAN NEOPLASM | 145,024 | 255 | 0.2% | 964 | 0.7%
Laparoscopy (no ovarian procedures) | 1,560 | 5 | 0.3% | 35 | 2.2%
Laparoscopy plus conservative ovarian procedure | 75 | 0 | 0.0% | 0 | 0.0%
Laparoscopy plus oophorectomy | 24 | 0 | 0.0% | 0 | 0.0%
Laparotomy (no ovarian procedure) | 700 | 4 | 0.6% | 16 | 2.3%
Laparotomy plus conservative ovarian procedure | 72 | 0 | 0.0% | 0 | 0.0%
Laparotomy plus oophorectomy | 31 | 0 | 0.0% | 0 | 0.0%
PELVIC MASS | 13,625 | 30 | 0.2% | 60 | 0.4%
Laparoscopy (no ovarian procedures)
Laparoscopy plus conservative ovarian procedure | 41
Laparoscopy plus oophorectomy
Laparotomy (no ovarian procedure) | 35 | 5 | 14.3%
Laparotomy plus conservative ovarian procedure
Laparotomy plus oophorectomy
OVARIAN CYSTS | 474,485 | 376 | 0.08% | 3045 | 0.6%
Laparoscopy (no ovarian procedures) | 5,508 | | 0.00% | 65 | 1.2%
Laparoscopy plus conservative ovarian procedure | 274 | | 0.00% | | 0.0%
Laparoscopy plus oophorectomy | 173 | | 0.00% | | 0.0%
Laparotomy (no ovarian procedure) | 1,429 | 79 | 5.53% | 19 | 1.3%
Laparotomy plus conservative ovarian procedure | 99 | | 0.00% | | 0.0%
Laparotomy plus oophorectomy | 86 | | 0.00% | | 0.0%
PARA-OVARIAN CYST | 21,807 | 5 | 0.0% | 92 | 0.4%
Laparoscopy (no ovarian procedures) | 271 | | 0.0% | | 0.0%
Laparoscopy plus conservative ovarian procedure | 24 | 0 | 0.0% | 0 | 0.0%
Laparoscopy plus oophorectomy | 9 | 0 | 0.0% | 0 | 0.0%
Laparotomy (no ovarian procedure) | 61 | 10 | 16.4% | 0 | 0.0%
Laparotomy plus conservative ovarian procedure | 5 | 0 | 0.0% | 0 | 0.0%
Laparotomy plus oophorectomy | 5 | | 0.0% | | 0.0%
PELVIC INFLAMMATORY DISEASE | 430,027 | 439 | 0.1% | 4793 | 1.1%
Laparoscopy (no ovarian procedures) | 7,184 | 4 | 0.1% | 150 | 2.1%
Laparoscopy plus conservative ovarian procedure | 445 | 0 | 0.0% | 9 | 2.0%
Laparoscopy plus oophorectomy | 159 | 0 | 0.0% | 5 | 3.1%
Laparotomy (no ovarian procedure) | 2,129 | 10 | 0.5% | 53 | 2.5%
Laparotomy plus conservative ovarian procedure | 160 | 0 | 0.0% | 0 | 0.0%
Laparotomy plus oophorectomy | 45 | 0 | 0.0% | 0 | 0.0%
NORMAL PELVIS | 108.8 | 0 | 0 | 0 | 0

### Other Outcomes

We identified two studies that reported on the sensitivity and specificity of intraoperative frozen section done to determine pathologic diagnosis.^220,^ ^236^ They reported similar findings. Both studies defined low malignant potential tumors as cancer. Canis et al.^220^ reported a sensitivity of 92.2 percent and a specificity of 92.2 percent in 141 women (29.8 percent postmenopausal, 35 percent with cancer or low malignant potential tumors). Tangjitgomol et al.^236^ estimated similar values, with a reported sensitivity of 91.3 percent and specificity of 93.3 percent in 212 women (menopausal status not reported, cancer prevalence 77 percent). Defining low malignant potential cancers as benign decreased sensitivity in both cases.

We identified only one article that addressed the potential impact of surgical management of benign cysts on fertility. Somigliana et al.^235^ followed 32 women who received ovarian stimulation after removal of an endometriotic cyst. The mean number of follicles observed in the ovary where the cyst had been removed (2.0 ± 1.5) was significantly lower than in the contralateral ovary (4.2 ± 2.5), suggesting that the surgical procedure may have led to decreased ovarian reserve. An alternative explanation is that the cyst itself had an adverse effect on ovarian reserve.

### Discussion

Ideally, reports of adverse outcomes of diagnostic surgery for adnexal masses would be divided into four separate categories, based on preoperative symptoms and postoperative findings: (1) women with symptomatic masses which ultimately proved malignant; (2) women with symptomatic masses which ultimately proved benign; (3) women with asymptomatic masses which ultimately proved malignant; and (4) women with asymptomatic masses which ultimately proved benign. For the first three groups, the operative procedure could be considered appropriate even in the event of morbidity, since there is some benefit (primary surgical therapy for malignancy, or management of symptomatic nonmalignant adnexal pathology) to be gained from surgical diagnosis and treatment. For women with asymptomatic benign masses, there are theoretical benefits for detecting some benign masses, including (1) prevention of subsequent malignant transformation, (2) avoidance of rupture which, for certain benign masses (endometrioma and mature teratoma) could cause acute symptoms, (3) easier surgical management, with fewer complications, compared to management of a larger symptomatic mass, (4) avoidance of torsion (twisting of the adnexa) and emergent surgical management and (5) avoidance of effects on fertility, either from the underlying condition itself or from more extensive surgery for a larger mass. However, we did not identify any evidence for these benefits; the probabilities of these potential benefits also would differ widely depending on the underlying pathology and natural history of a particular mass, the patient's age and reproductive status, and other comorbidities.

Unfortunately, neither the literature nor available discharge data allow estimates of the probabilities of outcomes based on initial presentation. In the case of the literature, this is because of a lack of reporting of the clinical path by which patients come to undergo surgery. In the case of discharge data, it is because of the inherent limitations of the International Classification of Diseases, Ninth Revision (ICD-9) coding. Even if more recent data on ambulatory surgery were available, it would still be limited by coding.

### Summary

Mortality for laparoscopic management of adnexal masses at experienced centers appears to be quite low, although the upper bound of this low rate is unclear.

Patient characteristics that determine risk of morbidity are unclear, although the need for more extensive procedures appears to increase the risk. Laparoscopy may have a lower morbidity rate than laparotomy, but this appears to be due, at least in part, to different patient selection criteria and surgical procedures performed.

Two small studies suggest that the false negative rate of intraoperative frozen section diagnosis is approximately eight percent, and the false positive rate is approximately five to seven percent. Whether either type of false result has a significant impact on outcome is unclear.

There is suggestive evidence that removal of a cyst in premenopausal women may affect ovarian reserve, potentially affecting fertility and/or age of menopause, but the underlying pathologic process may also play a role. More data are needed.

There are no data to allow estimation of the risks of a diagnostic procedure in the patient with an asymptomatic mass, or to assess the benefits of surgery in that patient compared to the risk of malignancy.

## Question 7: Modeling Diagnostic Strategies

Question 7 is: What are the estimated trade-offs resulting from various strategies for evaluation of the adnexal mass?

### Approach

A formal decision analytic approach is often quite helpful for synthesizing evidence coming from a range of sources, of varying quality, and of varying degrees of precision in estimates. Such models are also helpful in identifying which parameters are most important, in order to prioritize future research. Ideally, the underlying natural history of the disease in question can be modeled, with the impact of subsequent clinical interventions estimated based on test characteristics, effectiveness and morbidity from treatment, patient preferences, etc. In addition, the effect of varying both the incidence and natural history of ovarian cancer based on risk factors such as genetic predisposition can also be taken into account if adequate data are available. For example, such models have been quite helpful in exploring the impact of various interventions for cervical cancer prevention.^240^ In addition, data from currently ongoing trials of ovarian cancer screening will also provide valuable data on natural history. ^241^

Because of the methodological limitations of the literature on management of adnexal masses cited in the previous sections, a formal decision analysis does not seem appropriate at this time. In order to illustrate some of the key areas for future research, we did a simple estimate of the expected outcomes of several strategies for evaluation of the adnexal mass based on the findings of this review. Because models will ultimately need to incorporate the natural history of ovarian cancer, either to evaluate screening or to estimate the consequences of false negative diagnoses, we also performed a literature review of existing models of the natural history of ovarian cancer and the impact of screening or testing and developed an alternative model.

### Predicting Outcomes of Management Strategies

As an example, we can consider one clinical scenario: an asymptomatic postmenopausal woman undergoing a routine bimanual pelvic examination. If the bimanual examination is abnormal, she can undergo a variety of additional tests. We compared several strategies: (1) performing CA-125 only, then operating on women with values greater or equal to 35;(2) performing an ultrasound with Doppler velocimetry (the strategy with highest sensitivity and specificity in our review) and operating on women with positive results both morphologically and with Doppler; (3) performing CA-125, then performing ultrasound with Doppler on women with elevated CA-125 and operating on women with positive ultrasounds; (4) performing ultrasound with Doppler first, then performing CA-125 on women with positive ultrasound results, and operating on women with elevated CA-125, and (5) performing both ultrasound and CA-125 and combining these results with menopausal status to use the RMI (discussed in detail under Question 4); women with RMI scores above the threshold undergo surgery. Strategies 3 and 4 are examples of serial testing, Strategy 5 an example of parallel testing. Table 26 provides estimates for key parameters based on the previous chapters; estimates for test characteristics are taken from the point estimates of the pooled random-effects models.

Table 26 Estimates for key model parameters

Parameter | Value
Prevalence of adnexal masses in postmenopausal women (Question 1) | Malignant: 0.1%
| Benign: 1.0%
Sensitivity of the pelvic examination to detect adnexal masses (Question 2) | 0.45
Specificity of the pelvic examination to detect adnexal masses (Question 2) | 0.90
Sensitivity of combined morphology and Doppler (Question 3) | 0.86
Specificity of combined morphology and Doppler (Question 3) | 0.91
Note: We assumed that the specificity of ultrasound for determining the absence of pelvic mass was 100%.
Sensitivity of CA-125 in postmenopausal women (Question 3) | 0.80
Specificity of CA-125 in postmenopausal women (Question 3) | 0.87
Sensitivity of RMI (Question 4) | 0.74
Specificity of RMI (Question 4) | 0.91

Abbreviation: RMI = Risk of Malignancy Index

At the initial pelvic examination, the probability of detecting a mass equals:

Probability of true positive test + Probability of true negative test, or (Prevalence of mass * Test sensitivity) + (1-Prevalence of mass)*(1-Test Specificity)

Similarly, the probability of a negative test equals:

Probability of true negative + Probability of false negative, or (1-Prevalence)*Test Specificity + Prevalence*(1-Sensitivity)

At the time of ultrasound, the “prevalence” of disease is equal to the positive predictive value of the preceding test, the ultrasound, or:

Probability of true positive pelvic/(Probability of true positive pelvic + Probability of false negative pelvic)

Similar calculations were made for each test or combination of tests.

Table 27 shows the predicted outcomes (in terms of detected and missed cancers) of testing with either ultrasound morphology with Doppler velocimetry or CA-125 alone in a hypothetical cohort of 100,000 postmenopausal women.

Table 27 Predicted outcomes of ultrasound plus Doppler or CA-125 testing to determine surgical management in a hypothetical cohort of 100,000 postmenopausal women*

| Underlying pathology | | | | Prevalence of malignancy among test positives | Proportion of all tests positive | Missed cancers
| Cancer | Benign mass | Normal | Total
Baseline cases | 100 | 1,000 | 98,900 | 100,000 | 0.1%
Pelvic exam
Positive | 45 | 450 | 9,890 | 10,385
Negative | 55 | 550 | 89,010 | 89615 | 0.4% | 10.4% | 55
STRATEGY: CA-125 only
CA-125
Positive | 36 | 59 | 1,286 | 1,380
Negative | 9 | 392 | 8,604 | 9,005 | 2.6% | 15.3% | 9
Surgery
Positive | 36 | | | 36
Negative | | 59 | 1286 | 1,345 | | 2.6%
STRATEGY: Morphology/Doppler only
Morphology/Doppler
Positive | 39 | 41 | 0 | 80
Negative | 6 | 410 | 9,890 | 10,306 | 49.8% | 0.8% | 6
Surgery
Positive | 39 | 0 | 0 | 39
Negative | 0 | 41 | 0 | 41 | | 49.8%

* Some numbers may not add up correctly because of rounding.Abbreviation: CA-125 = cancer antigen 125

Table 28 shows the predicted outcomes of the serial and parallel testing strategies.

Table 28 Predicted outcomes of serial testing or parallel testing with ultrasound plus Doppler or CA-125 testing to determine surgical management in a hypothetical cohort of 100,000 postmenopausal women*

| Underlying pathology | | | | Prevalence of malignancy among positive tests | Proportion of all tests positive | Missed cancers
| Cancer | Benign mass | Normal | Total
Baseline cases | 100 | 1,000 | 98,900 | 100,000 | 0.1%
Pelvic exam
Positive | 45 | 450 | 9,890 | 10,385
Negative | 55 | 550 | 89,010 | 89,615 | 0.4% | 10.4% | 55
STRATEGY: CA-125, followed by morphology/Doppler
CA-125
Positive | 36 | 59 | 1,286 | 1,380
Negative | 9 | 392 | 8,604 | 9,005 | 2.6% | 13.2% | 9
Morphology/Doppler
Positive | 32 | 5 | 0 | 37
Negative | 4 | 53 | 1,286 | 1,343 | 86.5% | 2.7% | 4
Surgery
Positive | 32 | 0 | 0 | 32
Negative | 0 | 5 | 0 | 5
STRATEGY: Morphology/Doppler followed by CA-125
Morphology/Doppler
Positive | 40 | 41 | 0 | 81
Negative | 5 | 410 | 9,890 | 10,305 | 49.4% | 0.8% | 5
CA-125
Positive | 32 | 5 | 0 | 37
Negative | 8 | 35 | 0 | 43 | 86.5% | 45.7% | 8
Surgery
Positive | 32 | | | 32
Negative | 0 | 5 | 0 | 5 | | 86.5%
STRATEGY: RMI (morphology + CA-125 + menopausal status)
RMI
Positive | 33 | 41 | 0 | 74
Negative | 12 | 410 | 9,890 | 10,312 | 44.6% | 13.2% | 9
Surgery
Positive | 33 | 0 | 0 | 33
Negative | 0 | 41 | 0 | 41 | | 44.6%

* Some numbers may not add up correctly because of rounding.Abbreviations: CA-125 = cancer antigen 125; RMI = Risk of Malignancy Index

Table 29 summarizes the outcomes of the five strategies in terms of total number of tests, total number of missed cancers, and total number of surgeries.

Table 29 Estimated numbers of tests, missed cancers, and surgeries for each strategy

| Strategies
| Single tests | | Serial tests | | Parallel tests
| CA-125 | Ultrasound* | CA-125 followed by ultrasound | Ultrasound followed by CA-125 | Risk of Malignancy Index
Total tests | 10,385 | 10,385 | 11,765 | 10,466 | 20,770
Total missed cancers | 9 | 9 | 13 | 13 | 9
Total surgeries | 1,380 | 80 | 37 | 37 | 74

Abbreviation: CA-125 = cancer antigen 125

Table 30 illustrates the effect of increasing the prevalence of cancer (for example, in symptomatic women with a known mass) from 0.1 percent to 10 percent. The size of the cohort here is 1,100 women with masses (the same as in the screening cohort).

Table 30 Estimated numbers of tests, missed cancers, and surgeries for each strategy in 1,100 women with known adnexal mass and underlying prevalence of ovarian cancer 10%

| Strategies
| Single tests | | Serial tests | | Parallel tests
| CA-125 | Ultrasound* | CA-125 followed by ultrasound | Ultrasound followed by CA-125 | Risk of Malignancy Index
Total tests | 1,100 | 1,100 | 1,317 | 1,287 | 2,200
Total missed cancers | 20 | 15 | 32 | 32 | 26
Total surgeries | 197 | 184 | 90 | 90 | 155

Abbreviation: CA-125 = cancer antigen 125

This simple “model” illustrates several key points:

- The prevalence of malignancy increases as additional diagnostic tests are performed. This is certainly clinically appropriate and reflects the effects of sequential testing strategies. However, specificity and, to some extent, sensitivity for many of the tests reviewed appear to vary with underlying disease prevalence. Thus, estimates for test characteristics calculated at one point in the clinical pathway may not be appropriate for other points.
- Despite a poor sensitivity of 45 percent, the negative predictive value of a negative pelvic examination for malignancy is quite high (99.94 percent). The reassurance provided by a “normal” exam reflects the epidemiology of the underlying disease, rather than the intrinsic value of the test in discriminating benign from malignant. This reflects the low prevalence of ovarian cancer in the population. Conversely, the positive predictive value is only 0.4 percent, despite a specificity of 92 percent.
- In order to judge the trade-offs between detection of masses that ultimately prove malignant compared with the risks of diagnostic surgery, we would need better estimates of morbidity and mortality within different diagnostic categories - as noted previously, these do not exist.
- The most “efficient” strategy in terms of number of tests and surgeries is serial testing with ultrasound followed by CA-125; however, this results in four missed cancers compared with parallel testing using the RMI. However, parallel testing doubles the number of tests to be performed. A formal cost-effectiveness analysis requires significantly more data on test characteristics and ovarian cancer natural history, as well as the morbidity of surgical management.
- Modeling parallel testing beyond the data in scoring systems is difficult. Besides requiring specific assumptions about how results that were positive for one test but negative for another would be managed, one would also need to know if the sensitivity and specificity of each test were independent or correlated in some way. For example, it seems likely that the sensitivity of both ultrasound and CA-125 would be greater for larger masses than for smaller masses.
- In scenarios where the likelihood of ovarian cancer is higher, the negative predictive value of any diagnostic strategy will decrease (more missed cancers), and the positive predictive value will increase (the proportion of surgical cases where cancer is found will be higher). This is seen clearly by comparing Tables 29 and 30. The number of women with adnexal masses is the same, but the number of missed cancers is substantially higher with each strategy.
- In addition, for any screening modality, there needs to be evidence that early detection reduces disease-specific morbidity and mortality. In addition, in order to judge the impact of false negative results, data on the natural history of ovarian cancer are also needed. Since data from large trials are still pending, one way to examine the potential impact of different testing strategies for both initial screening and subsequent testing is through the development of simulation models.
  We next review published models of the natural history of ovarian cancer.

### Models of Ovarian Cancer: Literature Review

Four articles were identified from the literature review that used modeling to determine the effectiveness and cost-effectiveness of different screening strategies for the detection and treatment of ovarian cancer. These are described in Evidence Table 7 (Appendix D *). Studies were included if they were directly relevant to Question 7,^242^–^244^ or provided natural history information that could be used in the construction of a model.^245^

Schapira et al.^242^ conducted a decision analysis comparing a one-time screen using transvaginal sonography and CA-125 either alone or in combination to determine life-expectancy gains in a cohort of 40-year-old women in the United States. In the model women could either be screened or unscreened. Probabilities were derived from the literature for the following: prevalence of disease in 40-year-old women, percentage of early stage disease, clinical detection of disease, sensitivity of the screening test for detection of early stage disease, specificity of the screening test, and the mortality rate associated with diagnostic laparotomy. Life expectancy was calculated for women who had no disease, early stage disease, and late stage disease. Table 31 summarizes key input parameters and ranges.

Table 31 Key input parameters and ranges for the Schapira model^242^

Parameter | Value | Range | Source
Prevalence of ovarian cancer | 28.6/100,000 | 20 to 200/100,000 | NCI monograph No. 41; 1975
Percentage of prevalent cases in early stage | 50% | 20 to 80% | Assumed
Percentage of early stage disease diagnosed clinically | 25% | 20 to 80% | ACS Cancer Statistics 1990
Sensitivity of CA-125 and TVUS (combined) for early stage disease | 45% | 20 to 80% | Literature review
Sensitivity of CA-125 and TVUS (combined) for late stage disease | 81% | 50 to 100% | Literature review
Specificity of CA-125 and TVUS | 99.95% | 96 to 100% | Literature review
Probability of post-laparotomy death | 0.23% | 0 to 10% | National Halothane Study JAMA 1966

Abbreviations: ACS = American Cancer Society; NCI = National Cancer Institute; TVUS = transvaginal ultrasound

Assumptions in the model were that survival time for clinically and screen-detected early stage disease is the same; morbidity and mortality rates associated with diagnostic laparotomy are the same for people with and without the disease; and there is no benefit gained from identifying benign disease.

The results of the analysis suggested that use of the combined strategy would result in a gain in life expectancy (compared to no screening) of one third of a day of life. No screening was preferred if the postoperative mortality rate exceeded 7.32 percent or the specificity of the test was less than 98.53 percent. An additional analysis, examining the use of testing for women aged 65+ suggested that the combined strategy would result in an average gain in life expectancy of approximately 3/4 of a day of life.

Skates and Singer^244^ developed a stochastic model to evaluate screening with CA-125. Key assumptions in this model included:

- Stepwise progression from Stage I through Stage II through Stage III through Stage IV;
- Log-normal distributions of progression rates;
- Stage at clinical detection independent of duration of disease;
- The coefficient of variation in stage length is constant across all stages;
- Estimates for the duration of each stage were provided by two gynecologic oncologists.

In the base case, the model predicted that screening would save 3.4 years of life per detected case; of note, estimates for the gains in life expectancy for the entire population undergoing screening were not provided.

Urban et al.^243^ examined the cost-effectiveness of screening using CA-125 and TVUS alone or in combination in a cohort of 1 million 50-year-old women using a stochastic simulation model, building on the model of Skates and Singer (Table 32). Screening and case ascertainment was assumed to occur over a 3-year period; women were assumed to be followed until age 80 or death.

Table 32 Key assumptions and data sources used to derive values for parameters in the Urban model ^243^

Parameter | Estimate | Source
Stage of ovarian cancer | FIGO
Relative stage lengths (relative to Stage 1) | 0.5, 1.333, 0.333 | Skates et al.^244^ FIGO stages III and IV assumed to comprise SEER stage 3
Geometric mean stage length in months | 9; 4.5, 12 and 3 months
Probability of disease during testing period | 0.0121 | Not stated
Probability of age at clinical detection | Age 50–54 - 0.153 | SEER
| Age 55–59 - 0. 184
| Age 60–64 - 0.202
| Age 65–69 - 0.179
| Age 70–74 - 0.150
| Age 75–80 - 0.132
Probability of stage at clinical detection | Stage 1 - 0.223 | SEER
| Stage 2 - 0.153
| Stage ¾ - 0.624
Point in stage at clinical detection | 0.5 of stage length | Assumed
Stage length distribution | Log normal (9, 4.5) | Assumed
TVUS sensitivity | 100% | van Nagell, CA 1990
| | van Nagell, CA 1991
TVUS - false positive | 1^st^ screen 0.019; | Campbell, Br J Obstet and Gynecol 1990
| 2^nd^ screen 0.010;
| 3^rd^screen 0.006
CA-125 level in cases | Refer to page 254 of article for formula | Skates et al.^244^ Einhorn, Proc Am Soc Clin Oncol 1990
% of false negatives for CA-125 | 5% | Assumption
CA-125 specificity in women with false positive TVUS | 0.85 | Bast, Gyn Onc 1985
| | Woolas, JNCI, 1993
Return to normal life-expectancy post-diagnosis | 15 years | Assumption
Probability of death in surgery among false-positive | 0.001 | Assumption

Abbreviations: FIGO = International Federation of Gynecology and Obstetrics; SEER = Surveillance, Epidemiology, and End Results; TVUS = transvaginal ultrasound

Six screening strategies using TVUS and CA-125 either alone or in combination: annual TVUS; annual CA-125, elevated (35U/ml used for referral to laparoscopy); annual CA-125, rising or elevated (rising defined as CA-125 level that has doubled since last screen); annual TVUS conditional on rising or elevated CA-125; 6-month TVUS condition on rising or elevated CA-125; 2-year TVUS conditional on rising or elevated CA-125. Of these, the strategy of annual TVUS conditional on rising or elevated CA-125 was identified as efficient, meaning it saved an equivalent if not higher amount of life at lower costs compared to other strategies. The model was especially sensitive to assumptions about the duration of Stage I disease.

### Discussion

Secondary prevention of cancer mortality through screening has been remarkably effective in the case of cervical cancer. Mammography has also reduced mortality from breast cancer, although there remains some controversy. To date, although survival in early stage ovarian cancer is considerably higher than survival in later stage cancers, trials of screening have not yet demonstrated reduction in disease-specific mortality. Although the relative lack of effectiveness of ovarian cancer screening to date may reflect the lack of an appropriate test, differences in the biology and natural history of the different cancers may also result in some of the differences.

As outlined in a recent review,^246^ the most critical criteria for an effective screening strategy for ovarian cancer is that there is a time of sufficient duration during the development of ovarian cancer when cancer is detectable but in a stage when treatment effectiveness is high. As shown in the two most sophisticated models reviewed, estimates of the effectiveness of screening are highly dependent on assumptions about the duration of Stage I cancer. The basis for the estimates used in both models was the opinion of two clinicians; the methods used to derive these estimates were not described.

Cervical cancer is, in the majority of cases, a squamous carcinoma, which spreads primarily through direct extension and secondarily through lymphatic invasion. The most common type of ovarian cancer, on the other hand, is typically an adenocarcinoma, which spreads by dissemination of tumor cells throughout the peritoneal cavity.

One assumption commonly made in the models of ovarian cancer we identified is that ovarian cancer staging represents the natural history. Figure 24 illustrates a simplified schematic model used in all three of the reviewed papers. Patients can develop ovarian cancer, die of other causes, or remain healthy. Those who develop ovarian cancer can present with symptoms or through testing to become an incident case, or remain undetected, and can either remain within the same stage or progress to the next.

Figure 24. Schematic of Markov or stochastic model of ovarian cancer natural history

Although this stepwise progression through stages is the case for cervical cancer, there is no evidence to suggest that tumors limited to the ovary (Stage I) must necessarily spread first to adjacent pelvic organs (Stage II) prior to spread throughout the peritoneal cavity (Stage III). Although staging systems represent the extent of disease, they are developed to help with prognosis, and to allow comparison of treatment effectiveness - there is no explicit assumption that each stage necessarily must be preceded by the next lowest one. Figure 25 depicts an alternative model, which allows some Stage I cancers to progress directly to Stage III:

Figure 25. Alternative model of ovarian cancer history

Using the Markov model described in Chapter 2, we performed sensitivity analyses on progression rates and type of progression to determine if this second “model” of progression could result in similar stage distributions to observed data.

Figure 26 compares the predicted incidence of ovarian cancer derived from the model with incidence rates reported in the Surveillance, Epidemiology, and End Results (SEER) data set, under the assumption that there was a stepwise progression from Stage I through Stage IV:

Figure 26. Model predictions of ovarian cancer incidence (black triangles) compared to SEER incidence rates (closed circles)

We then allowed a proportion of Stage I cancers to proceed directly to Stage III and calibrated underlying progression rates. Table 33 compares the model input parameters and resulting stage distribution of the two models.

Table 33 Inputs and outputs of ovarian cancer models

| Model 1 (Stage 1 must progress through Stage II) | Model 2 (some Stage I can progress directly through Stage III) | Stage distribution: FIGO (local data from Skates et al.^244^) | Stage distribution: SEER (1995-2001)
Parameter estimate
Annual probability of presenting with symptoms: Stage I | 0.095 | 0.1
Annual probability of presenting with symptoms: Stage II | 0.095 | 0.15
Annual probability of presenting with symptoms: Stage III | 0.7 | 0.9
Annual probability of presenting with symptoms: Stage IV | 1 | 1
Proportion of Stage I progressing directly to Stage III | 0 | 0.25
Model output: stage distribution
FIGO:
Stage I | 19.1% | 19.6% | 25%
Stage II | 8.2% | 9.3% | 8%
Stage III | 54.2% | 65.2% | 52%
Stage IV | 18.6% | 5.9% | 15%
SEER/WHO:
Local | 19.1% | 19.6% | 25% | 19%
Regional | 8.2% | 9.3% | 8% | 7%
Distant and unstaged | 72.8% | 71.1% | 67% | 75%

Abbreviations: FIGO = International Federation of Gynecology and Obstetrics; SEER = Surveillance, Epidemiology, and End Results; WHO = World Health Organization

With relatively small changes in the probability of presenting with symptoms, a model that allows 25 percent of Stage I tumors to progress directly to Stage III results in stage distributions similar to observed data, and results in similar lifetime risk of ovarian cancer as the Urban model,^243^ In a model with multiple input parameters, a huge number of combinations of parameters can result in similar outputs. Given that estimations of the duration of the different stages of ovarian cancer are based on little empirical data, and that there is no empirical data on the natural history of ovarian cancer, further exploration of the implications for screening, and the evaluation of masses detected through screening, is warranted.

### Summary

The evidence is insufficient to develop a comprehensive model to estimate the relative benefits and risks of different management strategies for evaluating the adnexal mass.

Based on summary estimates of pooled sensitivity and specificity, management strategies that use imaging as the first step for evaluating an adnexal mass detected on examination (as opposed to CA-125) are more efficient, since they exclude false positive results from further examination. Serial testing with imaging followed by CA-125 results in the fewest number of surgeries, but misses more cancers than parallel testing. Parallel testing greatly increases the number of tests required, but results in fewer missed cancers. Additional data are needed to evaluate cost-effectiveness.

Alternative assumptions about the natural history of ovarian cancer can result in modeled outcomes similar to those of published models; the implications of these assumptions should be explored further.