# Methods

This section of the report describes the basic methodology used to develop the evidence report, including topic assessment and refinement, analytic framework, literature search strategies and results, literature screening and grading process and criteria, data abstraction and analysis methods, and quality control procedures.

## Topic Assessment and Refinement

The Centers for Disease Control and Prevention (CDC) and the Agency for Healthcare Research and Quality (AHRQ) originally identified five key questions to be addressed by the report, focused on management of adnexal masses in peri- and postmenopausal women. The Duke research team clarified and refined the overall research objectives and key questions by first consulting with the two study sponsors, AHRQ and CDC, at which time two questions were added, and then by convening a panel of national experts who would serve as advisors to the project. These experts were selected to represent relevant specialties including radiology, obstetrics-gynecology, and gynecologic oncology, as well as national professional societies, including the American College of Obstetricians and Gynecologists (ACOG), the Society of Gynecologic Oncologists (SGO) and the American College of Radiology (ACR). Members of the technical expert panel were:

Susan Ascher, MD; Department of Radiology, Georgetown University Hospital; Washington, DC (ACR)

Michael L. Berman, MD; Division of Gynecologic Oncology, UCI Medical Center; Orange, CA (SGO)

Barry B. Goldberg, MD; Department of Radiology, Thomas Jefferson University Hospital; Philadelphia., PA (ACR)

Edward E. Partridge, MD; Department of Obstetrics and Gynecology, University of Alabama, Birmingham; Birmingham, AL (American Cancer Society)

George F. Sawaya, MD; Department of Obstetrics and Gynecology, University of California, San Francisco; San Francisco, CA

Howard T. Sharp, MD; University of Utah Hospitals and Clinics; Salt Lake City, UT (ACOG)

Stanley Zinberg, MD, MS; ACOG; Washington, DC

As a result of an initial conference call with the technical experts, AHRQ, and CDC, the Duke research team modified the key research questions originally proposed in the Task Order in two fundamental ways: (1) The questions were expanded to include women of all ages, and (2) Question 6 would include laparotomy data, where available. After review of a draft version of the report by the technical experts and additional reviewers, the order of the questions was also changed to allow a more logical flow.

The key questions addressed by this report are:

Question 1: What is the prevalence of various tumor types among women with an adnexal mass, stratified by cancer status (malignant vs. benign), age, menopausal status, and size of tumor?

Question 2: What are the sensitivity, specificity, and reproducibility of the bimanual pelvic examination?

Question 3: Among women with a palpable adnexal mass on exam or a mass identified by ultrasound/imaging, what is the sensitivity/specificity of various evaluation modalities including ultrasound (transvaginal ultrasound, transabdominal ultrasound, color Doppler, two-dimensional [2D] vs. three-dimensional [3D] ultrasound), computer tomography (CT) scan, magnetic resonance imaging (MRI) scan, and cancer antigen 125 (CA-125) levels for diagnosing malignant masses?

Question 4: What is the accuracy of explicit scoring systems which incorporate various combinations of imaging findings, patient risk factors, and/or CA-125 levels for detecting malignancy? Have these scoring systems been applied to a population of women before laparoscopy or laparotomy?

Question 5: Among women with suspected benign masses on initial investigation, what are the sensitivity and specificity of monitoring with periodic CA-125 and/or interval ultrasound examinations for detecting malignant masses? How does the interval of testing/definition of change affect sensitivity and predictive value?

Question 6: Among women with adnexal masses, what are the morbidity and mortality from diagnostic surgery (laparoscopy or laparotomy)? At what point does the risk of surgery outweigh the risk of detecting malignancy?

Question 7: What are the estimated trade-offs resulting from various strategies for evaluation of the adnexal mass?

## Analytic Framework

Based on the original proposal and discussions with CDC, AHRQ, and the technical expert panel, we developed the following analytic framework to structure our review and synthesis (Figure 2).

Figure 2. Analytic framework for evidence report (numbers refer to key questions)

Comments on this analytic framework are as follows:

- Separate consideration of age or menopausal status is important, since several factors that may affect the probability that a given adnexal mass is malignant may vary with age and/or menopausal status: the underlying incidence of various conditions that result in an adnexal mass, the frequency of contact with clinicians, the type and length of followup, and the prevalence of other conditions that may cause symptoms similar to those caused by ovarian malignancy or other symptomatic pelvic pathology. Race/ethnicity may also play a role, both in the relative likelihood of malignancy and the likelihood of other conditions and contact with clinicians.
- A variety of conditions, both benign and malignant, can cause a mass in the adnexa. The underlying prevalence of each type of condition, along with the sensitivity and specificity of the initial diagnostic test, will determine the proportion of patients with a given test result who are truly disease-free, or who truly have disease. The evidence on the prevalence of these conditions is reviewed in Question 1.
- Women can present with an adnexal mass in one of two ways - through presentation with symptoms and subsequent detection of a mass through a physical examination, or through detection of a mass in an asymptomatic woman during physical examination or an imaging study. The ultimate probability of malignancy may vary based on how an adnexal mass is initially detected, since the prevalence of malignancy at this stage will drive the positive and negative predictive values of all subsequent tests. Because many women will initially have their masses detected through a bimanual pelvic examination, we review the evidence on the sensitivity and specificity of this component of the physical examination in Question 2.
- After the initial diagnosis of an adnexal mass, the choice of the next test will provide a revised estimate of the probability of a given disease. Although determining this probability is important in the symptomatic patient so that she may receive appropriate therapy, it is even more important in the asymptomatic patient, who runs the risk of undergoing unnecessary surgery for a benign condition if the test is falsely positive. Question 3 addresses the sensitivity and specificity of tests commonly used as “next step” diagnostic procedures.
- Frequently, a combination of various test results and patient characteristics can provide better discrimination between diseased and non-diseased, or benign and malignant, than any single test parameter. Question 4 addresses the performance of various multivariate scoring systems in discriminating benign from malignant masses.
- Because 100 percent sensitivity is difficult to achieve, some tests will be falsely negative. One strategy to minimize the consequences of a false negative test would be to monitor the patient with a specified test or tests, at a specified frequency, for a specified duration. Question 5 addresses the evidence for the effectiveness of such an approach, and which combination of test, test frequency, and duration of followup offers optimal performance.
- The ultimate diagnosis of ovarian malignancy requires surgical exploration, either through laparoscopy or laparotomy. Although an adverse outcome of surgery is not desirable under any circumstances, patients who undergo surgery because of a symptomatic mass have the possibility of improvement in symptoms, while, for patients who ultimately prove to have an ovarian malignancy, surgical management with adequate staging and reduction in tumor bulk appears to improve outcomes. However, for patients with some asymptomatic benign masses, the benefits of surgery may be less clear while providing substantial risks. Question 6 addresses the risks of diagnostic surgery, both laparoscopy and laparotomy, for women with adnexal masses.
- Finally, estimating the benefits, harms, and costs of various management strategies, including screening, for ovarian cancer is complex. Synthesizing the wide range of data and incorporating uncertainty, as well as missing data, can often be done using simulation models. Question 7 presents an initial attempt at summarizing the likely outcomes of several different diagnostic strategies. Because modeling the natural history of ovarian cancer will ultimately be important for comprehensive analyses of different screening and diagnostic strategies, we also review existing models for the natural history of ovarian cancer with special attention paid to underlying assumptions.

## Literature Search and Review

### Sources

The primary sources of literature were MEDLINE^®^ (1966-September 2004) and the Cochrane Database of Systematic Reviews. Searches of these databases were supplemented by reviews of reference lists contained in all included articles and in relevant review articles and meta-analyses.

### Search Strategies

The basic search strategy used the National Library of Medicine's Medical Subject Headings (MeSH) key word nomenclature developed for MEDLINE^®^ and was adapted for use in the other databases. The searches were limited to the English language. The texts of the three major search strategies are given in Appendix A.^*^ The searches yielded a total of 677 citations, whose records are maintained in a ProCite^20^ database.

* Appendixes cited in this report are provided electronically at http://www.ahrq.gov/downloads/pub/evidence/pdf/adnexal/adnexal.pdf.

### Abstract and Full-text Screening

Paired researchers from the Duke research team independently reviewed a set of abstracts and classified each as “include” or “exclude” according to study-specific criteria, which they developed. An abstract was included if at least one of the paired reviewers recommended that it be included. A total of 445 abstracts were included for the further “full-text review” stage. Interrater reliability for include/exclude decisions was tested by having 10 pairs of readers review 138 abstracts. Agreement was good to excellent (kappa 0.66 to 0.95).

At the full-text review stage, the paired researchers independently reviewed a set of the articles, and indicated a decision to “include” or “exclude” the article for the data abstraction stage. When a pair of reviewers arrived at a different opinion about whether to include an article, they were asked to reconcile the difference. Detailed inclusion and exclusion screening criteria were developed by research question and are listed below.

### Full-text Screening Criteria

Initially, the patient population was limited to peri- and postmenopausal women, and only articles that provided data specifically by age or menopausal status were included. After initial discussion with the expert panel, the search was expanded to include premenopausal women.

Question 1. Background clarifications were as follows:

(1) The search should be limited to (a) screening studies and (b) case series of women with an undiagnosed mass (not just women who went to laparoscopy/path diagnosis).
(2) Pathology list:
  a Benign
    i Uterine leiomyoma
    ii Nonneoplastic cysts, such as:
      1 Follicular (functional) cysts
      2 Corpus luteal (functional) cysts
      3 Theca lutein cysts
      4 Simple cysts
      5 Peritoneal inclusion cysts
      6 Paraovarian cysts
      7 Hemorrhagic cysts
      8 Endometrial cyst
    iii Polycystic ovary disease
    iv Cystic teratoma (dermoid cyst)
    v Hydrosalpinx,
    vi Cystadenoma
    vii Fibroma
  b Malignant ovarian neoplasms
    i Adenocarcinoma
    ii Others
  c Tumors of low malignant potential

Screening criteria for Question 1 were:

(1) undiagnosed mass (regardless of whether symptomatic or asymptomatic; detected by palpation or ultrasound imaging);
(2) exclude if n < 50; if n ≥ 50, write n on decision sheets;
(3) histology diagnosis;
(4) screened women without mass (case series or cohort) or women with adnexal mass (case series).

Question 2. Screening criteria were as follows:

(1) comparison of bimanual pelvic examination to a reference standard;
(2) n ≥ 20;
(3) able to construct 2-by-2 table for test characteristics.

Question 3. Screening criteria were as follows:

(1) undiagnosed mass (regardless of whether symptomatic or asymptomatic; detected by palpation or ultrasound imaging) or screening population;
(2) disease status distinguishes malignant from non-malignant;
(3) must have 20 or more subjects;
(4) disease status must be verified by histology or negative surgery (laparoscopy/laparotomy);
(5) test is ultrasound, CT, MRI, PET, serum CA-125, or bimanual pelvic exam;
(6) able to construct 2-by-2 table for test characteristics.

Question 4. Screening criteria were as follows:

(1) patients with cancer;
(2) studies with scoring, risk score, combined modality approach;
(3) assesses predictive value of two or more variables (radiographic, patient characteristics or CA-125) using multivariable model;
(4) screening studies;
(5) n ≥ 50.

Question 5. Screening criteria were as follows:

(1) n ≥ 50;
(2) histology or followup interval = at least 9 months;
(3) outcome = continued negative test with no clinical evidence of developing ovarian cancer.

Question 6. Screening criteria were as follows:

(1) procedure = operative laparoscopy for adnexal mass, with or without biopsy;
(2) addresses complications of procedure (morbidity or mortality);
(3) n ≥ 100 for morbidity.

Question 7. Screening criterion was as follows: article described mathematical or computer model of natural history of ovarian cancer.

Summaries of the results of the abstract screening and full-text review are provided in Tables 2 and 3. A list of excluded articles by reason for exclusion is found in Appendix B.^*^

Table 2 Results of abstract screening and full-text review

Articles identified | 1,023
Abstracts reviewed | 1,023
Included | 445
Excluded | 578
Full-text articles reviewed | 445^†^
Included | 204
Excluded | 269

† The combined number of included (204) and excluded (269) articles exceeds the total 445 reviewed at the full-text level because 28 articles were considered excluded for one question, but included for another question.

Table 3 Included full-text articles by research question

Question | Number of articles
Question 1: Prevalence of tumor types | 20
Question 2: Bimanual pelvic examination | 14
Question 3: Single modality tests | 153
Question 4: Explicit scoring systems | 36
Question 5: Monitoring women with suspected benign masses | 9
Question 6: Surgical morbidity and mortality | 24
Question 7: Modeling diagnostic strategies | 4
Total number of included articles | 204^†^

† Some articles were included for more than one question.

## Data Abstraction and Development f Evidence Tables

The Duke research team developed and piloted evidence table formats for abstracting data to answer each of the seven research questions (see Appendix C *). Based on clinical expertise, a pair of researchers was assigned to one of the seven research questions to abstract the data from the eligible articles. One of the paired researchers abstracted the data into the evidence tables, and the second researcher over-read the article and accompanying evidence table to check for accuracy and completeness. The completed evidence tables are provided in Appendix D.^*^

## Quality Assessment Criteria

At the data abstraction stage, the researcher was asked to evaluate each included article for factors affecting internal and external validity. The quality assessment criteria varied by question and are listed below. Researchers were instructed to assign a + or - to each item, and provide a brief rationale for each decision.

Quality criteria were as follows:

Question 1: What is the prevalence of various tumor types among women with an adnexal mass, stratified by cancer status (malignant vs. benign), age, menopausal status, and size of tumor?

- Size of population from which sample drawn. Rationale: Ideally, data on prevalence would come from population-based studies; alternatively, a precise description of the population served by a given center (for case series) allows comparison to other studies. Credit given for description.
- Number of cases. Rationale: Small numbers, especially in the denominator, decrease the precision of the estimate of proportion/prevalence.
- Patient selection. Rationale: The process by which patients come to undergo surgery may affect the prevalence of underlying disease, or the proportion of different types. For example, if one group of patients was more likely to undergo medical treatment for certain types of adnexal findings (such as oral contraceptives for possible functional cysts), the distribution of types of masses would be different than in a group less likely to undergo medical therapy prior to surgery. Studies were given credit if this process were described.
- Application of reference standard. Rationale: If either all or a random sample of test negative subjects do not undergo the reference standard test, significant overestimation of test sensitivity can occur. Studies given credit if all patients underwent reference standard; alternative standards (such as pre-defined followup) were allowed for screening studies.^15,^ ^21^

Question 2: What are the sensitivity, specificity, and reliability of the bimanual pelvic examination?

- Reference standard. Rationale: Histology or, at the least, intraoperative visualization, is the recognized reference standard for ovarian or other adnexal pathology. Studies given credit if all subjects underwent this reference standard (documented followup acceptable in screening studies).
- Verification bias. Rationale: If either all or a random sample of test negative subjects do not undergo the reference standard test, significant overestimation of test sensitivity can occur. Studies given credit if all patients underwent reference standard; alternative standards (such as predefined followup) were allowed for screening studies.
- Test reliability/variability. Rationale: Inter- and intraobserver variability can, at least, affect the precision of estimates of test characteristics (if random), or can bias results in one direction or the other (if systematic). Studies given credit if test reliability/variability were measured, other studies measuring it were referenced, or if it was discussed as an issue.
- Sample size. Rationale: Small sample sizes limit the precision of estimates, particularly for test characteristics, which are proportions. Studies given credit if sample size discussed, or if study over 100 subjects.
- Statistical tests. Rationale: Inappropriate use of statistical tests (e.g., use of parametric tests for nonparametric data) or inappropriate interpretation of results (concluding no difference for underpowered studies) can lead to invalid conclusions about a study. Studies given credit if no examples of inappropriate use identified.
- Blinding. Rationale: Awareness of other relevant information (such as clinical history or, in the case of retrospective studies where images are reviewed outside of the clinical setting, the ultimate diagnosis) can lead to biased interpretation of results. Studies given credit if blinding explicitly described.
- Definition of +/- on screening test. Rationale: The ability to replicate a study, or to compare results between studies, depends on a description of the criteria for defining a positive test. Studies given credit if definition provided, or reference for definition provided.

Question 3: Among women with a palpable adnexal mass on exam or a mass identified by ultrasound/imaging, what is the sensitivity/specificity of various evaluation modalities including ultrasound (transvaginal ultrasound, transabdominal ultrasound, color Doppler, 2D vs. 3D ultrasound), CT scan, MRI scan, and CA-125 levels for diagnosing malignant masses?

- Reference standard
- Verification bias
- Test reliability/variability
- Sample size
- Statistical tests
- Blinding
- Definition of +/- on screening test

Rationale for these criteria is the same as for Question 2.

Question 4: What is the accuracy of explicit scoring systems which incorporate various combinations of imaging findings, patient risk factors, and/or CA-125 levels for detecting malignancy? Have these scoring systems been applied to a population of women before laparoscopy or laparotomy?

- Reference standard. Rationale: Histology or, at the least, intraoperative visualization, is the recognized reference standard for ovarian or other adnexal pathology. Studies given credit if all subjects underwent this reference standard (documented followup acceptable in screening studies).
- Verification bias. Rationale: If either all or a random sample of test negative subjects do not undergo the reference standard test, significant overestimation of test sensitivity can occur. Studies given credit if all patients underwent reference standard; alternative standards (such as pre-defined followup) were allowed for screening studies.
- Test reliability/variability. Rationale: Inter- and intra-observer variability can, at least, affect the precision of estimates of test characteristics (if random), or can bias results in one direction or the other (if systematic). Studies given credit if test reliability/variability were measured, other studies measuring it were referenced, or if it was discussed as an issue.
- Sample size. Rationale: Small sample sizes limit the precision of estimates, particularly for test characteristics, which are proportions. In the setting of multivariate models, study power is limited by the number of cases in the data set. Studies given credit if sample size discussed.
- Statistical tests. Rationale: Inappropriate use of statistical tests (e.g., use of parametric tests for nonparametric data) or inappropriate interpretation of results (concluding no difference for underpowered studies) can lead to invalid conclusions about a study. Studies given credit if no examples of inappropriate use identified.
- Blinding. Rationale: Awareness of other relevant information (such as clinical history or, in the case of retrospective studies where images are reviewed outside of the clinical setting, the ultimate diagnosis) can lead to biased interpretation of results. Studies given credit if blinding explicitly described.
- Definition of +/- on screening test. Rationale: The ability to replicate a study, or to compare results between studies, depends on a description of the criteria for defining a positive test. Studies given credit if definition provided, or reference for definition provided.
- Explicit validation method. Rationale: A scoring system will often perform differently when tested in a data set other than the one in which it was developed. Studies given credit if the method for validating the system was explicitly described or referenced.

Question 5: Among women with suspected benign masses on initial investigation, what are the sensitivity and specificity of monitoring with periodic CA-125 and/or interval ultrasound examinations for detecting malignant masses? How does the interval of testing/definition of change affect sensitivity and predictive value?

- Reference standard
- Verification bias
- Test reliability/variability
- Sample size
- Statistical tests
- Blinding
- Definition of +/- on screening test

Rationale for these criteria is the same as for Question 2.

Question 6: Among women with adnexal masses, what are the morbidity and mortality from diagnostic surgery (laparoscopy or laparotomy)? At what point does the risk of surgery outweigh the risk of detecting malignancy?

- Size of population from which sample drawn
- Number of cases
- Patient selection
- Application of reference standard

Rationale for these criteria is the same as for Question 1.

Question 7: What are the estimated trade-offs resulting from various strategies for evaluation of the adnexal mass?

For this question, we examined published models of ovarian cancer and qualitatively assessed the underlying assumptions and evidence for them.

## Additional Analyses

### Test Characteristics and Confidence Intervals

For test characteristics, a Microsoft Excel® spreadsheet was developed which calculated appropriate test characteristics (sensitivity, specificity, negative predictive value, positive predictive value) for individual studies if studies provided enough data to input (a) values for individual cells of a 2-by-2 table, (b) the prevalence of disease and values for sensitivity and specificity, or (c) sufficient data to solve for two equations involving sensitivity, specificity, or predictive values. Ninety-five percent confidence intervals were automatically estimated using the approximate formula for proportions:

, where p = point estimate of proportion, N = total sample size.

### Prevalence and Event Rates and Confidence Intervals

For Questions 3 and 6, prevalence of different mass types, and morbidity and mortality rates, were also calculated using the above formula. For studies where the numerator of a particular proportion was 0, the upper bound was estimated using the formula:

, where p = 2/(N + 2).

### Estimation of Pooled Sensitivity and Specificity

For Questions 2, 3, and 4, we used two complementary methods for assessing diagnostic test performance: (1) summary receiver operating characteristic (ROC) analysis; and (2) independently combined sensitivity and specificity values. We calculated pooled sensitivity and specificity estimates, along with 95 percent confidence intervals and summary ROC curves, using Meta-Stat 0.6, a shareware program for performing meta-analyses of diagnostic tests.^22^ In this software, logits of sensitivity and specificity values are pooled, using a random-effects model weighted by the inverse of the variance.^23^

We combined the sensitivity and specificity values of the tests across studies using a random-effects model to estimate the average values. A random-effects model incorporates both the within-study variation (sampling error) and between-study variation (true treatment-effect differences) into the overall treatment estimate. It gives a wider confidence interval than the fixed-effect model (which considers only within-study variability) when estimates are based on heterogeneous results.

When each is combined separately, sensitivity and specificity tend to underestimate the true test sensitivity and specificity; however, they can provide an indication of the approximate test operating point for most of the studies.

Summary ROC curves are a potentially useful graphical summary of the diagnostic test performance data. In brief, each study provides a pair of sensitivity and specificity values to the analysis. After logistic transformation of data, a linear model is fitted to the observed studies using regression analysis. This best-fit model can then be transformed back to ROC space and plotted as curve. A summary ROC curve can be thought of as an ROC curve that describes joint changes in sensitivity and specificity with changes in cutoff values. The ideal position of an ROC curve is near the upper left corner. The area under the curve (AUC) is another summary measure of the degree of discrimination of a test.

The summary ROC method assumes that the variability in the reported sensitivity and specificity values from different studies is due to different cutoff values (explicit or implicit) being applied.^24^ However, the summary ROC curve can summarize studies whose variability may be due to other sources of variation, since the summary ROC curve no longer ties specific cutoff values to specific intervals of the curve. One can think of a summary ROC curve as an overall estimate of the discrimination ability of a test.

When there is little variability in the test results - i.e., when studies appear to be operating at similar thresholds and report similar results - summary ROC analysis provides little additional information. In this case, separately averaged sensitivity and specificity values across studies will give similarly useful summary information. However, where there is substantial variability in test results, the separately averaged sensitivity and specificity values tend to have wide confidence intervals and have means that do not characterize any of the studies. In this case, SROC curves provide a more suitable analysis framework.

### Estimates of National Rates of Surgery for Adnexal Mass

The Nationwide Inpatient Sample (NIS) is a public access database maintained by AHRQ. The NIS represents a stratified sample of approximately 20 percent of all discharges from U.S. hospitals; data for the year 2000 contain administrative discharge data from hospitals in 28 states, while 2001 contains data from 33 states.^25^ Weights are provided in order to allow estimation of national data based on this sample. We used data from 2000 and 2001 to provide supplemental data on the frequency of diagnostic laparoscopy and exploratory laparotomy for Question 6. Because previous work has shown that administrative data may lack sufficient clinical detail to compare outcomes,^26^ we did not attempt to directly compare complication rates between these procedures, or between diagnoses.

The search was limited to women 15 years and older, who had one of the following International Classification of Diseases, Ninth Revision (ICD-9) diagnostic codes: 183.x (malignant neoplasm of the ovary and other uterine adnexa), 220.x (benign neoplasms of the ovary); 620.x (ovarian cysts); 752.11 (para-ovarian cysts); 614.0, 614.1, 614.2, 614.6 (adnexal masses secondary to pelvic inflammatory disease); 789.33, 789.34, 789.39 (abdominal masses arising in the left or right lower quadrant, or other nonspecified site); and V655 (normal findings after diagnostic evaluation).

In order to avoid overestimation of complication rates due to other procedures, we then excluded patients who had an ICD-9 diagnosis code for hysterectomy (68.x). Procedures were then classified as laparoscopy only (54.21), laparoscopy with conservative ovarian surgery (65.3x, 65.4x, 65.5x, 65.6x), laparoscopy with oophorectomy (65.0×, 65.2x), or laparotomy (54.11) alone, with conservative ovarian surgery (same codes), or with oophorectomy (same codes).

A discharge status of “Dead” indicated in-hospital mortality. Complications of surgery or hospitalization were indicated by diagnosis codes of E870 through E876.

### Model of Natural History of Ovarian Cancer

We used a Markov state-transition model to explore the impact of alternate assumptions about the natural history of ovarian cancer. The original model was developed as a graduate school project by Karen Hoffman, MD, and further refined in collaboration with two of the authors of this report (Drs. Kulasingam and Myers).

The model simulates a cohort beginning at age 40 distributed across cancer stages. Subjects progress from no cancer through the stages of ovarian cancer to death. Each cycle is 12 months long. The original model design is illustrated in Figure 3; subsequent modifications include removal from the at-risk population by undergoing oophorectomy for another cause, and allowing some Stage I cancers the possibility of progressing directly to Stage III. Model variables and the ranges over which they were varied are outlined in Table 4. Probability of progressing from no cancer to Stage I cancer varies by age and is based on age-adjusted ovarian cancer incidence rates. Because the probability of progression (or duration of time within a stage) is unknown, probability of progression from Stage I to II, from Stage II to III, and from Stage III to Stage IV was adjusted to reflect incidence distribution across stages. Within the model, subjects may die from causes other than ovarian cancer. The probability of dying from a cause other than ovarian cancer varies by age and was constructed from CDC National Vital Statistics reports and Surveillance, Epidemiology, and End Results (SEER) data.^27,^ ^28^ Probability of clinical diagnosis is based on the annual report of the International Federation of Gynecology and Obstetrics (FIGO).^29^ Five-year survival rates gathered by SEER 1992-98 were used to predict probability of dying from ovarian cancer.^27^ SEER localized disease corresponds to Stage I cancer, regional disease corresponds to Stage II cancer, and distant disease corresponds to Stage III/IV ovarian cancer. The model was constructed in DATA 4.0.^30^

Table 4 Model variables

Variable description | Model abbreviation of variable | Value | Range varied
Probability of clinical diagnosis for each stage (I, II, III, or IV) if no screening test or if screening produces a false negative | pClinDxStageI | 0.261 | Calibrated
| pClinDxStageII | 0.446
| pClinDxStageIII | 0.837
| pClinDxStageIV | 0.950
Probability of dying from diagnostic exploratory laporotomy | pLapDeath | 0.00023 | 0.00 to 0.0010
Probability of dying from each stage of cancer, based on 5-year survival rates | pDieStageI | 0.051 | Not varied
| pDieStageII | 0.187 | Not varied
| pDieStageIII | 0.691 | Not varied
| pDieStageIV | 0.691 | Not varied
Probability of developing Stage I cancer, based on ovarian cancer incidence rates | tCompInc | | Varies with age
Probability of dying from a cause other than ovarian cancer | tMortCaAdj | | Varies with age

Figure 3. Schematic of natural history model

Abbreviations for probabilities are described in Table 4, below.

## Peer Review Process

We employed internal and external quality-monitoring checks through every phase of the study to reduce bias, enhance consistency, and verify accuracy. Examples of internal monitoring procedures include: three progressively stricter screening opportunities for each article (abstract screening, full-text article review, data abstraction review); involvement of three individuals (two clinicians and copy editor) in each data abstraction; agreement of at least two clinicians on all included studies.

Our principle external quality-monitoring device was the peer-review process. Nominations for peer reviewers were solicited from several sources, including a technical expert panel and interested federal agencies. The list of nominees was forwarded to the Agency for Healthcare Research and Quality (AHRQ) for vetting and approval. A final list of peer reviewers is provided in Appendix E.^*^