# Introduction

## Ovarian Tumors

Cancer of the ovaries is the leading cause of cancer death from gynecologic malignancies in the United States, with an annual incidence of over 25,000 and an annual mortality of approximately 14,000.^1^ Cancer incidence increases dramatically with age, being relatively rare prior to age 50 (Figure 1).

Figure 1. U.S. ovarian cancer incidence by age and race, 1992-2002

Source: Surveillance, Epidemiology, and End Results (SEER) Program ( www.seer.cancer.gov).^2^

Ovarian cancer incidence varies by race and ethnicity. Both incidence and mortality are highest for white women (Table 1).

Table 1 Age-adjusted annual U.S. incidence and mortality per 100,000 women by race and ethnicity, 1992-2002^†^

| White | African-American | Asian/Pacific Islander | Native American | Hispanic
Incidence | 15.1 | 10.3 | 10.4 | 8.9 | 11.9
Mortality | 9.3 | 7.6 | 4.8 | 5.1 | 6.2

† Source: Surveillance, Epidemiology, and End Results (SEER) Program (www.seer.cancer.gov).^2^

Malignant tumors of the ovary can either arise in the ovary (primary ovarian cancer) or be the result of metastasis from another site, such as the breast or colon. Primary ovarian tumors, whether benign or malignant, can arise from three broad types of cells: the cells on the surface (epithelial cells); the cells that form eggs (germ cells); and the cells surrounding the eggs, including the cells that produce ovarian hormones (sex cord-stromal cells). Epithelial tumors are the most common type, accounting for 60 percent of all ovarian tumors and up to 90 percent of primary cancers. Sex-cord-stromal tumors account for 10 to 15 percent of all tumors, while germ cell tumors account for 25 percent of tumors. In general, sex cord-stromal tumors and germ cell tumors are relatively more common in younger premenopausal women. Thus, although ovarian cancer is relatively rare in younger women, when it does occur it is more likely to be a non-epithelial cancer than cancers in postmenopausal women.^3^

Within the broad classification of epithelial, sex cord-stromal, and germ cell tumors, tumors are further classified by the individual cell types from which they are derived. For example, the most common epithelial tumors are serous and mucinous tumors, the most common sex-cord stromal tumors are fibromas (arising from the connective tissue surrounding eggs), and the most common germ cell tumors are teratomas. Within each histological class, tumors can be benign or malignant, based on their ability to metastasize.^3^

Some epithelial tumors are classified as “borderline” or “low malignant potential” (LMP) tumors. These are tumors in which there is no invasion into the ovarian stroma, but for which histologic evidence of proliferation exists (increased cell division, changes in the appearance of the cell nucleus). There is controversy over whether these tumors represent pre-invasive cancer, and, if untreated, would go on to become a cancer, or whether they represent a subtype of tumor that has a relatively small chance of becoming a cancer.^3^ In estimating the diagnostic accuracy of tests for determining whether a mass is benign or malignant, whether LMP tumors are classified as benign or malignant can have an effect on the estimates of test performance, as we will discuss later in the report.

Ovarian cancer spreads primarily by dissemination throughout the peritoneal cavity; common sites of metastasis are the small and large bowel, the omentum, the liver, and the diaphragm. Spread to retroperitoneal lymph nodes is also common.

Treatment for ovarian cancer consists of surgical removal of the ovaries, fallopian tubes, and uterus (if present), along with as much metastatic disease as possible; if there is no obvious spread beyond the ovaries, the lymph nodes are sampled to determine if there has been lymphatic metastasis. Surgery is followed by chemotherapy, with responsiveness to chemotherapy depending on the amount of tumor left after surgical removal and the cell type of tumor, among other factors.^3^

The high case-fatality rate observed in ovarian cancer has largely been attributed to the fact that most ovarian cancers are diagnosed in advanced stages (Stage III, where the cancer has spread beyond the pelvis to organs of the upper abdominal cavity, and Stage IV, where the cancer has spread outside of the peritoneal cavity), when survival is poor. Stage I cancer (limited to the ovaries) has a survival rate of over 90 percent. Thus, there has long been an emphasis on early detection of ovarian cancer, in the belief that detection in early stages will lead to decreases in morbidity and mortality, just as cervical cancer screening has resulted in substantial reductions in morbidity and mortality from cervical cancer. The detection of a mass in the area of the ovaries and fallopian tubes (the uterine adnexae) raises the possibility of ovarian cancer, which necessitates further study to rule out malignancy.

This evidence report was prepared by the Duke Evidence-based Practice Center, in partnership with the Centers for Disease Control and Prevention (CDC) and the Agency for Healthcare Research and Quality (AHRQ). The purpose of the report is to provide followup data regarding key issues identified at two conferences sponsored by CDC, one in November 2000 on broad issues in preventing morbidity and mortality from ovarian cancer,^4^ and one in May 2002 on the use of ultrasound in the diagnosis of ovarian cancer.^5^

## Definition of an Adnexal Mass

For the purposes of this report, we define an adnexal mass as an enlarged structure in the uterine adnexa which can either be palpated on a bimanual pelvic examination or visualized using radiographic imaging. The normal ovary is approximately 3 cm in length, decreasing in size after menopause.^6^ In terms of physical examination, the precise size definition used in the literature is quite variable and, in practice, may also vary depending on the ease with which the examination is performed, the patient's body habitus, the examiner's experience, the time taken during the exam, and the presence of other abnormalities such as uterine fibroids. Historically, because of the decrease in size after menopause, any palpable mass in a postmenopausal woman has been considered abnormal (the “palpable postmenopausal ovary syndrome”).^7^ As discussed below, some masses may ultimately prove to not be ovarian in origin.

The definition of an abnormal structure on radiologic imaging is also quite variable. Small fluid-filled cysts are quite common in both pre- and postmenopausal women. For the purposes of this report, we consider any structure observed during radiologic imaging that prompts additional evaluation (such as measurement of serologic markers or further imaging) as a mass.

## Detection of an Adnexal Mass

There are three main clinical routes by which an adnexal mass may be detected. First, women with symptoms may have an adnexal mass detected as part of their evaluation for those symptoms, either by physical exam or radiographic imaging. Because ovarian cancer often presents with vague abdominal symptoms, we would consider any evaluation for symptoms to be in symptomatic women. Second, the mass may be detected as part of a routine health maintenance examination. Finally, it is possible that an asymptomatic mass could be detected during imaging done for another indication. In premenopausal women, the most likely scenario where this would occur would be during ultrasound evaluation during pregnancy. Another common scenario in perior postmenopausal women would be evaluation for uterine bleeding; because uterine bleeding is not a common symptom of ovarian cancer, a finding of an adnexal mass during evaluation for bleeding could be considered as an incidental finding. Because malignancy is rare during pregnancy, and because the technical considerations for both diagnosis and management are different, the most appropriate management of masses detected during pregnancy, especially if detected serendipitously by ultrasound, is outside of the scope of this report.

We did not identify any literature that would allow an estimate of the proportions of women with adnexal masses presenting by each route; as we will discuss, this is a major deficiency of the literature. The proportions are likely to vary by setting, referral patterns, patient thresholds for seeking care, physician thresholds for diagnostic tests, and other factors. For example, one gynecologic oncologist estimated that well over half of the referrals for evaluation in a large health maintenance organization were for incidentally detected masses (W. Kinney, personal communication).

## Types of Adnexal Mass

Conditions that can present as an adnexal mass include:

- Benign primary ovarian tumors - epithelial, sex cord-stromal, and germ cell;
- Borderline and malignant ovarian tumors - epithelial, sex cord-stromal, and germ cell;
- Metastatic malignant tumors - most commonly breast and gastrointestinal tract;
- Masses arising from the fallopian tube - most commonly benign, including hydrosalpinx (a large, fluid-filled fallopian tube) and pyosalpinx (an infected, pus-filled fallopian tube); primary fallopian tube malignancies can occur, but are relatively rare.
- Masses arising from the uterus - most commonly benign leiomyomas (fibroids);
- Masses arising from the gastrointestinal tract - diverticula of the colon, large colonic tumors, tumors of the appendix;
- Masses arising from the urinary tract - pelvic kidneys, diverticula of the ureter;
- Masses arising from remnants of embryological development;
- Endometriosis;
- Pelvic inflammatory disease;
- Cysts arising from normal ovarian functions, such as development of eggs (follicular cysts) and ovulation (corpus luteum cysts).

## Management of the Adnexal Mass

With such a wide range of potential causes, and with a wide range of appropriate therapeutic options, precise diagnosis of a mass, especially in symptomatic women, is important. Once diagnosed, a mass may be managed in a variety of ways, ranging from observation to surgical removal and chemotherapy. However, a review of the test characteristics of various methods for obtaining precise diagnoses of specific conditions, and of the range of medical and surgical treatment options for each condition, is beyond the scope of this report. For our purposes, “management” of the adnexal mass refers to the process by which a mass is ultimately classified as benign or malignant.

## Importance of Discriminating Benign from Malignant Masses

The clinical significance of discriminating benign from malignant masses differs depending on the clinical setting in which the mass is initially detected.

In women who initially present with symptoms, diagnosis of the underlying cause of the mass is important since it may help define available treatment options. Although medical therapy may relieve symptoms in some cases, surgical management is the treatment of choice for many conditions. Because surgery may ultimately be the most appropriate management for symptomatic adnexal masses, the main reason to discriminate between benign and malignant lesions is to facilitate referral and management by clinicians with specialized training and experience in managing ovarian malignancy, with improved outcomes.^8^–^10^

The other main group of women with adnexal masses consists of those without symptoms who have a mass detected through either physical examination or imaging. No organization currently recommends routine screening with serum markers or imaging for ovarian cancer.^11,^ ^12^ The U.S. Preventive Services Task Force gives screening (including serum markers, imaging, or pelvic examination) a “D” recommendation (fair evidence against screening).^13^ However, because an annual pelvic examination continues to be recommended by professional organizations such as the American College of Obstetricians and Gynecologists (ACOG),^11,^ ^14^ many asymptomatic women may have an adnexal mass detected during a periodic health maintenance examination. In this setting, discriminating benign from malignant disease is important not only to ensure appropriate management in the setting of malignancy, but also to avoid unnecessary diagnostic procedures, including surgery, and anxiety in women with asymptomatic, nonmalignant conditions. In some cases, there may be a rationale for removing certain asymptomatic benign lesions, including prevention of malignant transformation; prevention of ovarian torsion (a condition where the ovary twists and occludes its blood supply, causing abdominal pain and possibly resulting in loss of ovarian function); prevention of rupture, which might lead to acute symptoms or a worse prognosis (for example, in the case of endometriosis); prevention of more advanced or complicated surgery for a larger mass or more extensive pathologic process after the development of symptoms; and, for premenopausal women, possible enhancement of fertility. A review of the evidence (or lack of evidence) supporting these rationales is beyond the scope of this report.

## Significance of Clinical Presentation in Evaluation of Management Strategies

As discussed above, the results of tests used to distinguish benign from malignant disease have different implications depending on whether the patient is symptomatic or asymptomatic. However, clinical presentation also has implications for interpretation of test results.

Diagnostic or screening tests are most commonly characterized by their sensitivity and specificity. The sensitivity of a test is the probability that, given the underlying presence of the disease, the test result will be positive; 100 percent minus the sensitivity is commonly called the false negative rate. The specificity of the test is the probability that, given the underlying absence of disease, the test result will be negative; 100 percent minus the specificity is commonly called the false positive rate. In an ideal evaluation, the sensitivity and specificity of the test are independent of the underlying probability, or prevalence, of disease.

Clinically, the more common scenario is that the clinician is aware of the test result and needs to know the probability of the presence or absence of disease. In this setting, the positive and negative predictive values of the test are more important.

The negative predictive value of a test is the probability that, given a negative test result, the patient truly does not have disease. It is a function of three parameters: the pretest probability of the disease, the sensitivity of the test, and the specificity of test:

(1 - Prevalence) * Specificity/[(1 - Prevalence) * Specificity] + [Prevalence * (1 - Sensitivity)]

As can be seen in the equation, the negative predictive value is much more dependent on test sensitivity than test specificity. Negative predictive value will be high when test sensitivity is high, and when prevalence is low (i.e., disease is rare).

Similarly, the positive predictive value is the probability that, given a positive test result, the patient actually has the disease. It is also a function of prevalence, sensitivity, and specificity:

Prevalence * Sensitivity/(Prevalence * Sensitivity) + [(1 - Prevalence) * (1 - Specificity)]

Positive predictive value is high when a test has high specificity, or when prevalence is high (disease is common).

For any given test, the positive predictive value will be higher and the negative predictive value lower when used in populations where the disease is common compared to populations where the disease is rare, while the positive predictive value will decrease and the negative predictive value increase as the disease becomes less common. This effect of prevalence on predictive values is independent of test sensitivity and specificity. The significance of the prevalence of disease in the population in which test characteristics are being evaluated is even more critical because, under some types of study design, disease prevalence can also affect estimates of sensitivity and specificity.^15^

Therefore, variations in the prevalence of malignancy among women with different clinical presentations will affect at least predictive values, and possibly sensitivity and specificity estimates. The prevalence of ovarian cancer clearly rises with age, so age and/or menopausal status are important considerations in evaluating management strategies in both the symptomatic and asymptomatic patient with an adnexal mass.

The prevalence of malignancy among asymptomatic women with an adnexal mass will be a function of the underlying prevalence or incidence of malignancy and the test characteristics of the initial test used to detect the mass. Evaluation of the different screening tests and strategies for early detection of ovarian cancer is beyond the scope of this report, especially since there are at least three large trials still ongoing.^16^–^18^ However, in order to properly interpret the results of tests performed in asymptomatic women with pelvic masses, some estimate of the underlying probability of malignancy among these women is needed. Since many of these women are likely identified through a bimanual pelvic examination, deriving this estimate requires an assessment of the sensitivity and specificity of the pelvic examination. Symptomatic patients may be more likely to have an underlying adnexal malignancy, especially among postmenopausal women.^19^ In any series of women with adnexal masses, the proportion of women who are symptomatic and asymptomatic will likely determine the prevalence, and thus the predictive values of the diagnostic tests used to evaluate the mass.

## Summary

In summary, this report focuses on the evidence relevant to establishing the most appropriate way to distinguish benign from malignant adnexal masses in both symptomatic and asymptomatic women. A key consideration throughout the report will be the underlying likelihood of malignancy in the populations studied, and the impact of this prevalence on the interpretation of the results of the reviewed studies. The results of this report are intended primarily to (a) provide a resource for clinicians and policymakers developing guidelines on management of adnexal masses, and (b) provide a resource for researchers and funding agencies in identifying gaps in our knowledge and research priorities.