# Appendix E: Peer Reviewers

The Duke Evidence-based Practice Center is grateful to the following peer reviewers who read and commented on a draft version of this report:

Susan M. Ascher, MD; Department of Radiology, Georgetown University Hospital; Washington, DC

Andrew Berchuck, MD; Division of Gynecologic Oncology, Duke University Medical Center; Durham, NC

Michael L. Berman; Division of Gynecologic Oncology, UCI Medical Center; Orange, CA

Christie R. Eheman, MD; Centers for Disease Control and Prevention; Atlanta, GA

Barbara Goff, MD; University of Washington School of Medicine; Seattle, WA

Walter Kinney, MD; Department of Obstetrics and Gynecology, The Permanente Medical Group; Sacramento, CA

Ann Kolker; Ovarian Cancer National Alliance; Washington, DC

Herschel Lawson, MD; Center for Disease Control and Prevention; Atlanta, GA

Saralyn Mark, MD; Department of Health and Human Services; Washington, DC

Susan Meikle, MD, MSPH; Agency for Healthcare Research and Quality; Rockville, MD

Valerie McGuire, PhD; Department of Health Research and Policy, Stanford University; Stanford, CA

Edward E. Partridge, MD; Department of Obstetrics and Gynecology, University of Alabama; Birmingham, AL

Mona Saraiya, MD, MPH; Centers for Disease Control and Prevention; Atlanta, GA

George F. Sawaya, MD; Department of Obstetrics and Gynecology, UCSF; San Francisco, CA

Howard T. Sharp, MD; University of Utah Hospitals and Clinics; Salt Lake City, UT

Edward L. Trimble, MD, MPH; National Cancer Institute; Rockville, MD

John R. van Nagell Jr., MD; Department of Obstetrics and Gynecology, University of Kentucky Medical Center; Lexington, Kentucky

Nominations for peer reviewers were solicited from several sources, including the project's technical expert panel and interested federal agencies. The list of nominees was vetted and approved by the Agency for Healthcare Research and Quality (AHRQ).