# Appendix D: Evidence Tables

Evidence Table 1. Question 1: What is the prevalence of various tumor types among women with an adnexal mass, stratified by cancer status (malignant vs. benign), age, menopausal status, and size of tumor?

Study | Study Design | Patients | Clinical Presentation | Results | Comments/Quality Scoring
Chalas, Welshinger, Engellener, et al., 1992 | Geographical location: | Age: | Symptomatic (n [%]): | Of the 241: | Comments:
#5100 | Stony Brook, NY | NR | NR | 121/241 were malignant = 50.2%; 95% CI, 44.4 to 56.9 | —Clinical presentation not described
| Dates: | Menopausal status (n [%]): | Detected by exam (n [%]): | 18/241 borderline = 7.5%; 4.8 to 11.7 | —Patients scheduled for surgery; malignancy likely overrepresented
| May 1980-Apr 1990 | NR; authors present some findings by age > 50, but do not report the numbers of women | NR | 102/241 benign = 42.3%; 36.6 to 49 | Quality assessment:
| Size of population: | Race/ethnicity (n [%]): | Detected by imaging (n [%]): | Malignant: | Size of population from which sample drawn: - (unclear)
| 241 | NR | NR | Serous epithelial 66 = 27.4%; 95% CI, 22.4 to 33.6 | Number of cases: - (241)
| Other: | Risk factors (n [%]): | Combination (n [%]): | Mucinous epithelial 12 = 5.0%; 2.8 to 8.7 | Patient selection: - (retrospective chart review)
| Retrospective chart review of patients with pelvic mass who underwent laparotomy to look at thrombocytosis as a predictor of cancer | NR | NR | Clear cell epithelial 13 = 5.4%; 3.2 to 9.2 | Application of reference standard: + (all had biopsy)
| | | Additional data used for diagnosis: | Endometrioid epithelial 11 = 4.6%; 2.5 to 8.2
| | | CA-125 and thrombocytosis | Papillary mixed epithelial 5 = 2.1%; 0.8 to 5.0
| | | | Dysgerminoma 2 = 0.8%; 0.05 to 3.2
| | | | Immature teratoma 1 = 0.4%; 0 to 2.6
| | | | Endodermal tumor 1 = 0.4%; 0 to 2.6
| | | | Granulose cell tumor 1 = 0.4%; 0 to 2.6
| | | | Sertoli-Leydig cell tumor 2 = 0.8%; 0.05 to 3.2
| | | | Peritoneal primary 1 = 0.4%; 0 to 2.6
| | | | Malignant mesothelioma 1 = 0.4%; 0 to 2.6
| | | | Other cancer 5 = 2.1%; 0.8 to 5.0
| | | | Borderline tumors (LMP):
| | | | Serous epithelial 9 = 3.7%; 95% CI, 1.9 to 7.1
| | | | Mucinous epithelial 7 = 2.9%; 1.3 to 6.1
| | | | Endometrioid epithelial 1 = 0.4%; 0 to 2.6
| | | | Papillary mixed epithelial 1 = 0.4%; 0 to 2.6
| | | | Benign:
| | | | Functional ovarian cyst 22 = 9.1%; 95% CI, 6.1 to 13.6
| | | | Serous cystadenoma 14 = 5.8%; 3.5 to 9.7
| | | | Mucinous cystadenoma 9 = 3.7%; 1.9 to 7.1
| | | | Brenner tumor 1 = 0.4%; 0 to 2.6
| | | | Endometrioma 10 = 4.1%; 2.2 to 7.6
| | | | Mature teratoma 6 = 2.5%; 1.1 to 5.5
| | | | Thecoma of fibroma 4 = 1.7%; 0.5 to 4.4
| | | | Tuboovarian abscess 4 = 1.7%; 0.5 to 4.4
| | | | Hydrosalpinx 4 = 1.7%; 0.5 to 4.4
| | | | Paratubal cyst 1 = 0.4%; 0 to 2.6
| | | | Leiomyoma 22 = 9.1%; 6.1 to 13.6Pseudomyxoma 2 = 0.8%; 0.05 to 3.2
| | | | Endometriosis 1 = 0.4%; 0 to 2.6
| | | | Mesothelial cyst 1 = 0.4%; 0 to 2.6
| | | | Diverticular abscess 1 = 0.4%; 0 to 2.6
Childers, Nasseri, and Surwit, 1996 | Geographical location: | Age: | Symptomatic (n [%]): | Benign: 119/138 (86.2%; 95% CI, 80.8 to 92.1) | Comments:
#6940 | Tucson, AZ | Mean: 52 | NR | 23 (16.7%; 11.6 to 24.2) cystadenoma | —Patients pre-selected for higher prevalence of malignancy
| Dates: | Range: 9–91 | Detected by exam (n [%]): | 9 (6.5%) 3.4 to 12.3) mucinous cystadenoma | -Clinical presentation not described
| 1991-1995 | Menopausal status (n [%]): | NR | 9 (6.5%; 3.4 to 12.3) cystadenofriboma | Quality assessment:
| Size of population: | NR | Detected by imaging (n [%]): | 11 (8.0%; 4.5 to 14.1) benign teratoma | Size of population from which sample drawn: - (all women at one hospital)
| 138 | Race/ethnicity (n [%]): | NR | 21 (15.2%; 10.3 to 22.5) endometrioma | Number of cases: - (wide CIs)
| Other | NR | Combination (n [%]): | 2 (1.4%; 0.1 to 5.6) Brenner cell | Patient selection: + (consecutive)
| 138 with adnexal mass | Risk factors (n [%]): | NR | 1 (0.7%; 0 to 4.5) struma ovarii | Application of reference standard: + (all had biopsy)
| | NR | Additional data used for diagnosis: | 9 (6.5%; 3.4 to 12.3) hydrosalpinx
| | | All subjects had some concerning finding: | 3 (2.2%; 0.5 to 6.6) corpus luteum
| | | CA-125 elevated: 39 (28%) | 6 (4.3%; 1.9 to 9.5) paraovarian cyst
| | | Abnormal US: 127 (92%) | 15 (10.9%; 6.8 to 17.5) leiomyoma
| | | Mass > 10 cm: 43 (32%) | 6 (4.3%; 1.9 to 9.5) ovarian fibroma
| | | | 3 (2.2%; 0.5 to 6.6) chronic tuboovarian abscess
| | | | Malignant: 19/138 (13.8%; 95% CI, 9.1 to 20.9) (16 of 19 adnexal primaries)
| | | | 5 (3.6%; 1.4 to 8.6) serous carcinoma
| | | | 5 (3.6%; 1.4 to 8.6) serous cystadenocarcinoma
| | | | 6 (4.3%; 1.9 to 9.5) endometroid carcinoma
| | | | 3 (2.2%; 0.5 to 6.6) mixed endometroid and serous carcinoma
| | | | Stage 1= 6
| | | | Stage 2 = 2
| | | | Stage 3 = 5
| | | | Unstaged = 3 (assumed to be Stage I), but 2 had recurrence
Cohen, Escobar, Scharm, et al., 2001 | Geographical location: | Age: | Symptomatic (n [%]): | Malignant: 13/71 = 18.3%; 95% CI, 11.4 to 29.7 | Comments:
#2460 | Chicago, IL | Range: 22–80 | NR | Serous cystadenocarcinoma 5 = 7%; 2.9 to 16.2 | —8/13 and the 1 borderline malignancy were in postmenopausal women
| Dates: | Menopausal status (n [%]): | Detected by exam (n [%]): | Mucinous cystadenocarcinoma 1 = 1.4%; 0 to 8.6 | —Clinical presentation not described
| Apr 1999-Jun 2000 | Pre (< 45): 40 (56%) | NR | Clear cell adenocarcinoma 1 = 1.4%; 0 to 8.6 | —Patients scheduled for surgery; malignancy likely to be overrepresented
| Size of population: | Post (> 55): 31 (44%) | Detected by imaging (n [%]): | Mixed mullerian 1 = 1.4%; 0 to 8.6 | Quality assessment:
| 71 | Race/ethnicity (n [%]): | NR | Malignant germ cell tumor 2 = 2.8%; 0.3 to 10.6 | Size of population from which sample drawn: - (unclear)
| Other | NR | Combination (n [%]): | Metastatic sarcoma 1 = 1.4%; 0 to 8.6 | Number of cases: +
| Women with a complex pelvic mass undergoing laparotomy | Risk factors (n [%]): | NR | Metastatic colon 2 = 2.8%; 0.3 to 10.6 | Patient selection: - (only complex adnexal masses)
| | NR | Additional data used for diagnosis: | Borderline tumors (LMP): 1/71 = 1.4%; 0 to 8.6 | Application of reference standard: + (all had biopsy)
| | | NR | Serous cystadenocarcinoma 1 = 1.4%; 0 to 8.6
| | | | Benign: 57/71 = 80.3%; 71.9 to 89.7
| | | | Serous cystadenoma 9 = 12.7%; 7.0 to 23.2
| | | | Mucinous cystadenoma 6 = 8.4%; 3.9 to 18.0
| | | | Adenofibroma 10 = 14.1%; 8 to 24.8
| | | | Endometrioma 11 = 15.5%; 9.1 to 26.5
| | | | Cystic teratoma 13 = 18.3%; 11.4 to 29.7
| | | | Thecoma 1 = 1.4%; 0 to 8.6
| | | | Hydrosalpinx 4 = 5.6%; 2 to 14.4
| | | | Tamoxifen stimulation 2 = 2.8%; 0.3 to 10.6
| | | | Leiomyoma 1 = 1.4%; 0 to 8.6
DePriest, Gallion, Pavlik, et al., 1997 | Geographical location: | Age: | Symptomatic (n [%]): | Of the 6470 screened: | Comments:
#3650 | Lexington, KY | Mean: 58 | NR | 7/6,470 malignant (ovarian) = 0.11%; 95% CI, 0.05 to 0.2 | DePriest, van Nagell Jr., Gallion, et al., 1993 [#6880])
| Dates: | Range: 30–92 | Detected by exam (n [%]): | 1/6,470 malignant (non-ovarian) = 0.02%; 0 to 0.1 | —Most patients had either ovarian, breast or colon cancer family history
| Dec 1987-Dec 1993 | Menopausal status (n [%]): | NR | 83/6,470 benign = 1.2%; 1.0 to 0.12 | Quality assessment:
| Size of population: | NR | Detected by imaging (n [%]): | Malignant: | Size of population from which sample drawn: + (6,470/small city)
| 6470; 8 found to have cancer (7 of these cancers were ovarian) | Race/ethnicity (n [%]): | 99% (all but one was detected by imaging) | Granulosa cell tumor 3 = 0.05%; 95% CI, 0.01 to 0.14 | Number of cases: - (8 with cancer)
| Screening study | NR | Combination (n [%]): | Adenocarcinoma 2 = 0.03%; 0 to 0.12 | Patient selection: + (well-specified mix of postmenopausal women and high-risk younger women)
| Used TVUS in asymptomatic women > 50 or postmenopausal and women > 30 with positive family history of ovarian carcinoma | Risk factors (n [%]): | NR | Serous cystadenocarcinoma 1 = 0.02%; 0 to 0.1 | Application of reference standard: + (all had biopsy)
| | Family history of: | Additional data used for diagnosis: | Endometrioid carcinoma 1 = 0.02%; 0 to 0.1
| | Ovarian cancer: 24% | NR | Metastatic colon cancer 1 = 0.02%; 0 to 0.1
| | Breast cancer: 30% | | Benign:
| | Colon cancer: 15% | | Serous cystadenoma 37 = 0.6%; 95% CI, 0.4 to 0.8
| | | | Endometriosis 18 = 0.3%; 0.2 to 0.4
| | | | Mucinous cystadenoma 3 = 0.05%; 0.01 to 0.14
| | | | Cystic teratoma 3 = 0.05%; 0.01 to 0.14
| | | | Hemorrhagic cyst 2 = 0.03%; 0 to 0.12
| | | | Fibroma/thecoma/Brenner tumor 4 = 0.06%; 0.02 to 0.2
| | | | Leiomyomata 4 = 0.06%; 0.02 to 0.2
| | | | Hydrosalpinx/paratubal 8 = 0.12%; 0.06 to 0.25
| | | | Other 4 = 0.06%; 0.02 to 0.2
DePriest, Shenson, Fried, et al., 1993 | Geographical location: | Age: | Symptomatic (n [%]): | Malignant: 13/121 = 10.7%; 95% CI, 6.5 to 17.9 | Comments:
#6390 | Lexington, KY | Range: 3–74 | NR | Serous cystadenocarcinoma 6 = 5%; 2.2 to 10.8 | —Clinical presentation not described
| Dates: | Menopausal status (n [%]): | Detected by exam (n [%]): | Mucinous cystadenocarcinoma 2 = 1.6%; 0.1 to 6.4 | —Patients scheduled for surgery; malignancy likely overrepresented
| Jan 1987-Jan1992 | Pre (< 45): 62 (51%) | NR | Granulosa cell tumor 1 = 0.8%; 0 to 5.1 | Quality assessment:
| Size of population: | Post (> 55): 59 (49%) | Detected by imaging (n [%]): | Metastatic adenocarcinoma 2 = 1.6%; 0.1 to 6.4 | Size of population from which sample drawn: - (not sure)
| 121 | Race/ethnicity (n [%]): | NR | Neurogenic sarcoma 1 = 0.8%; 0 to 5.1 | Number of cases: - (wide CI)
| Other | NR | Combination (n [%]): | Lymphoma 1 = 0.8%; 0 to 5.1 | Patient selection: - (only those going to surgery)
| Women with ovarian mass undergoing laparotomy | Risk factors (n [%]): | NR | Benign: 108/121 = 89.3%; 95% CI, 84 to 94.8 | Application of reference standard: + (all had biopsy)
| | NR | Additional data used for diagnosis: | Serous cystadenoma 21 = 17.4%; 11.9 to 25.5
| | | NR | Mucinous cystadenoma 2 = 1.6%; 0.1 to 6.4
| | | | PID 18 = 14.9%; 9.8 to 22.7
| | | | Benign cysts = 17 = 14%; 9.1 to 21.8
| | | | Endometriosis 14 = 11.6%; 7.1 to 18.9
| | | | Hemorrhagic corpus luteum cyst 12 = 9.9%; 5.8 to 16.9
| | | | Teratoma 11 = 9.1%; 5.2 to 16
| | | | Fibroma = 5 = 4.1%; 1.6 to 9.7
| | | | Leiomyoma 4 = 3.3%; 1.1 to 8.6
| | | | Normal ovary 4 = 3.3%; 1.1 to 8.6
DePriest, van Nagell Jr., Gallion, et al., 1993 | Geographical location: | Age: | Symptomatic (n [%]): | Benign: 41/3220 (1.3%; 95% CI, 0.9 to 1.7) | Comments:
#6880 | Lexington, KY | Mean: 60 | 0 | 21 (0.7%; 0.4 to 1.0) serous cystadenoma | —Majority, if not all, patients had either breast, ovarian, or colorectal cancer family history
| Dates: | Range: 33–90 | Detected by exam (n [%]): | 4 (0.1%; 0.04 to 0.30) endometrioma | —True negative defined as negative biopsy or no diagnosed cancer within 1 year of ultrasound
| Nov 1987-Jun 1992 | Menopausal status (n [%]): | 0 | 1 (0.03%; 0.0.2) cystadenofibroma | Quality assessment:
| Size of population: | Post (> 55): 100% | Detected by imaging (n [%]): | 1(0.03%; 0.0.2) thecoma | Size of population from which sample drawn: - (unclear how representative — small city )
| 3220 | Race/ethnicity (n [%]): | 44 had abnormal TVUS (1.4%) | 1 (0.03%; 0.0.2) teratoma | Number of cases: + (although only 3 with cancer)
| 3 had cancer | NR | Combination (n [%]): | 2 (0.06%; 0 to 0.2) fibroma | Patient selection: - (some had family history)
| Screening study (and most had a positive family history) | Risk factors (n [%]): | 0 | 3 (0.09%; 0.02 to 0.3) hydrodsalpinx | Application of reference standard: + (exploratory lab with biopsy)
| | Family history of: | Additional data used for diagnosis: | 5 (0.16%; 0.06 to 0.4) paratubal cyst
| | Ovarian cancer: 502 (15.6%) | NR | 3 (0.09%; 0.02 to 0.3) myoma
| | Breast cancer: 1034 (32.1%) | | Malignant: 3/3220 (0.09%; 95% CI, 0.02, 0.29%)
| | Colorectal cancer: 678 (21.1%) | | 3 primary ovarian adenocarcinoma
| | | | 2 Stage IA
| | | | 1 Stage IIIB
Dottino, Levine, Ripley, et al., 1999 | Geographical location: | Age: | Symptomatic (n [%]): | Benign: 139/160 (86.9%; 95% CI, 81.9 to 92.2) | Comments:
#6920 | New York, NY | Mean (SD): 52.2 (13.1) | NR | Borderline: 8 (5%; 95% CI, 2.5 to 9.9) | —Clinical presentation not described
| Dates: | Menopausal status (n [%]): | Detected by exam (n [%]): | Malignant: 13 (8.1%; 95% CI, 4.8 to 13.7) | Quality assessment:
| Apr 1992-Apr 1996 | Pre (< 45): 75 (47%) | NR | 6 epithelial cancers (3.7%; 1.6 to 8.2) | Size of population from which sample drawn: + (large city)
| Size of population: | Post (> 55): 85 (53%) | Detected by imaging (n [%]): | 2 Stage 1A (1.2%; 0.09 to 4.8) | Number of cases: - (wide CIs)
| 160 | Race/ethnicity (n [%]): | NR | 1 Stage 2C (0.6%; 0 to 3.9) | Patient selection: - (not described)
| Other | White 146 (91%) | Combination (n [%]): | 1 Stage 3A (0.6%; 0 to 3.9) | Application of reference standard: + (all had biopsy)
| Adnexal mass undergoing laparoscopic surgery | Risk factors (n [%]): | NR | 1 Stage 3C (0.6%; 0 to 3.9)
| | NR | Additional data used for diagnosis: | 1 Stage 4 (0.6%; 0 to 3.9)
| | | NR | 3 sex cord stromal tumors (1.9%; 0.4 to 5.7)
| | | | 2 Sertoli-Leydig cell (1.2%; 0.09 to 4.8)
| | | | 1 granulosa cell (0.6%; 0 to 3.9)
| | | | 4 non-gynecologic cancers (4%; 0.8 to 6.6)
Fleischer, Cullinan, Jones 3^rd^, et al., 1996 | Geographical location: | Age: | Symptomatic (n [%]): | Benign: 31/62 (50%; 95% CI, 39.5 to 63.5) | Comments:
#3840 | Nashville, TN | Mean: 50 | NR | 10 (16.1%; 9.3 to 28.2) hemorrhagic corpus luteum | —Clinical presentation not described
| Dates: | Range: 17–88 | Detected by exam (n [%]): | 1 (1.6%; 0 to 9.8) serous cyst | Quality assessment:
| 1990-1995 | Menopausal status (n [%]): | NR | 4 (6.4%; 2.3 to 16.4) cystadenomas | Size of population from which sample drawn: - (1 hospital)
| Size of population: | Pre (< 45): NR | Detected by imaging (n [%]): | 4 (6.4%; 2.3 to 16.4) endometriomas | Number of cases: - (small and wide CIs)
| 62 | Peri (45–55): NR | 100% | 8 (12.9%; 6.9 to 24.4) dermoid cysts | Patient selection: - (not described)
| Other | Post (> 55): (over 50%) | Combination (n [%]): | 2 (3.2%; 0.4 to 12.1) ovarian fibroma | Application of reference standard: + (all had biopsy)
| Patients who underwent Doppler for adnexal mass | Race/ethnicity (n [%]): | NR | 2 (3.2%; 0.4 to 12.1 leiomyoma
| | NR | Additional data used for diagnosis: | Malignant: 31/62 (50%; 95% CI, 39.5 to 63.5)
| | Risk factors (n [%]): | NR | 16 (25.8%; 17.3 to 39.0) cystadeno-carcinomas
| | NR | | 1 (1.6%; 0 to 9.8) papillary serous adenocarcinomas
| | | | 1 (1.6%; 0 to 9.8) endometroid carcinoma
| | | | 1 (1.6%; 0 to 9.8) dysgerminoma
| | | | 4 (6.4%; 2.3 to 16.4) metastases
| | | | 4 (6.4%; 2.3 to 16.4) germ cell tumors
| | | | 4 (6.4%; 2.3 to 16.4) stromal tumors
Lin, Angel, DuBeshter, et al., 1993 | Geographical location: | Age: | Symptomatic (n [%]): | Benign: 32/80 (40%; 95% CI, 30.9 to 52) | Comments:
#4890 | Rochester NY | Median: 56 | 70 (87%) | 23 (28.7%; 20.6 to 40.3) benign cyst | —Clinical presentation not described
| Dates: | Range: 19–88 | Detected by exam (n [%]): | 8 (10%; 5.2 to 19.2) other benign gynecologic condition | Quality assessment:
| Jun 1989-Jun 1990 | Menopausal status (n [%]): | 80 (100%) | 1 (1.2%; 0 to 7.7) diverticular disease | Size of population from which sample drawn: - (1 hospital)
| Size of population: | Pre (< 45): NR | —59 (74%) with discrete mass | Borderline: 2/80 (2.5%; 95% CI, 0.3 to 9.5) | Number of cases: - (wide CIs)
| 80 | Peri/Post: 62 (76%) | —21 (26%) ill-defined fullness | Malignant: 46/80 (57.5%; 48 to 69.1) | Patient selection: - (not described)
| Other | Race/ethnicity (n [%]): | Detected by imaging (n [%]): | 6 (7.5%; 3.4 to 16.1) colorectal carcinoma | Application of reference standard: + (all had biopsy)
| Pelvic masses undergoing laparoscopic surgery | White 72 (90%) | NR | 1 (1.2%; 0 to 7.7) endometrial carcinoma
| | Black 8 (10%) | Combination (n [%]): | 1 (1.2%; 0 to 7.7) vaginal carcinoma
| | Risk factors (n [%]): | NR | 2 (2.5%; 0.3 to 9.5) breast carcinoma
| | Family history of: | Additional data used for diagnosis: | 2 (2.5%; 0.3 to 9.5) lymphoma
| | Ovarian/breast/colon cancer: 11 (14%) | NR | 4 (5%; 1.7 to 12.9) multiple sites
| | | | 30 (37.5%; 28.6 to 49.5) ovarian carcinoma
| | | | 6 (7.5%; 3.4 to 16.1) Stage 1
| | | | 26 (32.5%; 24 to 44.3) Stage 3
| | | | 4 (5%; 1.7 to 12.9) Stage 4
Modesitt, Pavlik, Ueland, et al., 2003 | Geographical location: | Age: | Symptomatic (n [%]): | Benign: 117/15106 (0.8%; 95% CI, 0.6 to 0.9) | Comments:
#5560 | Lexington, KY | Range: 50–70+ | 0 | 61 (0.4%; 0.3 to 0.5) serous cystadenomas | —Although cumulative incidence data are helpful, unable to calculate annual incidence rates given data provided
| Dates: | Menopausal status (n [%]): | Detected by exam (n [%]): | 14 (0.09%; 0.05 to 0.16) serous cystadenofibromas | Quality assessment:
| 1987-2002 | Post (> 55): 100% | 0 | 9 (0.06%; 0.03 to 0.12) mucinous cystadenoma | Size of population from which sample drawn: + (population-based)
| Size of population: | Race/ethnicity (n [%]): | Detected by imaging (n [%]): | 9 (0.06%; 0.03 to 0.12) paraovarian | Number of cases: + (narrow CIs)
| 27 cancers/15,106 | NR | 100% | 7 (0.05%; 0.02 to 0.1) fibrothecoma | Patient selection: Screening study, all over 50
| Screening study with TVUS and followed up with Doppler and CA-125 if abnormal | Risk factors (n [%]): | Combination (n [%]): | 5 (0.03%; 0.01 to 0.08) endometrioma | Application of reference standard: +
| | Family history: some but NR | NR | 3 (0.02%; 0 to 0.06) cystic teratoma | (subset of patient underwent biopsy)
| | | Additional data used for diagnosis: | 1 (0.01%; 0 to 0.04) mucinous cystadenofibroma
| | | NR | 8 (0.05%; 0.03 to 0.11) other
| | | | Malignant: 27/15106 (0.18%; 95% CI, 0.12 to 0.26)
| | | | 17 (0.11%; 0.07 to 0.18) Stage 1
| | | | 4 (0.03%; 0.01 to 0.07) Stage 2
| | | | 6 (0.04%; 0.02 to 0.09) Stage 3
| | | | Note: this is a separate group; of these 27, 10 had had simple ovarian cyst at one point in screening; 7 had additional morphologic abnormality, 2 had resolution of cyst before developing cancer, 1 had cancer in contralateral ovary
| | | | Unilocular cyst — cumulative incidence by age:
| | | | 50–54 1315/5229 (25.1%)
| | | | 55–59 481/3278 (14.7%)
| | | | 60–64 373/2694 (13.8%)
| | | | 65–69 271/2008 (13.5%)
| | | | 70+ 323/1897 (17.0%)
Parker, Levine, Howard, et al., 1994 | Geographical location: | Age: | Symptomatic (n [%]): | All tumors were benign and were in postmenopausal women: | Comments:
#910 | Santa Monica, Irvine, and Los Angeles, CA; Louisville, KY; Rochester, NY | Mean: 65 | NR | 27 (44.3%; 95% CI, 33.9 to 58.1) serous cystomas | —Clinical presentation not reported
| Dates: | Range: 47–81 | Detected by exam (n [%]): | 15 (24.6%; 16.2 to 37.8) serous cystadenomas | Quality assessment:
| NR; published 1994 | Menopausal status (n [%]): | NR | 1 (1.6%; 0 to 9.9) mucinous cystadenomas | Size of population from which sample drawn: + (multiple sites)
| Size of population: | Post (> 55): 61 (100%) | Detected by imaging (n [%]): | 5 (8.2%; 3.5 to 18.7) cystadenofibromas | Number of cases: - (no cancers; wide CIs)
| 61 | Race/ethnicity (n [%]): | 100% | 4 (6.6%; 2.4 to 16.7) hydrosalpinges | Patient selection: - (limited to benign-appearing cystic masses)
| Other | NR | Combination (n [%]): | 6 (9.8%; 4.6 to 20.8) paratubal cysts | Application of reference standard: + (all had biopsy)
| Laparoscopic management of benign-appearing cystic masses | Risk factors (n [%]): | NR | 3 (4.9%; 1.4 to 14.5) paraovarian cysts
| | NR | Additional data used for diagnosis:
| | | NR
Roman, Muderspach, Stein, et al., 1997 | Geographical location: | Age: | Symptomatic (n [%]): | Of the 226 enrolled: | Comments:
#6160 | Los Angeles, CA | NR | NR | 26/226 were malignant = 11.5%; 95% CI, 8.0 to 16.5 | —Clinical presentation not described
| Dates: | Menopausal status (n [%]): | Detected by exam (n [%]): | 17/226 borderline tumors = 7.5%; 4.8 to 11.9 | —Patients underwent surgery; malignancy likely overrepresented
| Jul 1992-Mar 1994 | Pre (< 45): 181 (80%) | NR | 183/226 were benign = 81%; 76.1 to 86.2 | —Included women with pregnancy
| Size of population: | Post (> 55): 45 (20%) | Detected by imaging (n [%]): | Malignant: | —Age range NR, but 80% reported to be premenopausal
| 226 | Race/ethnicity (n [%]): | NR | Epithelial cancer 15 = 6.6%; 95% CI, 4.1 to 10.9 | Quality assessment:
| Other: | NR | Combination (n [%]): | Germ cell cancer 4 = 1.8%; 0.6 to 4.7 | Size of population from which sample drawn: - (unknown)
| Prospective study of women scheduled for removal of pelvic mass; included women with pregnancy | Risk factors (n [%]): | NR | Stromal cancer 6 = 2.7%; 1.1 to 5.9 | Number of cases: - (226)
| | NR | Additional data used for diagnosis: | Sarcoma 1 = 0.4%; 0 to 2.8 | Patient selection: + (prospectively collected information among women already scheduled for surgery)
| | | NR | Borderline tumors: | Application of reference standard: + (all had biopsy )
| | | | LMP 17 = 7.5%; 95% CI, 4.8 to 11.9
| | | | Benign:
| | | | Simple or functional cyst 46 = 20.4%; 95% CI, 15.8 to 26.3
| | | | Inflammatory process 18 = 8.0%; 5.1 to 12.4
| | | | Endometrioma 32 = 14.2%; 10.3 to 19.5
| | | | Cystic teratoma 32 = 14.2%; 10.3 to 19.5
| | | | Leiomyoma 11 = 4.9%; 2.7 to 8.7
| | | | Fibroma-thecoma 6 = 2.7%; 1.1 to 5.9
| | | | Cystadenoma 35 = 15.5%; 11.5 to 21
| | | | Cystadenofibroma 3 = 1.3%; 0.3 to 4.1
Schneider, Schneider, Reed, et al., 1993 | Geographical location: | Age: | Symptomatic (n [%]): | Of the 55 enrolled: | Comments:
#4830 | Tucson, AZ | Mean: 53 | NR | 14/55 were malignant = 25.5%; 95% CI, 16.6 to 39.5 | —Clinical presentation not described
| Dates: | Median: 53 | Detected by exam (n [%]): | 2/55 were borderline tumors = 3.6%; 0.5 to13.5 | —Patients underwent surgery and therefore malignancy likely to be over-represented
| NR; published 1993 | Range: 10–79 | NR | 39/55 were benign 70.9%; 60.5 to 83.4 | Quality assessment:
| Size of population: | Menopausal status (n [%]): | Detected by imaging (n [%]): | Malignant: | Size of population from which sample drawn: - (unknown)
| 55 | Pre (< 45): 22 (40%) | NR | Endometriod cancer 6 = 10.9%; 95% CI, 5.2 to 22.9 | Number of cases: - (55)
| Other: | Post (> 55): 33 (60%) | Combination (n [%]): | Adenocarcinoma, undifferentiated 3 = 5.5%; 1.5 to 16 | Patient selection: - (cross-sectional)
| Patients undergoing surgery for adnexal mass | Race/ethnicity (n [%]): | NR | Carcinosarcoma 1 = 1.8%; 0 to 11 | Application of reference standard: + (all had biopsy )
| | NR | Additional data used for diagnosis: | Clear-cell adenocarcinoma 1 = 1.8%; 0 to 11
| | Risk factors (n [%]): | NR | Krukenberg tumor (primary gastric) 1 = 1.8%; 0 to 11
| | NR | | Malignant Brenner tumor 1 = 1.8%; 0 to 11
| | | | Leiomyosarcoma 1 = 1.8%; 0 to 11
| | | | Borderline tumors (LMP):
| | | | Serous cystadenocarcinoma 2 = 3.6%; 95% CI, 0.5 to13.5
| | | | Benign:
| | | | Serous cystadenoma 12 = 21.8%; 95% CI, 13.6 to 35.6
| | | | Endometriosis 4 = 7.3%; 2.7 to 18.4
| | | | Mucinous cystadenoma 3 = 5.5%; 1.5 to 16
| | | | Follicular cyst 3 = 5.5%; 1.5 to 16
| | | | Adenofibroma 1 = 1.8%; 0 to 11
| | | | Brenner tumor 1 = 1.8%; 0 to 11
| | | | Corpus luteum cyst 1 = 1.8%; 0 to 11
| | | | Fibroma 1 = 1.8%; 0 to 11
| | | | Mature teratoma 1 = 1.8%; 0 to 11
| | | | Mixed stromal cell tumor 1 = 1.8%; 0 to 11
| | | | Serous Cystadenofibroma 1 = 1.8%; 0 to 11
| | | | Leiomyoma 4 = 7.3%; 2.7 to 18.4
| | | | Paraovarian cyst 3 = 5.5%; 1.5 to 16
| | | | Hydrosalpinx 2 = 3.6%; 0.5 to 13.5
| | | | Peritoneal inclusion cyst 1 = 1.8%; 0 to 11
Scoutt, McCarthy, Lange, et al., 1994 | Geographical location: | Age: | Symptomatic (n [%]): | Benign: 87/109 (79.8%; 95% CI, 72.8 to 87.5) | Comments:
#4530 | Connecticut | Median: 40 | NR | 17 (15.6%; 10.2 to 24.1) leiomyoma | —Clinical presentation not described
| Dates: | Range: 2–87 | Detected by exam (n [%]): | 19 (17.4%; 11.7 to 26.1) dermoid | Quality assessment:
| 1988-1990 | Menopausal status (n [%]): | NR | 13 (11.9%; 7.2 to 19.8) endometrioma | Size of population from which sample drawn: - (1 hospital)
| Size of population: | NR | Detected by imaging (n [%]): | 9 (8.3%; 4.4 to 15.4) hemorrhagic cysts | Number of cases: - (wide CIs)
| 109 masses with MRI | Race/ethnicity (n [%]): | NR | 9 (8.3%; 4.4 to 15.4) simple cysts | Patient selection: - (suspected mass who had MRI)
| Other | NR | Combination (n [%]): | 5 (4.6%; 1.8 to 10.8) serous cystadenoma | Application of reference standard: + (all had biopsy)
| Clinical masses that underwent MRI and then biopsy | Risk factors (n [%]): | 109 (100%) | 3 (2.7%; 0.7 to 8.3) mucinous cystadenoma
| | NR | Additional data used for diagnosis: | 3 (2.7%; 0.7 to 8.3) friboma
| | | NR | 3 (2.7%; 0.7 to 8.3) tuboovarian abscess
| | | | 3 (2.7%; 0.7 to 8.3) paratubal cyst
| | | | 1 (0.9%; 0 to 5.7) fibrothecoma
| | | | 1 (0.9%; 0 to 5.7) leutinized thecoma
| | | | 1 (0.9%; 0 to 5.7) hematosalpinx
| | | | Malignant: 22/109 (20.2%; 95% CI, 14 to 29.2)
| | | | 5 (4.6%; 1.8 to 10.8) papillary serous cystadenocarcinoma
| | | | 4 (3.7; 1.2 to 9.6%) metastatic adenocarcinoma
| | | | 3 (2.7%; 0.7 to 8.3) mucinous cystadenocarcinoma
| | | | 3 (2.7%; 0.7 to 8.3) endometroid carcinoma
| | | | 2 (1.8%; 0.2 to 7.0) adenocarcinoma
| | | | 1 (0.9%; 0 to 5.7) immature teratoma
| | | | 1 (0.9%; 0 to 5.7) embryonal cell carcinoma
| | | | 1 (0.9%; 0 to 5.7) dysgerminoma
| | | | 1 (0.9%; 0 to 5.7) granulosa cell tumor
| | | | 1 (0.9%; 0 to 5.7) endometrial carcinoma
Shen-Gunther and Mannel, 2002 | Geographical location: | Age: | Symptomatic (n [%]): | Benign: 57/125 (45.6%; 95% CI, 37.8 to 55.1) | Comments:
#2090 | Las Vegas, NV; Oklahoma City, OK | Median: 58 | NR | 22 (17.6%; 12.1 to 25.6) serous cystadenoma | —Large proportion of subjects had ascites on exam or imaging — very high prevalence of malignancy
| Dates: | Range: 18–86 | Detected by exam (n [%]): | 3 (2.4%; 0.6 to 7.3) mucinous cystadenoma | Quality assessment:
| Jan 1994-Dec 1994 and Jan 1999-Dec 2001 | Menopausal status (n [%]): | 6% | 4 (3.2%; 1.1 to 8.4) friboma | Size of population from which sample drawn: + (2 cities)
| Size of population: | NR | Detected by imaging (n [%]): | 2 (1.6%; 0.1 to 6.2) thecoma | Number of cases: - (wide CIs)
| 125 | Race/ethnicity (n [%]): | Ultrasound 46% | 5 (4%; 1.6 to 9.4) teratoma | Patient selection: - (2 separate time frames introduces bias; also high prevalence of ascites)
| Other | White 82% | CT 18% | 5 (4%; 1.6 to 9.4 follicular cyst | Application of reference standard: + (all had biopsy)
| Patients treated for pelvic mass | Black 9% | Both 31% | 1 (0.8%; 0 to 5) paratubal cyst
| | Hispanic 2% | Combination (n [%]): | 5 (4%; 1.6 to 9.4 hemorrhagic cysts
| | Asian 4% | NR | 2 (1.6%; 0.1 to 6.2) tuboovarian adhesions
| | American Indian 3% | Additional data used for diagnosis: | 8 (6.4%; 3.2 to 12.5) endometrioma
| | Risk factors (n [%]): | NR | Borderline (LMP): 12/125 (9.6%; 95% CI, 5.6 to 16.4)
| | NR | | 8 (6.4%; 3.2 to 12.5) serous low malignant potential
| | | | 4 (3.2%; 1.1 to 8.4) mucinous low malignant potential
| | | | Malignant: 56/125 (44.8%; 37.1 to 54.3)
| | | | 39 (31.2%; 24.2 to 40.3) serous cystadenocarcinoma
| | | | 2 (1.6%; 0.1 to 6.2) mucinous cystadenocarcinoma
| | | | 4 (3.2%; 1.1 to 8.4) endometroid carcinoma
| | | | 4 (3.2%; 1.1 to 8.4) primary peritoneal carcinoma
| | | | 2 (1.6%; 0.1 to 6.2) clear cell carcinoma
| | | | 1 (0.8%; 0 to 5) undifferentiated adenocarcinoma
| | | | 2 (1.6%; 0 to 5) immature teratoma
| | | | Stage 1 = 11
| | | | Stage 2 = 1
| | | | Stage 3 = 33
| | | | Stage 4 = 5
| | | | Unstaged = 6
Smikle, Lunt, and Hankins, 1995 | Geographical location: | Age: | Symptomatic (n [%]): | Benign: 169/195 (86.7%; 95% CI, 82.1 to 95.0) | Comments:
#6290 | San Antonio, TX | Range: < 20 and > 61 | NR | 37 (19.0%; 14.3 to 25.3) serous cystadenoma | —Clinical presentation not described
| Dates: | Menopausal status (n [%]): | Detected by exam (n [%]): | 11 (5.6%; 3.2 to 10.1) mucinous cystadenoma | Quality assessment:
| Jun 1990-Aug 1992 | Pre (< 45): NR | NR | 26 (13.3%; 9.4 to 19.1) hemorrhagic cysts | Size of population from which sample drawn: - (military hospital)
| Size of population: | Peri (45–55): NR | Detected by imaging (n [%]): | 20 (10.3%; 6.8 to 15.6) endometriosis | Number of cases: - (26 cancers and wide CIs)
| 195 | Post (> 55): 78 (40%) 51 and older | NR | 17 (8.7%; 5.5 to 13.8) teratoma (mature) | Patient selection: - (all surgical cases)
| Other | Race/ethnicity (n [%]): | Combination (n [%]): | 7 (3.6%; 1.7 to 7.6) cyst of Morgagni | Application of reference standard: + (all had biopsy)
| Surgical cases with preoperative diagnosis of pelvic mass | NR | 195 (100%) | Data not provided for 27 cases
| | Risk factors (n [%]): | Additional data used for diagnosis: | Malignant: 26/195 (13.3%; 95% CI, 9.4 to 19.1)
| | NR | NR | 14 (7.2%; 4.3 to 11.9) serous cystadenocarcinoma
| | | | 5 (2.6%; 1.0 to 6.3) mucinous cystadenocarcinoma
| | | | 1 (0.5%; 0 to 3.2) endometroid carcinoma
| | | | 4 (2.1%; 0.7 to 5.4) undifferentiated adenocarcinoma
| | | | 1 (0.6%; 0 to 3.2) granulosa cell carcinoma
| | | | Benign mass by age:
| | | | Age ≤ 50 (n = 117)
| | | | Serous cystadenoma: 19 (16.2%; 95% CI, 10.9 to 24.4)
| | | | Functional cyst: 20 (17.1%; 11.6 to 25.4)
| | | | Hydrosalpinx/tuboovarian abscess: 18 (15.4%; 10.1 to 23.5%)
| | | | Endometriosis: 16 (13.7%; 8.7 to 21.5)
| | | | Mature teratoma: 11 (9.4%; 5.4 to 16.5)
| | | | Mucinous cystadenoma: 3 (2.6%; 0.6 to 7.8)
| | | | Cyst of Morgagni: 4 (3.4%; 1.1 to 8.9)
| | | | Age > 50 (n = 78)
| | | | Serous cystadenoma: 18 (23.1%;15.6 to 34.4)
| | | | Functional cyst: 6 (7.7%; 3.5 to 16.5)
| | | | Hydrosalpinx/ tuboovarian abscess: 5 (6.4%; 2.6 to 14.9)
| | | | Endometriosis: 4 (5.1%; 1.8 to13.2)
| | | | Mature teratoma: 6 (7.7%; 3.5 to 16.5)
| | | | Mucinous cystadenoma: 8 (10.3%; 5.3 to 19.7)
| | | | Cyst of Morgagni: 3 (3.9%; 1.0 to 11.5%)
Troiano, Quedens-Case, and Taylor, 1997 | Geographical location: | Age: | Symptomatic (n [%]): | Malignant: 17/144 = 11.8%; 95% CI, 7.6 to 18.4 | Comments:
#3680 | New Haven, CT | Mean: Approx. 45 | NR | Serous cystadenocarcinoma 7 = 4.9%; 2.3 to 10 | —Not all subjects went to surgery; better generalizability, but possible error in diagnosis
| Dates: | Range: 18–79 | Detected by exam (n [%]): | Mucinous cystadenocarcinoma 1 = 0.7%; 0 to 4.3 | Quality assessment:
| 1991-1996 | Menopausal status (n [%]): | 100% suspected mass on exam | Endometrioid carcinoma 1 = 0.7%; 0 to 4.3 | Size of population from which sample drawn: - (not clear)
| Size of population: | Pre (< 45): 101 (70%) | Detected by imaging (n [%]): | Embryonal cell carcinoma 1 = 0.7%; 0 to 4.3 | Number of cases: - (wide CIs)
| 144 patients | Post (> 55): 42 (29%) | NR | Granulosa cell 1 = 0.7%; 0 to 4.3 | Patient selection: + (better than the others — all with suspected mass on exam)
| Other | Missing 1 case | Combination (n [%]): | Fallopian tube carcinoma 1 = 0.7%; 0 to 4.3 | Application of reference standard: + (not all had biopsy, but all had followup)
| Patients with suspected mass on exam and referred for US; not all went on to surgery, but all had followup | Race/ethnicity (n [%]): | NR | Endometrial 1 = 0.7%; 0 to 4.3
| | NR | Additional data used for diagnosis: | Metastatic 4 = 2.8%; 0.9 to 7.3
| | Risk factors (n [%]): | NR | Borderline tumors 3/144 = 2.1%; 0.5 to 6.3
| | NR | | Borderline papillary serous 3 = 2.1%; 0.5 to 6.3
| | | | Benign: 97/144 = 67.4%; 95% CI, 60.3 to 75.3
| | | | Serous cystadenoma 1 = 0.7%; 0 to 4.3
| | | | Mucinous cystadenoma 3 = 2.1%; 0.5 to 6.3
| | | | Functional ovarian cyst 3 = 2.1%; 0.5 to 6.3
| | | | Paratubal cyst 4 = 2.8%; 0.9 to 7.3
| | | | Ovarian dermoid cyst 4 = 2.8%; 0.9 to 7.3
| | | | Fibroma or thecoma 2 = 1.4%; 0.1 to 5.4
| | | | Cystadenofibroma 1 = 0.7%; 0 to 4.3
| | | | Endometriosis or hemorrhagic cyst 16 = 11.1%; 7 to 17.6
| | | | Leiomyomas or adenomyosis 43 29.9%; 23.4 to 38.3
| | | | Leiomyomas with endometriosis 6 = 4.2%; 1.8 to 9.1
| | | | Leiomyomas with simple ovarian cyst 2 = 1.4%; 0.1 to 5.4
| | | | Leiomyomas with paratubal cyst 1 = 0.7%; 0 to 4.3
| | | | Leiomyomas with ovarian fibroma 1 = 0.7%; 0 to 4.3
| | | | Leiomyomas with Brenner tumor 1 = 0.7%; 0 to 4.3
| | | | Leiomyomas with ovarian cystadenoma 2 = 1.4%; 0.1 to 5.4
| | | | Cirrhosis 1 = 0.7%; 0 to 4.3
| | | | Pregnancy 1 = 0.7%; 0 to 4.3
| | | | No biopsy because ultrasound negative: 27 = 18.7%; 95% CI, 13.4 to 26.3
Twickler, Forte, Santos-Ramos, et al., 1999 | Geographical location: | Age: | Symptomatic (n [%]): | Malignant: 14/244 = 5.7%; 95% CI, 3.4 to 9.6 | Comments:
#3080 | Dallas, TX | Mean: 38.6 | NR | Serous 4 = 1.6%; 0.5 to 4.4 | —Not all subjects went to surgery; better generalizability, but more possibility of error
| Dates: | Range: 15–80 | Detected by exam (n [%]): | Metastasis 4 = 1.6%; 0.5 to 4.4 | Quality assessment:
| Feb 1993-Aug 1996 | Menopausal status (n [%]): | NR | Adenocarcinoma 2 = 0.8%; 0.05 to 3.2 | Size of population from which sample drawn: - (not known)
| Size of population: | NR | Detected by imaging (n [%]): | Mucinous 1 = 0.4%; 0 to 2.6 | Number of cases: +
| 244 women | Race/ethnicity (n [%]): | NR | Small cell 1 = 0.4%; 0 to 2.6 | Patient selection: - (not clear)
| Other | NR | Combination (n [%]): | Sarcoma 1 = 0.4%; 0 to 2.6 | Application of reference standard: - (not all had biopsy and some were lost to followup )
| 304 had ultrasound for mass, and 217 had surgery and another 27 had ultrasound followup, for a total of 244 | Risk factors (n [%]): | NR | Mixed germ cell 1 = 0.4%; 0 to 2.6
| | NR | Additional data used for diagnosis: | Borderline tumors: 16/244 = 6.6%; 95% CI, 4.1 to 10.6
| | | NR | Mucinous 8 = 3.3%; 1.6 to 6.5
| | | | Serous 5 = 2%; 0.8 to 4.9
| | | | Granulosa cell 2 = 0.8%; 0.05 to 3.2
| | | | Endometrioid 1 = 0.4%; 0 to 2.6
| | | | Benign: 214/244 = 87.7%; 83.7 to 91.9
| | | | Simple functional cyst 69 = 28.3%; 23.2 to 34.5
| | | | PID mass 25 = 10.2%; 7.1 to 14.9
| | | | Endometriomas 13 = 5.3%; 3.1 to 9.1
| | | | No ovarian mass 7 = 2.9%; 1.3 to 6
| | | | Non-defined ovarian cystic disease 8 = 3.3%; 1.6 to 6.5
| | | | Para-ovarian cyst 1 = 0.4%; 0 to 2.6
| | | | Paratubal cyst 1 = 0.4%; 0 to 2.6
| | | | Fibrovascular ampullary mass 1 = 0.4%; 0 to 2.6
| | | | Ectopic mass 1 = 0.4%; 0 to 2.6
| | | | Ovarian lymphocele 1 = 0.4%; 0 to 2.6
| | | | Peritoneal cyst 1 = 0.4%; 0 to 2.6
| | | | Mesonephric cyst 1 = 0.4%; 0 to 2.6
| | | | Dermoid/cystic teratoma 35 = 14.3%; 10.6 to 19.5
| | | | Serous cystadenoma 19 = 7.8%; 5.1 to 12
| | | | Cystadenofibroma 13 = 5.3%; 3.1 to 0.1
| | | | Mucinous cystadenoma 7 = 2.9%; 1.3 to 6
| | | | Cystadenoma (unspecified) 3 = 1.2%; 0.3 to 3.8
| | | | Fibroma 2 = 0.8%; 0.05 to 3.2
| | | | Fibrothecoma 1 = 0.4%; 0 to 2.6
| | | | Seromucinous 1 = 0.4%; 0 to 2.6
| | | | Other 4 = 1.6%; 0.5 to 4.4
van Nagell Jr., DePriest, Reedy, et al., 2000 | Geographical location: | Age: | Symptomatic (n [%]): | Benign: 155/14,469 (1.1%; 95% CI, 0.9 to 1.2) | Quality assessment:
#2730 | Kentucky | Mean (SD): 54.7 (10.7) | 0 | 78 (0.5%; 0.4 to 0.7) serous cystadenomas | Size of population from which sample drawn: + (screening study)
| Dates: | Range: 25–92 | Detected by exam (n [%]): | 25 (0.2%; 0.1 to 0.3) endometriomas | Number of cases: + (large screening study with narrow CIs)
| 1987-1999 | Menopausal status (n [%]): | 3/17 cancers were palpated on exam but not detected on exam | 10 (0.07%; 0.04 to 0.1) mucinuos cystadenomas | Patient selection: - (most with family history)
| Size of population: | All ≥ 50 or ≥ 25 with family history | Detected by imaging (n [%]): | 11 (0.08%; 0.04 to 0.1) cystic teratomas | Application of reference standard: + (all with abnormal TVUS had biopsy)
| 17 cancers/14,469 | Race/ethnicity (n [%]): | 100% had TVUS | 13 (0.09%; 0.05 to 0.2) fibroma/thecoma
| (actually 3 were borderline) | NR | Combination (n [%]): | 4 (0.03%; 0.01 to 0.07) leiomyoma
| Screening study (most had positive family history; 180 had a biopsy) | Risk factors (n [%]): | NR | 14 (0.1%; 0.06 to 0.2) hydrosaplinx/paratubal cyst
| | Family history of: | Additional data used for diagnosis: | Borderline (LMP): 3/14,469 (0.02%; 95% CI, 0 to 0.06)
| | Ovarian cancer: 23% | NR | All 3 serous low malignant potential
| | Breast cancer: 34% | | Malignant: 14/14469 (0.1%; 95% CI, 0.06 to 0.2)
| | Colon cancer: 23% | | 1 (0.01%; 0 to 0.04) serous cystadenocarcinoma
| | | | 1 (0.01%; 0 to 0.04) mucinous cystadenocarcinoma
| | | | 3 (0.02%; 0 to 0.06) endometroid carcinoma
| | | | 6 (0.04%; 0.02 to 0.09) undifferentiated adenocarcinoma
| | | | 3 (0.02%; 0 to 0.06) granulosa cell carcinoma
Vasilev, Schlaerth, Campeau, et al., 1988 | Geographical location: | Age: | Symptomatic (n [%]): | Malignant: 15/182 = 8.2%; 95% CI, 5.1 to 13.4 | Comments:
#6770 | Los Angeles, CA | NR | NR | Serous cystadenocarcinoma 4 = 2.2%; 0.7 to 5.8 | —8 of 10 masses in women over 50 were malignant
| Dates: | Menopausal status (n [%]): | Detected by exam (n [%]): | Mucinous cystadenocarcinoma 2 = 1.1%; 0.1 to 4.3 | —Selection criteria for inclusion in series not included
| Apr 1984-Feb 1986 | NR | NR | Endometrioid carcinoma 1 = 0.5%; 0 to 3.4 | Quality assessment:
| Size of population: | Race/ethnicity (n [%]): | Detected by imaging (n [%]): | Leiomyosarcoma1 = 0.5%; 0 to 3.4 | Size of population from which sample drawn: -
| 182 non-consecutive patients with pelvic mass | NR | NR | Gastric Krukenberg tumor 1 = 0.5%; 0 to 3.4 | Number of cases: -
| Other | Risk factors (n [%]): | Combination (n [%]): | Hypernephroma 1 = 0.5%; 0 to 3.4 | Patient selection: - (all had mass)
| Non-consecutive series of patients scheduled for surgery for adnexal mass | NR | NR | Lymphoma 1 = 0.5%; 0 to 3.4 | Application of reference standard: - (not all had biopsy)
| | | Additional data used for diagnosis: | Melanoma 1 = 0.5%; 0 to 3.4
| | | NR | Uterine leiomyosarcoma 3 = 1.6%; 0.4 to 5
| | | | Borderline tumors 3/182 = 1.6%; 95% CI, 0.4 to 5
| | | | Serous low malignant potential 1 = 0.5%; 0 to 3.4
| | | | Mucinous low malignant potential 2 = 1.1%; 0.1 to 4.3
| | | | Benign: 164/182 = 90.1%; 95 % CI, 85.9 to 94.5
| | | | Adhesions complex 2 = 1.1%; 0.1 to 4.3
| | | | Paratubal cysts 6 = 3.3%; 1.4 to 7.3
| | | | Ectopic pregnancy 2 = 1.1%; 0.1 to 4.3
| | | | Acute salpingitis 12 = 6.6%; 3.8 to 11.4
| | | | Chronic salpingitis 3 = 1.6%; 0.4 to 5
| | | | Serous cystadenoma 9 = 4.9%; 2.6 to 9.4
| | | | Mucinous cystadenoma 4 = 2.2%; 0.7 to 5.8
| | | | Benign cystic teratoma 13 = 7.1%; 4.2 to 12.1
| | | | Fibroma 2 = 1.1%; 0.1 to 4.3
| | | | Brenner tumor 1 = 0.5%; 0 to 3.4
| | | | Endometrioma 5 = 2.7%; 1.1 to 6.5
| | | | Simple ovarian cyst 2 = 1.1%; 0.1 to 4.3
| | | | Leiomyoma 71 = 39%; 32.6 to 46.7
| | | | adenomyosis 9 = 4.9%; 2.6 to 9.4
| | | | Leiomyomas with endometriosis 2 = 1.1%; 0.1 to 4.3
| | | | Leiomyomas with adenomyosis 8 = 4.4%; 2.2 to 8.7
| | | | Leiomyomas with chronic salpingitis 5 = 2.7%; 1.1 to 6.5
| | | | Leiomyomas with endometriosis and adenomyosis 1 = 0.5%; 0 to 3.4
| | | | Leiomyomas with Brenner tumor and mucinous cystadenoma 1 = 0.5%; 0 to 3.4
| | | | Leiomyomas with serous cystadenoma 1 = 0.5%; 0 to 3.4
| | | | Leiomyomas with adenomyosis and chronic salpingitis 2 = 1.1%; 0.1 to 4.3
| | | | Leiomyomas with endometriosis and chronic salpingitis 1 = 0.5%; 0 to 3.4
| | | | Leiomyomas and salpingitis and paratubal cyst 1 = 0.5%; 0 to 3.4
| | | | Cystadenofibroma and Leiomyoma and endometriosis 1 = 0.5%; 0 to 3.4

Evidence Table 2. Question 2: What are the sensitivity, specificity, and reliability of the bimanual pelvic examination?

Study | Study Design | Patients | Clinical Presentation | Clinical Setting of Exam | Results | | | | Comments/Quality Scoring
Adonakis, Para-skevaidis, Tsiga, et al., 1996 | Geographical location: Greece | Age: | Symptomatic (n [%]): | Screening study | 1) Benign vs. malignant: | | | | Comments:
#810 | Dates: Mar 1991-Jun 1993 | Mean (SD): 58.1 (6.9) | 0 (0%) | | | Dis+ | Dis- | Tot | —1 tumor LMP grouped in with 2 other malignancies
| Size of population: | Range: 45–80 | Detected by exam (n [%]): | | T+ | 2 | 57 | 59 | —“Ambiguous” BME was classed as Test -, although all patients with ambiguous BME had TVUS to further evaluate
| 2000 | Menopausal status (n [%]): | 50 (3%) positive exam | | T- | 1 | 1940 | 1941 | —Borderline tumors considered Dis+
| Screening study | Pre: 405 (20%) | 115 (6%) “ambiguous” exam | | Tot | 3 | 1997 | 2000 | Quality assessment:
| Reference standard: | Peri: 293 (15%) | Detected by imaging (n [%]): | | | | Lower | Upper | Reference standard: + (followup with CA-125 at 12 months reasonable for screening study)
| US if BME abnormal or ambiguous; surgery if US positive; 12-month CA-125 if negative | Post: 1302 (65%) | NR | | | Value | 95% CI | 95% CI | Verification bias: + (all test negatives had 12-month CA-125)
| Reference standard applied to all test negatives?: Yes | Race/ethnicity (n [%]): | Combination (n [%]): | | Se | 66.7% | 13.3% | 100.0% | Test reliability/variability: -
| Test reliability established?: No; performed by 3 gynecological oncologists | NR | NR | | Sp | 97.1% | 96.4% | 97.9% | Sample size: +
| Statistical tests used: | Risk factors (n [%]): | Additional data used for diagnosis: | | PPV | 3.4% | 0.0% | 8.0% | Statistical tests: +
| Se, Sp | NR | Women with elevated CA-125 or and abnormal or ambiguous BME were recalled for TVUS. Only women with +TVUS were referred for further management | | NPV | 99.9% | 99.8% | 100.0% | Blinding: +
| Blinding: Yes | Inclusion criteria: | | | | | | | Definition of +/- on screening test: - (“palpable” not precise)
| Definition of positive and negative on screening test: | Women > 45, no evidence of adnexal pathology, agreed to participate
| Positive exam: palpable adnexal mass | Exclusion criteria:
| Ambiguous: origin of mass unclear or inadequate exam | History of ovarian cancer or any other malignancy, history of bilateral oophorectomy, ascites
Andolf, Jorgensen, and Astedt, 1990 | Geographical location: Sweden | Age: | Symptomatic (n [%]): | One gynecologist clinical examiner, and then a midwife did the US | 1) Abnormal vs. normal US: | | | | Comments:
#1200 | Dates: Oct 1984-Jul 1987 | Range: 40–70 | 419 (52.3%) | | | Dis+ | Dis- | Tot | —US by midwife and not a radiologist; only 30 abnormal scans went on to surgery
| Size of population: | Menopausal status (n [%]): | Detected by exam (n [%]): | | T+ | 55 | 51 | 106 | —2 endometrial carcinomas and 1 borderline ovarian tumor
| 801 | NR | NR | | T- | 108 | 587 | 695 | Quality assessment:
| Screening study | Race/ethnicity (n [%]): | Detected by imaging (n [%]): | | Tot | 163 | 638 | 801 | Reference standard: - (all had US and not all had biopsy)
| For women at high risk for ovarian cancer | NR | NR | | | | Lower | Upper | Verification bias: -
| Reference standard: | Risk factors (n [%]): Family history: 190 (23.7%) | Combination (n [%]): | | | Value | 95% CI | 95% CI | Test reliability/variability: -
| All had US and some had biopsies | Inclusion criteria: | NR | | Se | 33.7% | 26.5% | 41.0% | Sample size: - (no ovarian cancer)
| Reference standard applied to all test negatives?: No | Women older than 40 with either abdominal pain, nulliparity, family history of breast, ovarian, or endometrial cancer, or previous history of cancer | Additional data used for diagnosis: | | Sp | 92.0% | 89.9% | 94.1% | Statistical tests: -
| Test reliability established?: No | Exclusion criteria: | NR | | PPV | 51.9% | 42.4% | 61.4% | Blinding: - (not stated)
| Statistical tests used: | NR | | | NPV | 84.5% | 81.8% | 87.2% | Definition of +/- on screening test: -
| None
| Blinding: NR
| Definition of positive and negative on screening test:
| NR
Balbi, Musone, Menditto, et al., 2001 | Geographical location: Naples, Italy | Age: | Symptomatic (n [%]): | Women with pelvic mass prior to surgery. Physical exam by standard protocol. Examiner was asked to predict benign or malignant. | 1) Benign vs. malignant: | | | | Comments:
#2320 | Dates: Jan 1996-Mar 2000 | Range: 40–80 | NR | | | Dis+ | Dis- | Tot | —20 patients excluded for reasons that seem to indicate there wasn't blinding
| Size of population: | Menopausal status (n [%]): | Detected by exam (n [%]): | | T+ | 20 | 13 | 33 | —Vague definition of PE
| 92 | NR | NR | | T- | 2 | 37 | 39 | —Although RI measured, not included in definition of +US
| Case series | Race/ethnicity (n [%]): | Detected by imaging (n [%]): | | Tot | 22 | 50 | 72 | Quality assessment:
| Reference standard: | NR | NR | | | | Lower | Upper | Reference standard: +
| Histopathological diagnosis | Risk factors (n [%]): | Combination (n [%]): | | | Value | 95% CI | 95% CI | Verification bias: - (“clearly benign” excluded)
| Reference standard applied to all test negatives?: No - 18 women with “clearly benign” masses not verified; 2 patients with “clearly malignant” disease (metastases) also excluded | NR | NR | | Se | 90.0% | 77.5% | 100.0% | Test reliability/variability: -
| Test reliability established?: | Inclusion criteria: | Additional data used for diagnosis: | | Sp | 74.0% | 61.8% | 86.2% | Sample size: -
| Not for PE or CA-72–4 | “Women with a pelvic mass originating in the ovary” | NR | | PPV | 60.6% | 43.9% | 77.3% | Statistical tests: +
| Uncertain for US and RI | Exclusion criteria: | | | NPV | 94.9% | 87.9% | 100.0% | Blinding: -
| Yes for CA-125 | NR | | | | | | | Definition of +/- on screening test: - (definition of “clinical impression” not provided)
| Statistical tests used:
| Se, Sp, multivariate logistic analysis
| Blinding: NR
| Definition of positive and negative on screening test:
| PE: “malignant clinical impression”
Buckshee, Temsu, Bhatla, et al., 1998 | Geographical location: India | Age: | Symptomatic (n [%]): | One gynecologist clinical examiner | 1) Malignant vs. benign: | | | | Quality assessment:
#710 | Dates: May 1995-Apr 1997 | Range: 20 to > 50 | NR | | | Dis+ | Dis- | Tot | Reference standard: + (all had biopsy)
| Size of population: | Menopausal status (n [%]): | Detected by exam (n [%]): | | T+ | 7 | 3 | 10 | Verification bias: +
| 34 non-consecutive women with 36 tumors | Pre (< 45): NR | 10 (2.8%) | | T- | 2 | 24 | 26 | Test reliability/variability: -
| Other: | Peri (45–55): NR | Detected by imaging (n [%]): | | Tot | 9 | 27 | 36 | Sample size: - (small study)
| Women scheduled for surgery for adnexal mass | Post (> 55): 5 > 50 | NR | | | | Lower | Upper | Statistical tests: +
| Reference standard: | Race/ethnicity (n [%]): | Combination (n [%]): | | | Value | 95% CI | 95% CI | Blinding: + (yes)
| Biopsy | Indian | NR | | Se | 77.8% | 50.6% | 100.0% | Definition of +/- on screening test: - (not very specific; essentially a clinical impression of benign vs. malignant)
| Reference standard applied to all test negatives?: Yes | Risk factors (n [%]): | Additional data used for diagnosis: | | Sp | 88.9% | 77.0% | 100.0%
| Test reliability established?: No | Family history: 1 (3%) | NR | | PPV | 70.0% | 41.6% | 98.4%
| Statistical tests used: | Inclusion criteria: | | | NPV | 92.3% | 82.1% | 100.0%
| McNemar test | Scheduled for surgery
| Blinding: Yes | Exclusion criteria:
| Definition of positive and negative on screening test: | Known cancer and with evidence of extensive/metastatic disease on US or CT scan
| Yes
| Clinical diagnosis- benign vs. malignant
Dowd, Quinn, Rome, and Koh, 199 | Geographical location: Melbourne, Australia | Age: | Symptomatic (n [%]): | Not described; presumably, in outpatient setting | 1) Benign vs. malignant - all patients: | | | | Comments:
#4680 | Dates: 1978-1989 | Mean: 47 | NR | | | Dis+ | Dis- | Tot | —Examiners not blinded to history, possibly other findings
| Size of population: | Range: 15–89 | Detected by exam (n [%]): | | T+ | 56 | 15 | 71 | —High prevalence of malignancy
| 264 (n = 225 with definite clinical impression) | Menopausal status (n [%]): | NR | | T- | 54 | 100 | 154 | —History not provided; unclear how many subjects were symptomatic
| Case series | Pre (< 45): 78 (61%) | Detected by imaging (n [%]): | | Tot | 110 | 115 | 225 | Quality assessment:
| Reference standard: | Peri (45–55): | NR | | | | Lower | Upper | Reference standard: +
| Pathology | Post (> 55): 50 (39%) | Combination (n [%]): | | | Value | 95% CI | 95% CI | Verification bias: -
| Reference standard applied to all test negatives?: Yes | Race/ethnicity (n [%]): | NR | | Se | 51.0% | 41.7% | 60.3% | Test reliability/variability: -
| Test reliability established?: Not referenced or measured | NR | Additional data used for diagnosis: | | Sp | 87.0% | 80.8% | 93.2% | Sample size: + (but confidence intervals not given)
| Statistical tests used: | Risk factors (n [%]): | NR | | PPV | 79.0% | 69.5% | 88.5% | Statistical tests: +
| Se, Sp, NPV, PPV | NR | | | NPV | 65.0% | 57.5% | 72.5% | Blinding: -
| Blinding: No | Inclusion criteria: | | | 2) Other: | | | | Definition of +/- on screening test: - (definitions not explicit)
| Definition of positive and negative on screening test: | Suspected pelvic mass, CA-125 level available | | | Values also reported by menopausal status, but insufficient data to construct 2×2 table:
| “Mass described as ‘hard, irregular, fixed, attached to other structures’, or associated with ascites, or a specific statement from a consultant gynaecologist of the suspected malignant nature of the mass” | Exclusion criteria: | | | Premenopausal:
| | Screening, inadequate documentation of clinical findings of pathology | | | Sensitivity 31%, specificity 95%, PPV 76%, NPV 75%
| | | | | Postmenopausal:
| | | | | Sensitivity 59%, specificity 75%, PPV 79%, NPV 54%
Finkler, Benacerraf, Lavin, et al., 1988 | Geographical location: Boston, MA | Age: | Symptomatic (n [%]): | One gynecologist examiner who gave his/her verbal clinical impression before surgery | 1) Total study - clinical impression is test, and malignant (yes/no) is disease state: | | | | Comments:
#1230 | Dates: Nov 1986-Apr 1987 | Mean: 45.2 | NR | | | Dis+ | Dis- | Tot | —Definition of a positive physical examination is the “impression of clinical exam” that includes history
| Size of population: | Range: 17–84 | Detected by exam (n [%]): | | T+ | 16 | 6 | 22 | Quality assessment:
| 106 | Menopausal status (n [%]): | NR | | T- | 21 | 59 | 80 | Reference standard: + (all had biopsy)
| Other: | | Detected by imaging (n [%]): | | Tot | 37 | 65 | 102 | Verification bias: -
| Consecutive patients with adnexal mass scheduled for surgery | Pre (< 45): 74 (69.8%) | NR | | | | Lower | Upper | Test reliability/variability: -
| Reference standard: | Post (> 55): 32 (30.2%) | Combination (n [%]): | | | Value | 95% CI | 95% CI | Sample size: - (small study)
| Biopsy | Race/ethnicity (n [%]): | NR | | Se | 43.2% | 27.3% | 59.2% | Statistical tests: -
| Reference standard applied to all test negatives?: Yes | NR | Additional data used for diagnosis: | | Sp | 90.8% | 83.7% | 97.8% | Blinding: - (not stated)
| Test reliability established?: No | Risk factors (n [%]): | NR | | PPV | 72.7% | 54.1% | 91.3% | Definition of +/- on screening test: - (“impression of clinical exam” that includes history)
| Statistical tests used: | NR | | | NPV | 73.8% | 64.1% | 83.4%
| Fisher's exact test | Inclusion criteria: | | | 2) Premenopausal group:
| Blinding: NR | Adnexal mass scheduled for surgery | | | | Dis+ | Dis- | Tot
| Definition of positive and negative on screening test: | Exclusion criteria: | | | T+ | 3 | 4 | 7
| Clinicians asked to judge the clinical appearance of the mass based on history and physical exam combined | US unavailable or uninterpretable; pregnancy; known cancer | | | T- | 15 | 48 | 63
| | | | | Tot | 18 | 52 | 70
| | | | | | | Lower | Upper
| | | | | | Value | 95% CI | 95% CI
| | | | | Se | 16.7% | 0.0% | 33.9%
| | | | | Sp | 92.3% | 85.1% | 99.6%
| | | | | PPV | 42.9% | 6.2% | 79.5%
| | | | | NPV | 76.2% | 65.7% | 86.7%
| | | | | 3) Postmenopausal group:
| | | | | | Dis+ | Dis- | Tot
| | | | | T+ | 13 | 2 | 15
| | | | | T- | 6 | 11 | 17
| | | | | Tot | 19 | 13 | 32
| | | | | | | Lower | Upper
| | | | | | Value | 95% CI | 95% CI
| | | | | Se | 68.4% | 47.5% | 89.3%
| | | | | Sp | 84.6% | 65.0% | 100.0%
| | | | | PPV | 86.7% | 69.5% | 100.0%
| | | | | NPV | 64.7% | 42.0% | 87.4%
Grover and Quinn, 1995 | Geographical location: Melbourne, Australia | Age: | Symptomatic (n [%]): | Single examiner | 1) All women: | | | | Comments:
#830 | Dates: NR | Mean: 51 | 0 (0%) | | | Dis+ | Dis- | Tot | —Single examiner; interobserver variability not an issue
| Size of population: | Range: 25–92 | Detected by exam (n [%]): | | T+ | 0 | 40 | 40 | —83% followup at 1 year
| 2623 | Menopausal status (n [%]): | NR | | T- | 1 | 2582 | 2583 | —1 malignancy in patient with normal exam, US, elevated CA-125; menopausal status not reported
| Screening study | Pre (< 45): 1121 (43%) | Detected by imaging (n [%]): | | Tot | 1 | 2622 | 2623 | —Prevalence of abnormal adnexae 1.8% in pre-, 1% in peri-, and 1.4% in postmenopausal women
| Healthy volunteers | Peri (45–55): 384 (15%) | NR | | | | Lower | Upper | —Normal US in 37.5% of post-, 50% pre- and perimenopausal women
| Reference standard: | Post (> 55): 1118 (42%) | Combination (n [%]): | | | Value | 95% CI | 95% CI | —Benign ovarian disease in 20% pre-, 25% peri-, 25% postmenopausal women
| US if mass or elevated CA-125 | Race/ethnicity (n [%]): | NR | | Se | 0.0% | 0.0% | 100.0% | Quality assessment:
| Surgery or 12-month followup questionnaire | NR | Additional data used for diagnosis: | | Sp | 98.5% | 98.0% | 98.9% | Reference standard: - (not all got a biopsy)
| Reference standard applied to all test negatives?: Yes - | Risk factors (n [%]): | NR | | PPV | 0.0% | 0.0% | 7.5% | Verification bias: -
| 12-month followup questionnaire for all | NR | | | NPV | 100.0% | 99.9% | 100.0% | Test reliability/variability: +
| Test reliability established?: No; single examiner | Inclusion criteria: | | | | | | | Sample size: +
| Statistical tests used: | Asymptomatic, recruited (not clear how) | | | Unable to calculate by menopausal status. | | | | Statistical tests: -
| Chi-square | Exclusion criteria: | | | | | | | Blinding: - (not stated)
| Blinding: No | NR | | | | | | | Definition of +/- on screening test: - (subjective)
| Definition of positive and negative on screening test:
| Premenopausal: “larger than normal”
| Postmenopausal: palpable
Jacobs, Stabile, Bridges, et al., 1988 | Geographical location: London, UK | Age: | Symptomatic (n [%]): | One clinical examiner | 1) Abnormal US as gold standard: | | | | Comments:
#6830 | Dates: Patients recruited over a 6-month period; published 1988 | Mean: 54 | NR | | | Dis+ | Dis- | Tot | —“Palpable pelvic mass of any size that could be clinically distinguished as being separate from the uterus and GI tract”
| Size of population: | Range: 45–83 | Detected by exam (n [%]): | | T+ | 11 | 17 | 28 | Quality assessment:
| 1010 women | Menopausal status (n [%]): | NR | | T- | 2 | 980 | 982 | Reference standard: + (biopsy and/or 12-month followup)
| Screening study | Post (> 55): 1010 (100%) | Detected by imaging (n [%]): | | Tot | 13 | 997 | 1010 | Verification bias:
| Reference standard: | Race/ethnicity (n [%]): | NR | | | | Lower | Upper | Test reliability/variability:
| Biopsy or 12-month followup | NR | Combination (n [%]): | | | Value | 95% CI | 95% CI | Sample size: - (one cancer)
| Reference standard applied to all test negatives?: All had followup, and a few had biopsy | Risk factors (n [%]): | NR | | Se | 84.6% | 65.0% | 100.0% | Statistical tests: +
| Test reliability established?: No | 18 (1.8%) had history of breast cancer | Additional data used for diagnosis: | | Sp | 98.3% | 97.5% | 99.1% | Blinding: - (not stated)
| Statistical tests used: | Inclusion criteria: | NR | | PPV | 39.3% | 21.2% | 57.4% | Definition of +/- on screening test: - (palpable pelvic mass of any size)
| Chi-square | Age over 45 and postmenopausal | | | NPV | 99.8% | 99.5% | 100.0%
| Blinding: NR | Exclusion criteria: | | | 2) Cancer yes/no:
| Definition of positive and negative on screening test: | History of ovarian cancer or undergoing treatment for other cancer; history of bilateral oophorectomy | | | | Dis+ | Dis- | Tot
| “Palpable pelvic mass of any size that could be clinically distinguished as being separate from the uterus and GI tract” | | | | T+ | 1 | 27 | 28
| | | | | T- | 0 | 982 | 982
| | | | | Tot | 1 | 1009 | 1010
| | | | | | | Lower | Upper
| | | | | | Value | 95% CI | 95% CI
| | | | | Se | 100.0% | 0.0% | 100.0%
| | | | | Sp | 97.3% | 96.3% | 98.3%
| | | | | PPV | 3.6% | 0.0% | 10.4%
| | | | | NPV | 100.0% | 99.7% | 100.0%
Ong, Duffy, and Murphy, 1996 | Geographical location: Dublin, Ireland | Age: | Symptomatic (n [%]): | One gynecologist examiner | 1) Ovarian mass yes/no by US: | | | | Comments:
#780 | Dates: Jan 1993-Feb 1995 | NR | NR | | | Dis+ | Dis- | Tot | —Separates the Se/Sp for detection of uterine mass and ovarian mass
| Size of population: | Menopausal status (n [%]): | Detected by exam (n [%]): | | T+ | 46 | 9 | 55 | Quality assessment:
| 86 undergoing laparotomy | NR | NR | | T- | 18 | 13 | 31 | Reference standard: + (biopsy)
| Other: | Race/ethnicity (n [%]): | Detected by imaging (n [%]): | | Tot | 64 | 22 | 86 | Verification bias: -
| Patients undergoing surgery | NR | NR | | | | Lower | Upper | Test reliability/variability: -
| Reference standard: | Risk factors (n [%]): | Combination (n [%]): | | | Value | 95% CI | 95% CI | Sample size: -
| Biopsy | NR | NR | | Se | 71.9% | 60.9% | 82.9% | Statistical tests: +
| Reference standard applied to all test negatives?: Yes | Inclusion criteria: | Additional data used for diagnosis: | | Sp | 59.1% | 38.5% | 79.6% | Blinding: - (not stated)
| Test reliability established?: No | NR | NR | | PPV | 83.6% | 73.9% | 93.4% | Definition of +/- on screening test: - (not stated)
| Statistical tests used: | Exclusion criteria: | | | NPV | 41.9% | 24.6% | 59.3%
| Se, Sp | Pregnant; missing information or no US | | | 2) Uterine mass:
| Blinding: NR | | | | | Dis+ | Dis- | Tot
| Definition of positive and negative on screening test: | | | | T+ | 14 | 5 | 19
| NR (retrospective chart review) | | | | T- | 4 | 63 | 67
| | | | | Tot | 18 | 68 | 86
| | | | | | | Lower | Upper
| | | | | | Value | 95% CI | 95% CI
| | | | | Se | 77.8% | 58.6% | 97.0%
| | | | | Sp | 92.6% | 86.4% | 98.9%
| | | | | PPV | 73.7% | 53.9% | 93.5%
| | | | | NPV | 94.0% | 88.4% | 99.7%
Padilla, Radosevich, and Milad, 2000 | Geographical location: Chicago, IL | Age: | Symptomatic (n [%]): | Exam under anesthesia by attendings, residents, and medical students | 1) Left adnexa by attending: | | | | Comments:
#460 | Dates: Mar 1997-Mar 1998 | Mean: 39.3 | NR | | | Dis+ | Dis- | Tot | —Left and right adnexa were considered separately - abstractor not sure 2×2 tables are correct - don't tell us number of Dis -
| Size of population: | Menopausal status (n [%]): | Detected by exam (n [%]): | | T+ | 16 | 9 | 25 | Quality assessment:
| 82 adnexal masses in 140 patients undergoing surgery | Pre (< 45): NR | NR | | T- | 33 | 69 | 102 | Reference standard: + (all had surgery)
| Other: | Peri (45–55): NR | Detected by imaging (n [%]): | | Tot | 49 | 78 | 127 | Verification bias: -
| Women undergoing laparotomy | Post (> 55): 14 (10%) | NR | | | | Lower | Upper | Test reliability/variability: +
| Reference standard: | Race/ethnicity (n [%]): | Combination (n [%]): | | | Value | 95% CI | 95% CI | Sample size: - (small study)
| Surgery | NR | NR | | Se | 32.7% | 19.5% | 45.8% | Statistical tests: +
| Reference standard applied to all test negatives?: Yes | Risk factors (n [%]): | Additional data used for diagnosis: | | Sp | 88.5% | 81.4% | 95.6% | Blinding: - (not stated)
| Test reliability established?: No | NR | NR | | PPV | 64.0% | 45.2% | 82.8% | Definition of +/- on screening test: + (greater than 5 cm adnexa)
| Statistical tests used: | Inclusion criteria: | | | NPV | 67.6% | 58.6% | 76.7%
| Youden j statistic, Se, Sp | Many indications for surgery, including sterilization | | | 2) Right adnexa by attending:
| Blinding: NR | Exclusion criteria: | | | | Dis+ | Dis- | Tot
| Definition of positive and negative on screening test: Adnexal mass defined as approx. 5 cm or more in greatest diameter | NR | | | T+ | 7 | 20 | 27
| | | | | T- | 26 | 74 | 100
| | | | | Tot | 33 | 94 | 127
| | | | | | | Lower | Upper
| | | | | | Value | 95% CI | 95% CI
| | | | | Se | 21.2% | 7.3% | 35.2%
| | | | | Sp | 78.7% | 70.4% | 87.0%
| | | | | PPV | 25.9% | 9.4% | 42.5%
| | | | | NPV | 74.0% | 65.4% | 82.6%
| | | | | 3) Left adnexa by resident:
| | | | | | Dis+ | Dis- | Tot
| | | | | T+ | 18 | 8 | 26
| | | | | T- | 31 | 81 | 112
| | | | | Tot | 49 | 89 | 138
| | | | | | | Lower | Upper
| | | | | | Value | 95% CI | 95% CI
| | | | | Se | 36.7% | 23.2% | 50.2%
| | | | | Sp | 91.0% | 85.1% | 97.0%
| | | | | PPV | 69.2% | 51.5% | 87.0%
| | | | | NPV | 72.3% | 64.0% | 80.6%
| | | | | 4) Right adnexa by resident:
| | | | | | Dis+ | Dis- | Tot
| | | | | T+ | 9 | 14 | 23
| | | | | T- | 24 | 91 | 115
| | | | | Tot | 33 | 105 | 138
| | | | | | | Lower | Upper
| | | | | | Value | 95% CI | 95% CI
| | | | | Se | 27.3% | 12.1% | 42.5%
| | | | | Sp | 86.7% | 80.2% | 93.2%
| | | | | PPV | 39.1% | 19.2% | 59.1%
| | | | | NPV | 79.1% | 71.7% | 86.6%
| | | | | 5) Left adnexa by student:
| | | | | | Dis+ | Dis- | Tot
| | | | | T+ | 11 | 6 | 17
| | | | | T- | 38 | 42 | 80
| | | | | Tot | 49 | 48 | 97
| | | | | | | Lower | Upper
| | | | | | Value | 95% CI | 95% CI
| | | | | Se | 22.4% | 10.8% | 34.1%
| | | | | Sp | 87.5% | 78.1% | 96.9%
| | | | | PPV | 64.7% | 42.0% | 87.4%
| | | | | NPV | 52.5% | 41.6% | 63.4%
| | | | | 6) Right adnexa by student:
| | | | | | Dis+ | Dis- | Tot
| | | | | T+ | 5 | 5 | 10
| | | | | T- | 28 | 59 | 87
| | | | | Tot | 33 | 64 | 97
| | | | | | | Lower | Upper
| | | | | | Value | 95% CI | 95% CI
| | | | | Se | 15.2% | 2.9% | 27.4%
| | | | | Sp | 92.2% | 85.6% | 98.8%
| | | | | PPV | 50.0% | 19.0% | 81.0%
| | | | | NPV | 67.8% | 58.0% | 77.6%
Padilla, Radosevich, and Milad, 2005 | Geographical location: Chicago, IL | Age: | Symptomatic (n [%]): | Examination under anesthesia in dorsal lithotomy position. | 1) Total all examiners - detection of adnexal mass: | | | | Comments:
#7280 | Dates: Mar 1997-Mar 1998 | Mean: (SD) 37.7 (0.93) | NR | Bladder drained. | | Dis+ | Dis- | Tot | —Final diagnoses not presented
| Size of population: | Menopausal status (n [%]): | Detected by exam (n [%]): | Examiners reported adnexal size, presence of mass, uterine position, size, contour, mobility. | T+ | 14 | 10 | 24 | —Reasons for surgery not systematically presented
| 84 | Pre (< 45): 95.2% | NR | Examiners divided into board-certified OB/GYN (n = 52), OB/GYN residents (n = 30), 3^rd^ and 4^th^ year med students (n = 40). | T- | 76 | 152 | 228 | Quality assessment:
| Screening study Registry Other | Peri (45–55): NR | Detected by imaging (n [%]): | | Tot | 90 | 162 | 252 | Reference standard: +
| Series of women undergoing gyn surgery | Post (> 55): NR | NR | | | | Lower | Upper | Verification bias: +
| Reference standard: | Race/ethnicity (n [%]): | Combination (n [%]): | | | Value | 95% CI | 95% CI | Test reliability/variability: - (reliability not referenced or discussed)
| Surgery | NR | NR | | Se | 15.6% | 8.1% | 23.0% | Sample size: + (but no a priori sample size presented)
| Reference standard applied to all test negatives?: Yes | Risk factors (n [%]): | Additional data used for diagnosis: | | Sp | 93.8% | 90.1% | 97.5% | Statistical tests: +
| Test reliability established?: Not discussed | NR | NR | | PPV | 58.3 | 38.6% | 78.1% | Blinding: +
| Statistical tests used: | Other: | | | NPV | 66.7% | 60.5% | 72.8% | Definition of +/- on screening test: +
| Se, Sp, NPV, PPV, Youden's J statistic, likelihood ratio, logistic regression | Mean BMI 26.5 18% BMI > 30 | | | (calculated by summing results for attending, residents, and students)
| Blinding: Examiners blinded to symptoms, indications | Inclusion criteria: | | | 2) Attending - detection of adnexal mass:
| Definition of positive and negative on screening test: | Women presenting for laparoscopy or laparotomy; range of indications: diagnostic laparoscopy, sterilization, suspected malignancy, etc. | | | | Dis+ | Dis- | Tot
| Positive: Adnexal mass ≥ 5 cm | Exclusion criteria: | | | T+ | 8 | 4 | 12
| | NR | | | T- | 22 | 50 | 72
| | | | | Tot | 30 | 54 | 84
| | | | | | | Lower | Upper
| | | | | | Value | 95% CI | 95% CI
| | | | | Se | 28.0% | 11.9% | 44.1%
| | | | | Sp | 93.0% | 86.2% | 99.8%
| | | | | PPV | 66.7% | 40.0% | 93.3%
| | | | | NPV | 69.4% | 58.8% | 80.1%
| | | | | 3) Residents - detection of adnexal mass:
| | | | | | Dis+ | Dis- | Tot
| | | | | T+ | 5 | 3 | 8
| | | | | T- | 25 | 51 | 76
| | | | | Tot | 30 | 54 | 84
| | | | | | | Lower | Upper
| | | | | | Value | 95% CI | 95% CI
| | | | | Se | 16.0% | 2.9% | 29.1%
| | | | | Sp | 95.0% | 89.2% | 100.0%
| | | | | PPV | 62.5% | 29.0% | 96.0%
| | | | | NPV | 67.1% | 56.5% | 77.7%
| | | | | 4) Students - detection of adnexal mass:
| | | | | | Dis+ | Dis- | Tot
| | | | | T+ | 1 | 3 | 4
| | | | | T- | 29 | 51 | 80
| | | | | Tot | 30 | 54 | 84
| | | | | | | Lower | Upper
| | | | | | Value | 95% CI | 95% CI
| | | | | Se | 4.0% | 0.0% | 11.0%
| | | | | Sp | 95.0% | 89.2% | 100.0%
| | | | | PPV | 25.0% | 0.0% | 67.4%
| | | | | NPV | 63.8% | 53.2% | 74.3%
| | | | | 5) Other:
| | | | | Likelihood of not detecting an adnexal mass increased with less experience (OR for resident 1.13, student 1.36 compared to attending, although 95% Cls cross 1).
| | | | | Statistically significant increase in missed diagnosis of subject with BMI > 30 (OR 2.57; 95% Cl 1.36 to 4.87), and significant decrease in presence of enlarged uterus (OR 0.48; 95% Cl 0.25 to 0.93).
Roman, Muder-spach, Stein, et al., 1997 | Geographical location: Los Angeles, CA | Age: | Symptomatic (n [%]): | By staff gynecologist in clinic 1 to 4 days prior to surgery | Results not given for 26 women in whom mass was not palpable. | | | | Comments:
#6160 | Dates: Jul 1992-Mar 1994 | NR | NR | | 1) All women: | | | | —Preselected group with “suspicious masses”
| Size of population: | Menopausal status (n [%]): | Detected by exam (n [%]): | | | Dis+ | Dis- | Tot | —Results don't include 26 with nonpalpable masses; data on final diagnosis in these patients not provided
| 226 | Pre (< 45): 181 (80.1%) | NR | | T+ | 22 | 26 | 48 | —Not clear how low malignant potential tumors were classified in terms of calculation of Se/Sp
| Other | Post (> 55): 45 (19.9%) | Detected by imaging (n [%]): | | T- | 21 | 131 | 152 | Quality assessment:
| Nonconsecutive case series | Race/ethnicity (n [%]): | NR | | Tot | 43 | 157 | 200 | Reference standard: +
| Reference standard: | NR | Combination (n [%]): | | | | Lower | Upper | Verification bias: -
| Surgical/path findings | Risk factors (n [%]): | NR | | | Value | 95% CI | 95% CI | Test reliability/variability: -
| Reference standard applied to all test negatives?: Yes | NR | Additional data used for diagnosis: | | Se | 51.2% | 36.3% | 66.1% | Sample size: -
| Test reliability established?: No | Inclusion criteria: | NR | | Sp | 83.6% | 77.8% | 89.4% | Statistical tests: +
| Statistical tests used: | Suspicious mass needing surgical evaluation | | | PPV | 45.8% | 31.7% | 59.9% | Blinding: -
| Pearson, logistic regression | Exclusion criteria: | | | NPV | 86.2% | 80.7% | 91.7% | Definition of +/- on screening test: +
| Blinding: No | Emergent laparotomy, clinical or radiologic evidence of metastatic disease, U/S by gynecologist | | | 2) Premenopausal women:
| Definition of positive and negative on screening test: | | | | Sufficient data not provided to calculate 2×2 or Cls.
| Positive = fixed, irregular contour, or clinical ascites | | | | Se | 50.0%
| | | | | Sp | 83.2%
| | | | | PPV | 36.1%
| | | | | NPV | 89.9%
| | | | | 3) Postmenopausal women:
| | | | | Sufficient data not provided for 2×2 table.
| | | | | Se | 53.3%
| | | | | Sp | 85.7%
| | | | | PPV | 66.7%
| | | | | NPV | 77.4%
Schutter, Kenemans, Sohn, et al., 1994 | Geographical location: Netherlands and Germany | Age: | Symptomatic (n [%]): | One gynecologist examiner | 1) Malignant vs. benign: | | | | Quality assessment:
#940 | Dates: Nov 1990-Dec 1992 | Mean: 63 | NR | | | Dis+ | Dis- | Tot | Reference standard: + (all had biopsy)
| Size of population: | Median: 62 | Detected by exam (n [%]): | | T+ | 88 | 47 | 135 | Verification bias: -
| 228 | Range: 45–88 | 199 (87%) | | T- | 7 | 80 | 87 | Test reliability/variability: -
| Other: | Menopausal status (n [%]): | Detected by imaging (n [%]): | | Tot | 95 | 127 | 222 | Sample size: + (good size)
| Women presenting with pelvic mass | Post (> 55): 100% | 28 (12%) by US | | | | Lower | Upper | Statistical tests: +
| Reference standard: | Race/ethnicity (n [%]): | Combination (n [%]): | | | Value | 95% CI | 95% CI | Blinding: - (not stated)
| Biopsy | NR | NR | | Se | 92.6% | 87.4% | 97.9% | Definition of +/- on screening test: + (benign or malignant)
| Reference standard applied to all test negatives?: Yes | Risk factors (n [%]): | Additional data used for diagnosis: | | Sp | 63.0% | 54.6% | 71.4%
| Test reliability established?: No | NR | NR | | PPV | 65.2% | 57.1% | 73.2%
| Statistical tests used: | Inclusion criteria: | | | NPV | 92.0% | 86.2% | 97.7%
| Chi-square or Fisher's | > 45 years, postmenopausal
| Blinding: NR | Exclusion criteria:
| Definition of positive and negative on screening test: | Another cancer, indeterminate exam
| Palpable mass of any size, benign vs. malignant
Schutter, Sohn, Kristen, et al., 1998 | Geographical location: Amsterdam, Netherlands; Wurzburg and Mainz, Germany | Age: | Symptomatic (n [%]): | Not described; presumably, in outpatient setting | 1) Benign vs. malignant (borderline = benign): | | | | Comments:
#730 | Dates: NR (referenced in another paper by this group) | Mean: 63 | NR | | | Dis+ | Dis- | Tot | —Examiners not blinded
| Size of population: | Median: 61 | Detected by exam (n [%]): | | T+ | 54 | 24 | 78 | —High prevalence of disease
| 180 (155 met inclusion/exclusion criteria) | Range: 45–88 | NR | | T- | 5 | 68 | 73 | —Clinical history prior to examination not described
| Other | Menopausal status (n [%]): | Detected by imaging (n [%]): | | Tot | 59 | 92 | 151 | Quality assessment:
| Case series | Post (> 55): 180 (100%) | NR | | | | Lower | Upper | Reference standard: +
| Reference standard: | Race/ethnicity (n [%]): | Combination (n [%]): | | | Value | 95% CI | 95% CI | Verification bias: -
| Surgery/pathology | NR | NR | | Se | 91.5% | 84.4% | 98.6% | Test reliability/variability: + (discussed)
| Reference standard applied to all test negatives?: Yes | Risk factors (n [%]): | Additional data used for diagnosis: | | Sp | 73.9% | 64.9% | 82.9% | Sample size: +
| Test reliability established?: Lack of data on reliability discussed | NR | NR | | PPV | 69.2% | 59.0% | 79.5% | Statistical tests: +
| Statistical tests used: | Inclusion criteria: | | | NPV | 93.2% | 87.4% | 98.9% | Blinding: -
| Se, Sp, NPV, PPV | Not described (referenced) | | | | | | | Definition of +/- on screening test: (criteria for definition of malignancy not given)
| Blinding: NR | Exclusion criteria:
| Definition of positive and negative on screening test: | Not described (referenced)
| Abnormal: mass of any size clinically distinguishable as being separate from uterus and GI tract; examiner asked to state whether benign or malignant

Evidence Table 3. Question 3: Among women with a palpable adnexal mass on exam or a mass identified by ultrasound/imaging, what is the sensitivity/specificity of various evaluation modalities including ultrasound (transvaginal ultrasound, transabdominal ultrasound, color Doppler, 2D vs. 3D ultrasound), CT scan, MRI scan, and CA-125 levels for distinguishing benign from malignant masses?

Study | Study Design | Patients | Clinical Presentation | Results | | | | Comments/Quality Scoring
Adonakis, Para-skevaidis, Tsiga, et al., 1996 | Geographical location: | Age: | Symptomatic (n [%]): | 1) CA-125 (T+ ≥ 35 U/ml) | | | | Comments:
#810 | Greece | Mean (SD): 58.1(6.9) | 0 (0%) | | Dis+ | Dis- | Tot | —1 tumor LMP grouped in with 2 other malignancies
| Dates: Mar 1991- Jun 1993 | Range: 45–80 | Detected by exam (n [%]): | T+ | 3 | 15 | 18 | —“Ambiguous” BME was classed as Test -, although all patients with ambiguous BME had TVUS to further evaluate
| Size of population: | Menopausal status (n [%]): | 50 (3%) + exam | T- | 0 | 1982 | 1982 | —Borderline tumors considered Dis+
| 2000/2000 | Pre: 405 (20%) | 115 (6%) “ambiguous” exam | Tot | 3 | 1997 | 2000 | Quality assessment:
| Screening study | Peri: 293 (15%) | Detected by imaging (n [%]): | | | Lower | Upper | Reference standard: +; all had at least 12 months of followup.
| Reference standard: | Post: 1302 (65%) | NR | | Value | 95% CI | 95% CI | Verification bias: +; reference standard of followup applied to all
| Histopathology for selected positives; followup at 12 months for all others | Race/ethnicity (n [%]): | Combination (n [%]): | Se | 100.0% | 0.0% | 100.0% | Test reliability/variability: + CA-125, - BME
| Reference standard applied to all test negatives?: | NR | NR | Sp | 99.2% | 98.9% | 99.6% | Sample size: -; large sample size, but small number of cases makes CIs around test characteristic estimates wide, especialy for sensitivity
| 180 of the 2000 patients went onto TVUS, and only 35 these had histopathologic diagnosis; 145 verified by clinical followup of repeat exam, TVUS and/or CA-125. No reported loss to followup (although not explicitly stated). | Risk factors (n [%]): | Additional data used for diagnosis: | PPV | 16.7% | 0.0% | 33.9% | Statistical tests: +
| Test reliability established?: | NR | Women with elevated CA-125 or and abnormal or ambiguous BME were recalled for TVUS. Only women with +TVUS were referred for further management. | NPV | 100.0% | 99.8% | 100.0% | Blinding: +
| BME - No | Inclusion criteria: | | 2) PE | | | | Definition of +/- on screening test: + CA-125, - BME
| CA-125 - Yes | Women > 45, no evidence of adnexal pathology, agreed to participate | | | Dis+ | Dis- | Tot
| Statistical tests used: | Exclusion criteria: | | T+ | 2 | 57 | 59
| Se, Sp | Women with history of ovarian cancer or any other malignancy, history of bilateral oophorectomy, ascites | | T- | 1 | 1940 | 1941
| Blinding: | | | Tot | 3 | 1997 | 2000
| NR, but exams preceded surgery | | | | | Lower | Upper
| Definition of positive and negative on screening test: | | | | Value | 95% CI | 95% CI
| CA-125 ≥ 35 U/mL | | | Se | 66.7% | 13.3% | 100.0%
| BME - “palpable mass” | | | Sp | 97.1% | 96.4% | 97.9%
| | | | PPV | 3.4% | 0.0% | 8.0%
| | | | NPV | 99.9% | 99.8% | 100.0%
Alcazar and Castillo, 2005 | Geographical location: | Age: | Symptomatic (n [%]): | All results for masses not patients | | | | Comments:
#7460 | Pamplona, Spain | Mean (SD): 48.4 (16.4) | NR | 1) 2D (combined Doppler and morphology) | | | | —14 of the 60 patients included in this study were included in a previous study by the authors (Alcazar 2003, ref 17)
| Dates: Jan 2002 - Apr 2004 | Range: 17–82 | Detected by exam (n [%]): | | Dis+ | Dis- | Tot | —One person performed all scans (both 2D and 3D); however, he only interpreted the 2D scans. 3D scans interpreted by other individual blinded to 2D results.
| Size of population: | Menopausal status (n [%]): | NR | T+ | 44 | 3 | 47 | —Kappa index calculated for interobserver agreement (k = 0.90)
| 60 patients | Pre (< 45): 32 (53%) | Detected by imaging (n [%]): | T- | 1 | 21 | 22 | —No discussion of clinical pathway to diagnosis.
| 69 masses | Post (> 55): 28 (47%) | NR | Tot | 45 | 24 | 69 | —No discussion of why decision for 3D US - most likely suspicious 2D scan
| Case series | Race/ethnicity (n [%]): | Combination (n [%]): | | | Lower | Upper | —High incidence of cancer in this study
| Reference standard: | NR | NR | | Value | 95% CI | 95% CI | —Descriptive morphologic classification for 2D and doppler- no scoring system used
| Histopathology | Risk factors (n [%]): | Additional data used for diagnosis: | Se | 97.8% | 93.5% | 100.0% | —3D US - definition of positive/negative test not mentioned
| Reference standard applied to all test negatives?: | NR | NR | Sp | 87.5% | 74.3% | 100.0% | —Unclear how Doppler included in final table
| Yes | Inclusion criteria: | | PPV | 93.6% | 86.6% | 100.0% | —Unable to stratify by menopausal status
| Test reliability established?: | Women with diagnosis of adnexal mass who received treatment at institution in time frame for who got 2D and 3D US | | NPV | 95.5% | 86.8% | 100.0% | —Results reported by masses not patients
| Yes | Exclusion criteria: | | 2) 3D (combined) | | | | —LMP tumors grouped in with malignant
| Statistical tests used: | “Masses in which the echo features were highly characteristic of a given pathologic condition (such as simple cyst, cystic teratoma, or endometrioma)” | | | Dis+ | Dis- | Tot | —Numbers in text and table II don't mesh exactly (2×2 tables here from Table II data)
| Se, Sp, MCNemar, Fleiss kappa index | | | T+ | 44 | 5 | 49 | —Authors note no difference in Se and Sp between 2D and 3D p = 0.250
| Blinding: | | | T- | 1 | 19 | 20 | —Good discussion of literature on 3D
| Yes | | | Tot | 45 | 24 | 69 | —TVUS only
| Definition of positive and negative on screening test: | | | | | Lower | Upper | Quality assessment:
| 2D US - presence of at least one of the following: thick wall (> 3 mm), thick papillary projections (> 3 mm), solid areas or purely solid echogenicity = complex mass. | | | | Value | 95% CI | 95% CI | Reference standard: +
| Doppler - blood flow detected within a papillary projection, solid area, or central area of solid tumor = malignant. | | | Se | 97.8% | 93.5% | 100.0% | Verification bias: +
| 3D - not mentioned. | | | Sp | 79.2% | 63.0% | 95.4% | Test reliability/variability: -
| | | | PPV | 89.8% | 81.3% | 98.3% | Sample size: -
| | | | NPV | 95.0% | 85.4% | 100.0% | Statistical tests: +
| | | | | | | | Blinding: +
| | | | | | | | Definition of +/- on screening test: -
Alcazar, Errasti, Zornoza, et al., 1999 | Geographical location: | Age: | Symptomatic (n [%]): | 1) Color Doppler - all | | | | Comments:
#3110 | Spain | Mean (SD): 47.4 (16.1) | NR | | Dis+ | Dis- | Tot | —LMP tumors grouped in with malignant
| Dates: Jan 1995- Feb 1998 | Range: 17–79 | Detected by exam (n [%]): | T+ | 49 | 6 | 55 | —Inclusion criteria predispose to increased likelihood of cancer
| Size of population: | Menopausal status (n [%]): | NR | T- | 7 | 32 | 39 | —Pre-study history (symptomatic vs asymptomatic) not described
| 94 of 480 | Pre (< 45): 55.3% | Detected by imaging (n [%]): | Tot | 56 | 38 | 94 | Quality assessment:
| Other | Post (> 55): 44.7% | NR | | | Lower | Upper | Reference standard: +; pathology
| Retrospective case series | Race/ethnicity (n [%]): | Combination (n [%]): | | Value | 95% CI | 95% CI | Verification bias: +; all underwent surgery
| Reference standard: | NR | NR | Se | 87.5% | 78.8% | 96.2% | Test reliability/variability: +; one reader for Doppler; inter and intra assay coefficient of variation for CA-125
| Pathology | Risk factors (n [%]): | Additional data used for diagnosis: | Sp | 84.2% | 72.6% | 95.8% | Sample size: +
| Reference standard applied to all test negatives?: | NR | NR | PPV | 89.1% | 80.9% | 97.3% | Statistical tests: +
| Yes | Inclusion criteria: | | NPV | 82.1% | 70.0% | 94.1% | Blinding: -
| Test reliability established?: | Sonographically suspicious adnexal mass, “presence of at least one of the following: gross septa (> 3 mm), gross papillary projections (> 3 mm), solid wall nodules, multilocularity, irregular borders or ascitis” | | 2) CA-125 - all | | | | Definition of +/- on screening test: +
| Inter and intra assay coefficient for CA-125 reported | Transvaginal color Doppler evaluation and serum CA-125 levels determined prior to surgery | | | Dis+ | Dis- | Tot
| Statistical tests used: | Definitive histopathological diagnosis | | T+ | 47 | 12 | 59
| Kolmogorov-Smirnov | Exclusion criteria: | | T- | 9 | 26 | 35
| Student t-test | NR | | Tot | 56 | 38 | 94
| Mann-Witney U | | | | | Lower | Upper
| Chi-square | | | | Value | 95% CI | 95% CI
| McNemars Test | | | Se | 83.9% | 74.3% | 93.5%
| ROC | | | Sp | 68.4% | 53.6% | 83.2%
| Blinding: | | | PPV | 79.7% | 69.4% | 89.9%
| NR | | | NPV | 74.3% | 59.8% | 88.8%
| Definition of positive and negative on screening test: | | | 3) Doppler - Premenopausal
| Doppler | | | | Dis+ | Dis- | Tot
| Resistance index [RI=S-D] calculated for each case | | | T+ | 23 | 5 | 28
| Malignancy suspected if lowest RI ≤ 0.45 | | | T- | 3 | 21 | 24
| CA-125 level | | | Tot | 26 | 26 | 52
| CA-125 = 35 U/ml considered as suspicious for malignancy | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 88.5% | 76.2% | 100.0%
| | | | Sp | 80.8% | 65.7% | 95.9%
| | | | PPV | 82.1% | 67.9% | 96.3%
| | | | NPV | 87.5% | 74.3% | 100.0%
| | | | 4) CA-125 - Premenopausal
| | | | | Dis+ | Dis- | Tot
| | | | T+ | 22 | 8 | 30
| | | | T- | 4 | 18 | 22
| | | | Tot | 26 | 26 | 52
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 84.6% | 70.7% | 98.5%
| | | | Sp | 69.2% | 51.5% | 86.9%
| | | | PPV | 73.3% | 57.5% | 89.1%
| | | | NPV | 81.8% | 65.7% | 97.9%
| | | | 5) Doppler - Postmenopausal
| | | | | Dis+ | Dis- | Tot
| | | | T+ | 26 | 1 | 27
| | | | T- | 4 | 11 | 15
| | | | Tot | 30 | 12 | 42
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 86.7% | 74.5% | 98.9%
| | | | Sp | 91.7% | 76.1% | 100.0%
| | | | PPV | 96.3% | 89.2% | 100.0%
| | | | NPV | 73.3% | 50.9% | 95.7%
| | | | 6) CA-125 - Postmenopausal
| | | | | Dis+ | Dis- | Tot
| | | | T+ | 25 | 4 | 29
| | | | T- | 5 | 8 | 13
| | | | Tot | 30 | 12 | 42
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 83.3% | 70.0% | 96.6%
| | | | Sp | 66.7% | 40.0% | 93.4%
| | | | PPV | 86.2% | 73.6% | 98.8%
| | | | NPV | 61.5% | 35.0% | 88.0%
Alcazar, Galan, Garcia-Manero, et al., 2003 | Geographical location: | Age: | Symptomatic (n [%]): | 1) 2D US | | | | Comments:
#1990 | Spain | Mean (SD): 49.5 | NR | | Dis+ | Dis- | Tot | —Descriptive not numerical/reproducible scoring system
| Dates: Jun 2001 to Jun 2002 | Range: 23–75 | Detected by exam (n [%]): | T+ | 19 | 9 | 28 | —2×2 tables for masses not for individuals
| Size of population: | Menopausal status (n [%]): | NR | T- | 2 | 14 | 16 | —Pre-study history (symptomatic vs asymptomatic) not described
| 44 masses | Pre (< 45): 20 (49%) | Detected by imaging (n [%]): | Tot | 21 | 23 | 44 | Quality assessment:
| 41 women | Post (> 55): 21 (51%) | NR | | | Lower | Upper | Reference standard: +
| Other | Race/ethnicity (n [%]): | Combination (n [%]): | | Value | 95% CI | 95% CI | Verification bias: +
| Prospective case series | NR | NR | Se | 90.0% | 77.2% | 100.0% | Test reliability/variability: +
| Reference standard: | Risk factors (n [%]): | Additional data used for diagnosis: | Sp | 61.0% | 41.1% | 80.9% | Sample size: +; “state small numbers of patients”
| Histopathology | NR | NR | PPV | 67.9% | 50.6% | 85.2% | Statistical tests: +
| Reference standard applied to all test negatives?: | Inclusion criteria: | | NPV | 87.5% | 71.3% | 100.0% | Blinding: NR
| Yes | Women with the diagnosis of complex adnexal masses on 2D TVUS | | 2) 3D US | | | | Definition of +/- on screening test: +; stated
| Test reliability established?: | Exclusion criteria: | | | Dis+ | Dis- | Tot
| Yes using kappa | NR | | T+ | 21 | 5 | 26
| Statistical tests used: | | | T- | 0 | 18 | 18
| McNemars | | | Tot | 21 | 23 | 44
| Blinding: | | | | | Lower | Upper
| Second 3D reviewer blinded, 2D and first 2D reviewer not | | | | Value | 95% CI | 95% CI
| Definition of positive and negative on screening test: | | | Se | 100.0% | 85.7% | 100.0%
| Presence of one of the following fulfilled criteria for adnexal mass: | | | Sp | 78.0% | 61.1% | 94.9%
| A thick wall (> 3 mm) | | | PPV | 80.8% | 65.6% | 95.9%
| A thick septum (> 3 mm) | | | NPV | 100.0% | 83.3% | 100.0%
| Thick papillary projections (> 3 mm), solid areas, purely solid echogenicity
Alcazar and Lopez-Garcia, 2001 | Geographical location: | Age: | Symptomatic (n [%]): | 1) Morphology criteria of Sassone et al | | | | Comments:
#5740 | Spain | Mean (SD): 46.6 (14.1) | NR | | Dis+ | Dis- | Tot | —LMP tumors considered malignant in analysis
| University Hospital | Range: 16–81 | Detected by exam (n [%]): | T+ | 23 | 19 | 42 | —There seems to be an inconsistency between the definition of Venous Doppler; the Se/Sp reported in text and; and the Se/Sp reported in Table 3
| Dates: Jun 1998 - May 1999 | Menopausal status (n [%]): | NR | T- | 2 | 47 | 49 | —Pre-study history (symptomatic vs asymptomatic) not described
| Size of population: | Pre (< 45): 58 (63.7%) | Detected by imaging (n [%]): | Tot | 25 | 66 | 91 | —Results for 89 subjects not undergoing surgery not provided
| 180 women | Post (> 55): 33 (36.3%) | NR | | | Lower | Upper | Quality assessment:
| Other | Race/ethnicity (n [%]): | Combination (n [%]): | | Value | 95% CI | 95% CI | Reference standard: +
| Consecutive patients undergoing surgery with masses | NR | NR | Se | 92.0% | 81.4% | 100.0% | Verification bias: +
| Reference standard: | Risk factors (n [%]): | Additional data used for diagnosis: | Sp | 71.2% | 60.3% | 82.1% | Test reliability/variability: + for Sasonne and RI
| Surgery | NR | NR | PPV | 54.8% | 39.7% | 69.8% | Sample size: -
| Reference standard applied to all test negatives?: | Inclusion criteria: | | NPV | 95.9% | 90.4% | 100.0% | Statistical tests: +
| No, 180 patients evaluated by TVUS for adnexal mass; only 91 underwent surgery | Adnexal mass undergoing surgery | | 2) Arterial Doppler (RI) T+≤ 0.45 (in patients in whom arterial flow was detected) (Table 3) | | | | Blinding: +
| Test reliability established?: | Exclusion criteria: | | | Dis+ | Dis- | Tot | Definition of +/- on screening test: + morphology criteria and RI; - for arterial and venous Doppler
| Yes | NR | | T+ | 17 | 1 | 18
| Statistical tests used: | | | T- | 6 | 26 | 32
| ROC | | | Tot | 23 | 27 | 50
| Se, Sp | | | | | Lower | Upper
| McNemar test | | | | Value | 95% CI | 95% CI
| Blinding: | | | Se | 76.0% | 58.5% | 93.5%
| Surgeons blinded to US result | | | Sp | 95.5% | 87.7% | 100.0%
| Prospective study | | | PPV | 94.4% | 83.9% | 100.0%
| Definition of positive and negative on screening test: | | | NPV | 81.3% | 67.7% | 94.8%
| Sasonne's scoring system (ref 20) | | | 3) Venous Doppler; cutoff not described
| Wall thickness (1–3) | | | | Dis+ | Dis- | Tot
| Septa (1–3) | | | T+ | 12 | 1 | 13
| Inner wall structure (1–4) | | | T- | 6 | 13 | 19
| Echogenicity (1–5) | | | Tot | 18 | 14 | 32
| Total score is sum, ranges from 4–15 | | | | | Lower | Upper
| T+ if score ≥ 9 | | | | Value | 95% CI | 95% CI
| Arterial flow lowest RI ≤ 0.45 | | | Se | 68.0% | 46.4% | 89.6%
| Venous Doppler calculated from ROC curve but no number given in text | | | Sp | 93.9% | 81.4% | 100.0%
| | | | PPV | 92.3% | 77.8% | 100.0%
| | | | NPV | 68.4% | 47.5% | 89.3%
| | | | 4) Venous flow velocity; cutoff 10 cm/s AUC = 0.859 ± 0.06 SEM
| | | | | Dis+ | Dis- | Tot
| | | | T+ | 17 | 4 | 21
| | | | T- | 1 | 10 | 11
| | | | Tot | 18 | 14 | 32
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 94.0% | 83.0% | 100.0%
| | | | Sp | 71.0% | 47.2% | 94.8%
| | | | PPV | 81.0% | 64.2% | 97.7%
| | | | NPV | 90.9% | 73.9% | 100.0%
Alcazar, Merce, Laparte, et al., 2003 | Geographical location: | Age: Part 2 | Symptomatic (n [%]): | 1) Sassone | | | | Comments:
#5390 | Pamplona and Madrid, Spain | Mean (SD): 53.5 (11.3) | NR | | Dis+ | Dis- | Tot | —Stepwise regression (forward)
| Dates: | Range: 20–80 | Detected by exam (n [%]): | T+ | 20 | 7 | 27 | —Their model not reproducible from description in article
| Part 1 | Menopausal status (n [%]): | NR | T- | 11 | 52 | 63 | —Borderline tumors grouped in with malignant
| Jan 1995 - Jun 201 | Pre (< 45): 26 (30.2%) | Detected by imaging (n [%]): | Tot | 31 | 59 | 90 | —2×2 tables use cases not individuals
| Part 2 | Post (> 55): 60 (69.8%) | NR | | | Lower | Upper | —Pre-study history (symptomatic vs asymptomatic) not described
| Jul 2001 - Apr 2002 | Race/ethnicity (n [%]): | Combination (n [%]): | | Value | 95% CI | 95% CI | Quality assessment:
| Size of population: | NR | NR | Se | 64.5% | 47.7% | 81.3% | Reference standard: +
| Part One 665 (705 masses) | Risk factors (n [%]): | Additional data used for diagnosis: | Sp | 88.1% | 79.8% | 96.4% | Verification bias: +
| Part Two 86 (90 masses) | NR | NR | PPV | 74.1% | 57.5% | 90.6% | Test reliability/variability: + for Sassone and DePriest, ? for Ferrazzi, - for current study
| Other | Inclusion criteria: | | NPV | 82.5% | 73.2% | 91.9% | Sample size: -
| Part 1 retrospective analysis of ultrasound data to construct scoring system | Part 1 retrospective analysis of 665 women with adnexal masses who had US in hospital during time frame. | | 2) DePriest | | | | Statistical tests: +/-
| Part 2 prospective of consecutive patients to test scoring system and compare with other ultrasound scoring systems | Part 2 - prospective analysis of women (consecutive? - NR) with adnexal masses who had surgery in time frame at hospital | | | Dis+ | Dis- | Tot | Blinding: +/-
| Reference standard: | Exclusion criteria: | | T+ | 31 | 11 | 42 | Definition of +/- on screening test: - for current study
| Histopathology | NR | | T- | 0 | 48 | 48
| Reference standard applied to all test negatives?: | | | Tot | 31 | 59 | 90
| Yes | | | | | Lower | Upper
| Test reliability established?: | | | | Value | 95% CI | 95% CI
| Sassone - Yes | | | Se | 100.0% | 90.3% | 100.0%
| DePriest - Yes | | | Sp | 81.4% | 71.5% | 91.3%
| Ferrazzi - ? | | | PPV | 73.8% | 60.5% | 87.1%
| This one - ? | | | NPV | 100.0% | 93.8% | 100.0%
| Statistical tests used: | | | 3) Ferrazzi
| Multivariate logistic regression | | | | Dis+ | Dis- | Tot
| ROC curves | | | T+ | 26 | 10 | 36
| Blinding: | | | T- | 5 | 49 | 54
| NR - same individual did all US - prospective part 2 | | | Tot | 31 | 59 | 90
| Definition of positive and negative on screening test: | | | | | Lower | Upper
| Not described for Sassone, DePries,t or Ferrazzi (but can assume to be identical to reported in literature). | | | | Value | 95% CI | 95% CI
| Their scoring system used variables only for: | | | Se | 83.9% | 71.0% | 96.8%
| Thick papillary projections, high velocity/low resistance, solid area, and central flow (unclear how this is measured). | | | Sp | 83.1% | 73.5% | 92.7%
| | | | PPV | 72.2% | 57.6% | 86.9%
| | | | NPV | 90.7% | 83.0% | 98.5%
| | | | 4) Current study
| | | | | Dis+ | Dis- | Tot
| | | | T+ | 31 | 3 | 34
| | | | T- | 0 | 56 | 56
| | | | Tot | 31 | 59 | 90
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 100.0% | 90.3% | 100.0%
| | | | Sp | 94.9% | 89.3% | 100.0%
| | | | PPV | 91.2% | 81.6% | 100.0%
| | | | NPV | 100.0% | 94.6% | 100.0%
| | | | 5) Menopause Sassone
| | | | | Dis+ | Dis- | Tot
| | | | T+ | 17 | 4 | 21
| | | | T- | 11 | 30 | 41
| | | | Tot | 28 | 34 | 62
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 61.0% | 42.9% | 79.1%
| | | | Sp | 88.0% | 77.1% | 98.9%
| | | | PPV | 81.0% | 64.2% | 97.7%
| | | | NPV | 73.2% | 59.6% | 86.7%
| | | | 6) Menopause DePriest
| | | | | Dis+ | Dis- | Tot
| | | | T+ | 28 | 6 | 34
| | | | T- | 0 | 28 | 28
| | | | Tot | 28 | 34 | 62
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 100.0% | 89.3% | 100.0%
| | | | Sp | 82.4% | 69.5% | 95.2%
| | | | PPV | 82.4% | 69.5% | 95.2%
| | | | NPV | 100.0% | 89.3% | 100.0%
| | | | 7) Menopause Ferrazzi
| | | | | Dis+ | Dis- | Tot
| | | | T+ | 23 | 6 | 29
| | | | T- | 5 | 28 | 33
| | | | Tot | 28 | 34 | 62
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 82.0% | 67.8% | 96.2%
| | | | Sp | 82.0% | 69.1% | 94.9%
| | | | PPV | 79.3% | 64.6% | 94.1%
| | | | NPV | 84.8% | 72.6% | 97.1%
| | | | 8) Menopause current study
| | | | | Dis+ | Dis- | Tot
| | | | T+ | 28 | 2 | 30
| | | | T- | 0 | 32 | 32
| | | | Tot | 28 | 34 | 62
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 100.0% | 89.3% | 100.0%
| | | | Sp | 94.1% | 86.2% | 100.0%
| | | | PPV | 93.3% | 84.4% | 100.0%
| | | | NPV | 100.0% | 90.6% | 100.0%
| | | | 9) Premenopause Sassone
| | | | | Dis+ | Dis- | Tot
| | | | T+ | 3 | 3 | 6
| | | | T- | 0 | 22 | 22
| | | | Tot | 3 | 25 | 28
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 100.0% | 0.0% | 100.0%
| | | | Sp | 88.0% | 75.3% | 100.0%
| | | | PPV | 50.0% | 10.0% | 90.0%
| | | | NPV | 100.0% | 86.4% | 100.0%
| | | | 10) Premenopause DePriest
| | | | | Dis+ | Dis- | Tot
| | | | T+ | 3 | 5 | 8
| | | | T- | 0 | 20 | 20
| | | | Tot | 3 | 25 | 28
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 100.0% | 0.0% | 100.0%
| | | | Sp | 80.0% | 64.3% | 95.7%
| | | | PPV | 37.5% | 4.0% | 71.0%
| | | | NPV | 100.0% | 85.0% | 100.0%
| | | | 11) Premenopause Ferrazzi
| | | | | Dis+ | Dis- | Tot
| | | | T+ | 3 | 4 | 7
| | | | T- | 0 | 21 | 21
| | | | Tot | 3 | 25 | 28
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 100.0% | 0.0% | 100.0%
| | | | Sp | 84.0% | 69.6% | 98.4%
| | | | PPV | 42.9% | 6.2% | 79.5%
| | | | NPV | 100.0% | 85.7% | 100.0%
| | | | 12) Premenopause current study
| | | | | Dis+ | Dis- | Tot
| | | | T+ | 3 | 1 | 4
| | | | T- | 0 | 24 | 24
| | | | Tot | 3 | 25 | 28
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 100.0% | 0.0% | 100.0%
| | | | Sp | 96.0% | 88.3% | 100.0%
| | | | PPV | 75.0% | 32.6% | 100.0%
| | | | NPV | 100.0% | 87.5% | 100.0%
Ananda-kumar, Chew, Wong, et al., 1996 | Geographical location: | Age: | Symptomatic (n [%]): | 1) Presence of flow - color imaging alone | | | | Comments:
#10980 | Singapore | Mean:For benign 35; for malignant 42.9 | NR | | Dis+ | Dis- | Tot | —LMP tumors grouped in with malignant
| Dates: 1991-1993 | Range: for whole study pop 16–71 | Detected by exam (n [%]): | T+ | 26 | 39 | 65 | —2×2 tables and results calculated for masses not patients
| Size of population: | Menopausal status (n [%]): | NR | T- | 8 | 83 | 91 | —No description of why 0.66 used as cut point for RI
| 146 patients | NR | Detected by imaging (n [%]): | Tot | 34 | 122 | 156 | —“Color flow imaging alone” criteria for positive subjective and not reproducible
| 156 tumors | Race/ethnicity (n [%]): | NR | | | Lower | Upper | —Overlap in RI range with benign tumors (0.44–0.80) and malignant (0.3–0.60)
| Case series | NR | Combination (n [%]): | | Value | 95% CI | 95% CI | —From their data, performance of Doppler improves if masses with solid components, however, I was unable to get 2×2 table from these results (Tables 4, 5)
| Reference standard: | Risk factors (n [%]): | NR | Se | 76.5% | 62.2% | 90.8% | —TVUS only
| Histopathology | NR | Additional data used for diagnosis: | Sp | 68.0% | 59.7% | 76.3% | Quality assessment:
| Reference standard applied to all test negatives?: | Inclusion criteria: | NR | PPV | 40.0% | 28.1% | 51.9% | Reference standard: +/-
| Yes | Women with pelvic tumors detected clinically | | NPV | 91.2% | 85.4% | 97.0% | Verification bias: +
| Test reliability established?: | Exclusion criteria: | | 3) RI ≤ 0.66 | | | | Test reliability/variability: +/-
| Yes | NR | | | Dis+ | Dis- | Tot | Sample size: -
| Statistical tests used: | | | T+ | 24 | 24 | 48 | Statistical tests: +
| Student's t-test | | | T- | 10 | 98 | 108 | Blinding: -
| Z test of proportions and indices of normality | | | Tot | 34 | 122 | 156 | Definition of +/- on screening test: +/-
| Se, Sp | | | | | Lower | Upper
| Blinding: | | | | Value | 95% CI | 95% CI
| Not described | | | Se | 71.0% | 55.7% | 86.3%
| Definition of positive and negative on screening test: | | | Sp | 80.3% | 73.2% | 87.4%
| RI <= 0.66 | | | PPV | 50.0% | 35.9% | 64.1%
| Color flow alone = abnormal vessels “continuously fluctuating rather than pulsatile, also with mosaic pattern with yellow-green color combinations indicating turbulent flow” | | | NPV | 90.7% | 85.3% | 96.2%
Andolf, Jorgensen, and Astedt, 1990 | Geographical location: | Age: | Symptomatic (n [%]): | 1) Using US and BME combined (both positive for test to be positive) | | | | Comments:
#1200 | Lund Sweden | Range: 40–70 | 419 (52.3%) | | Dis+ | Dis- | Tot | —No description of what constituted an abnormal US
| Dates: Oct 1984-Jul 1987 | Menopausal status (n [%]): | Detected by exam (n [%]): | T+ | 6 | 49 | 55 | —No description of what constituted an abnormal manual exam
| Size of population: | NR | NR | T- | 0 | 746 | 746 | —Women with normal US and exam - half contacted via mail, cancer cases would have been detected in hospital system, only 2% of them had moved out of cachement area
| 801 screened | Race/ethnicity (n [%]): | Detected by imaging (n [%]): | Tot | 6 | 795 | 801 | —Six women excluded from results secondary to poor quality scans - no mention of follow up in them (cancer? etc.)
| Screening study | NR | NR | | | Lower | Upper | —Unable to get 2×2 tables for US and BME by itself
| Reference standard: | Risk factors (n [%]): | Combination (n [%]): | | Value | 95% CI | 95% CI | —Abdominal US only
| Surgery or repeat US or CT within 6 months | Family history: 190 (23.7%) | NR | Se | 100.0% | 50.0% | 100.0% | Quality assessment:
| Reference standard applied to all test negatives?: | Inclusion criteria: | Additional data used for diagnosis: | Sp | 93.8% | 92.2% | 95.5% | Reference standard: +
| No - but follow up US for all test positives who did not go to surgery | Women 40–70 years old who attended outpatient clinic of OB/GYN university hospital Lund, Sweden | NR | PPV | 10.9% | 2.7% | 19.1% | Verification bias: +
| Test reliability established?: | Exclusion criteria: | | NPV | 100.0% | 99.6% | 100.0% | Test reliability/variability: -
| Yes | NR; 6 scans excluded from analysis secondary to poor image quality | | | | | | Sample size: -
| Statistical tests used: | | | | | | | Statistical tests: -
| Not described | | | | | | | Blinding: -
| Blinding: | | | | | | | Definition of +/- on screening test: -
| Not mentioned
| Definition of positive and negative on screening test:
| Not described
Antonic and Rakar, 1995 | Geographical location: | Age: | Symptomatic (n [%]): | 1) Presence or absence of color flow in mass for all patients | | | | Comments:
#10830 | Ljubljana, Slovenia | Premenopausal women: mean 41; range 35–54 | NR | | Dis+ | Dis- | Tot | —LMP tumors grouped in with malignant
| Dates: Jan-Jul 1993 | Peri 53 (52–53) | Detected by exam (n [%]): | T+ | 16 | 28 | 44 | —No description of clinical path
| Size of population: | Post 63 (51–82) | NR | T- | 2 | 25 | 27 | —Good data on overlap of PI and RI range in malignant and non malignant outcomes.
| 71 | Menopausal status (n [%]): | Detected by imaging (n [%]): | Tot | 18 | 53 | 71 | —Did not clearly define visualization of color flow or not
| Prospective case series | Pre (< 45): 32 (45.1%) | NR | | | Lower | Upper | —No discussion of inter observer reliability
| Reference standard: | Peri (45–55): 4 (5.6%) | Combination (n [%]): | | Value | 95% CI | 95% CI | —Combination TVUS and abdominal US used (N for each not specified, unable to stratify)
| Histopathology | Post (> 55): 29(40.8%) | NR | Se | 88.9% | 74.4% | 100.0% | Quality assessment:
| Reference standard applied to all test negatives?: | 6 had undergone hysterectomy (8.5%) | Additional data used for diagnosis: | Sp | 47.2% | 33.7% | 60.6% | Reference standard: +
| Yes | Race/ethnicity (n [%]): | NR | PPV | 36.4% | 22.1% | 50.6% | Verification bias: +
| Test reliability established?: | NR | | NPV | 92.6% | 82.7% | 100.0% | Test reliability/variability: -
| Yes | Risk factors (n [%]): | | 2) Presence or absence of color flow in mass for menopausal patients | | | | Sample size: -
| Statistical tests used: | NR | | | Dis+ | Dis- | Tot | Statistical tests: +
| Fisher exact test | Inclusion criteria: | | T+ | 13 | 3 | 16 | Blinding: +
| Se, Sp | NR | | T- | 2 | 11 | 13 | Definition of +/- on screening test: + for CA-125, - for Doppler
| Mann-Whitney U test | Exclusion criteria: | | Tot | 15 | 14 | 29
| Blinding: | NR | | | | Lower | Upper
| Not described but prospective | | | | Value | 95% CI | 95% CI
| Definition of positive and negative on screening test: | | | Se | 86.7% | 69.5% | 100.0%
| PI [=(S-D)/M] and RI [=(S-D)/S] were calculated but test used presence or absence of colored flow without calculation | | | Sp | 78.6% | 57.1% | 100.0%
| CA-125 > 34 U/ml | | | PPV | 81.3% | 62.1% | 100.0%
| | | | NPV | 84.6% | 65.0% | 100.0%
| | | | 3) CA-125 for all patients
| | | | | Dis+ | Dis- | Tot
| | | | T+ | 15 | 4 | 19
| | | | T- | 3 | 49 | 52
| | | | Tot | 18 | 53 | 71
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 83.3% | 66.1% | 100.0%
| | | | Sp | 92.5% | 85.3% | 99.6%
| | | | PPV | 78.9% | 60.6% | 97.3%
| | | | NPV | 94.2% | 87.9% | 100.0%
| | | | 4) CA-125 for postmenopausal patients
| | | | | Dis+ | Dis- | Tot
| | | | T+ | 13 | 1 | 14
| | | | T- | 2 | 13 | 15
| | | | Tot | 15 | 14 | 29
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 86.7% | 69.5% | 100.0%
| | | | Sp | 92.9% | 79.4% | 100.0%
| | | | PPV | 92.9% | 79.4% | 100.0%
| | | | NPV | 86.7% | 69.5% | 100.0%
Asif, Sattar, Dawood, et al., 2004 | Geographical location: | Age: | Symptomatic (n [%]): | 1) CA-125 for whole study pop (> 35 U/ml) | | | | Comments:
#1580 | Rawalpindi, Pakistan | Mean (SD): | NR | | Dis+ | Dis- | Tot | —No tests of significance done
| Dates: Jan 2001 - Jan 2002 | For malignant - 45(11) | Detected by exam (n [%]): | T+ | 45 | 7 | 52 | —Unable to do 2×2 table for postmenopause (even though have info: 33 cancer, 11 benign - can't assume same test characteristics)
| Size of population: | For B9 - 37(14) | NR | T- | 10 | 38 | 48 | —Pre-study history (symptomatic vs asymptomatic) not described
| 100 | Menopausal status (n [%]): | Detected by imaging (n [%]): | Tot | 55 | 45 | 100 | Quality assessment:
| Other | Pre (< 45): 56(56%) | NR | | | Lower | Upper | Reference standard: +
| Consecutive preoperative patients at hospital with mass | Peri (45–55): | Combination (n [%]): | | Value | 95% CI | 95% CI | Verification bias: +
| Reference standard: | Post (> 55): 44(44%) | NR | Se | 82.0% | 71.8% | 92.2% | Test reliability/variability: + (for CA125)
| Histopathology | Race/ethnicity (n [%]): | Additional data used for diagnosis: | Sp | 84.0% | 73.3% | 94.7% | Sample size: -
| Reference standard applied to all test negatives?: | NR | NR | PPV | 86.5% | 77.3% | 95.8% | Statistical tests: +/-
| Yes | Risk factors (n [%]): | | NPV | 79.2% | 67.7% | 90.7% | Blinding: -
| Test reliability established?: | NR | | 2) US score (Jacobs) ≥ 1 | | | | Definition of +/- on screening test: +
| CA-125 yes | Inclusion criteria: | | | Dis+ | Dis- | Tot
| US - ? | 100 consecutive women admitted to hospital in time frame for surgery for adnexal mass | | T+ | 53 | 38 | 91
| Statistical tests used: | Exclusion criteria: | | T- | 2 | 7 | 9
| ROC | NR | | Tot | 55 | 45 | 100
| Se, Sp | | | | | Lower | Upper
| Blinding: | | | | Value | 95% CI | 95% CI
| NR - prospective study | | | Se | 96.4% | 91.4% | 100.0%
| Definition of positive and negative on screening test: | | | Sp | 15.6% | 5.0% | 26.1%
| CA-125 - 35U/mL | | | PPV | 58.2% | 48.1% | 68.4%
| US - Jacobs scoring system: cutoff not described in article | | | NPV | 77.8% | 50.6% | 100.0%
| | | | 3) US score (Jacobs) ≥ 2
| | | | | Dis+ | Dis- | Tot
| | | | T+ | 42 | 5 | 47
| | | | T- | 13 | 40 | 53
| | | | Tot | 55 | 45 | 100
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 76.4% | 65.1% | 87.6%
| | | | Sp | 88.9% | 79.7% | 98.1%
| | | | PPV | 89.4% | 80.5% | 98.2%
| | | | NPV | 75.5% | 63.9% | 87.1%
Balbi, Musone, Menditto, et al., 2001 | Geographical location: | Age: | Symptomatic (n [%]): | Not enough info to stratify by age or menopausal status | | | | Comments:
#2320 | Naples, Italy | Range: 40–80 | NR | 1) PE physical exam by standard protocol. Examiner was asked to predict benign or malignant. | | | | —20 patients excluded for reasons that seem to indicate there wasn't blinding
| Dates: Jan 1996-Mar 2000 | Menopausal status (n [%]): | Detected by exam (n [%]): | | Dis+ | Dis- | Tot | —Physical exam had high sensitivity, but examiners not blinded to patient history or prior diagnosis of pelvic mass
| Size of population: | NR | NR | T+ | 20 | 13 | 33 | —Although RI measured, not included in definition of +US
| 92 women | Race/ethnicity (n [%]): | Detected by imaging (n [%]): | T- | 2 | 37 | 39 | —Pre-study history (symptomatic vs asymptomatic) not described
| Other | NR | NR | Tot | 22 | 50 | 72 | Quality assessment:
| Case series | Risk factors (n [%]): | Combination (n [%]): | | | Lower | Upper | Reference standard: +
| Reference standard: | NR | NR | | Value | 95% CI | 95% CI | Verification bias: -
| Histopathological diagnosis | Inclusion criteria: | Additional data used for diagnosis: | Se | 90.0% | 77.5% | 100.0% | Test reliability/variability: + for CA-125; ? for PE, CA-72-4, and US
| Reference standard applied to all test negatives?: | “Women with a pelvic mass originating in the ovary” | NR | Sp | 74.0% | 61.8% | 86.2% | Sample size: -
| No, 18 women with “clearly benign” masses not verified; 2 patients with “clearly malignant” disease (metastases) also excluded. | Exclusion criteria: | | PPV | 60.6% | 43.9% | 77.3% | Statistical tests: +
| Test reliability established?: | NR | | NPV | 94.9% | 87.9% | 100.0% | Blinding: -
| Not for PE or CA-72-4 | | | 2) US | | | | Definition of +/- on screening test: +
| ? US and RI | | | | Dis+ | Dis- | Tot
| Yes for CA-125 | | | T+ | 19 | 14 | 33
| Statistical tests used: | | | T- | 3 | 36 | 39
| Se, Sp | | | Tot | 22 | 50 | 72
| Multivariate logistic analysis | | | | | Lower | Upper
| Blinding: | | | | Value | 95% CI | 95% CI
| NR | | | Se | 86.0% | 71.5% | 100.0%
| Definition of positive and negative on screening test: | | | Sp | 72.0% | 59.6% | 84.4%
| PE - “palpable mass of any size ...clinically distinguishable from the gastrointestinal tract”; clinician asked to designate as benign or malignant | | | PPV | 57.6% | 40.7% | 74.4%
| CA-125 > 35 U/ml | | | NPV | 92.3% | 83.9% | 100.0%
| CA-72-4 > 3 U/ml | | | 3) CA-125
| US “multilocular solid tumor or solid tumor” from Valentin et al classification ref 19 | | | | Dis+ | Dis- | Tot
| RI < 0.4 | | | T+ | 15 | 7 | 22
| | | | T- | 7 | 43 | 50
| | | | Tot | 22 | 50 | 72
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 68.0% | 48.5% | 87.5%
| | | | Sp | 86.0% | 76.4% | 95.6%
| | | | PPV | 68.2% | 48.7% | 87.6%
| | | | NPV | 86.0% | 76.4% | 95.6%
| | | | 4) CA-72-4 > 3 U/ml
| | | | | Dis+ | Dis- | Tot
| | | | T+ | 13 | 6 | 19
| | | | T- | 9 | 44 | 53
| | | | Tot | 22 | 50 | 72
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 59.0% | 38.4% | 79.6%
| | | | Sp | 88.0% | 79.0% | 97.0%
| | | | PPV | 68.4% | 47.5% | 89.3%
| | | | NPV | 83.0% | 72.9% | 93.1%
Benjapibal, Sunsanee-vitayakul, Boriboon-hirunsarn, et al., 2002 | Geographical location: | Age: | Symptomatic (n [%]): | 1) PI ≤ 1.0 is T+ | | | | Comments:
#2150 | Bangkok, Thailand | Mean (SD): 41 (14) | Abdominal pain 30.8% | | Dis+ | Dis- | Tot | —No discussion of 7 excluded (no intent to treat analysis)
| Dates: Jun 2000-Sep 2001 | Range: 12–81 | Detected by exam (n [%]): | T+ | 29 | 15 | 44 | —One of few studies to describe pre-study clinical history
| Size of population: | Menopausal status (n [%]): | Palpable mass 30% | T- | 6 | 63 | 69 | Quality assessment:
| 120 | Pre (< 45): NR | Detected by imaging (n [%]): | Tot | 35 | 78 | 113 | Reference standard: +
| 7 excluded for no measurable flow | Peri (45–55): NR | NR | | | Lower | Upper | Verification bias: +
| Other: | Post (> 55): “one fourth” | Combination (n [%]): | | Value | 95% CI | 95% CI | Test reliability/variability: -
| Consecutive patients | Race/ethnicity (n [%]): | NR | Se | 82.9% | 70.4% | 95.4% | Sample size: -
| Reference standard: | NR | Additional data used for diagnosis: | Sp | 80.8% | 72.1% | 89.5% | Statistical tests: +
| Histopathology | Risk factors (n [%]): | NR | PPV | 65.9% | 51.9% | 79.9% | Blinding: -
| Reference standard applied to all test negatives?: | NR | | NPV | 91.3% | 84.7% | 98.0% | Definition of +/- on screening test: +
| Yes | Inclusion criteria:
| Test reliability established?: | Patients with suspected ovarian tumors admitted for surgery
| Yes | PI measured
| Statistical tests used: | Exclusion criteria:
| Student t-test | PI not measurable (7)
| Chi-square analysis
| Blinding:
| Blinded to ultimate diagnosis, but not to other clinical factors
| Definition of positive and negative on screening test:
| PI ≤ 1.0 is positive (from Bourne ref 25)
Benjapibal, Sunsanee-vitayakul, Boriboon-hirunsarn, et al., 2003 | Geographical location: | Age: | Symptomatic (n [%]): | 1) Sonographic pattern score ≥ 10 is T+ | | | | Comments:
#5600 | Bangkok, Thailand | Mean (SD): 41.5 (14.1) | 92% had gynecological symptoms that made them contact their physicians | | Dis+ | Dis- | Tot | —Overlap in dates (3 months) from other study by same group (#2150)
| Dates: Jul 2001-Jun 2002 | Range: 12–81 | Detected by exam (n [%]): | T+ | 31 | 9 | 40 | —Reliability of scoring system not established
| Size of population: | Menopausal status (n [%]): | 8% diagnosed at routine gynecological checkup | T- | 4 | 76 | 80 | —Pre-study clinical history described
| 123 | Pre (< 45): NR | Detected by imaging (n [%]): | Tot | 35 | 85 | 120 | Quality assessment:
| 3 excluded | Peri (45–55): NR | NR | | | | | Reference standard: +
| Other | Post (> 55): “one fourth” | Combination (n [%]): | | | Lower | Upper | Verification bias: +
| Patients with suspected ovarian tumor admitted for elective surgery | Race/ethnicity (n [%]): | NR | | Value | 95% CI | 95% CI | Test reliability/variability: -
| Reference standard: | NR | Additional data used for diagnosis: | Se | 88.6% | 78.1% | 99.1% | Sample size: -
| Histopathology | Risk factors (n [%]): | NR | Sp | 89.4% | 82.9% | 95.9% | Statistical tests: +
| Reference standard applied to all test negatives?: | NR | | PPV | 77.5% | 64.6% | 90.4% | Blinding: -
| Yes | Inclusion criteria: Suspicion of ovarian mass, admitted for surgery | | NPV | 95.0% | 90.2% | 99.8% | Definition of +/- on screening test: -
| Test reliability established?: | Exclusion criteria: | | Complete data on varying cutoffs provided (ROC curve could be constructed)
| No | Non ovarian origin of tumor (n = 3; leiomyoma and parovarian cyst)
| Statistical tests used:
| Chi-square
| Blinding:
| NR
| Prospective study (but not blinded to clinical history)
| Definition of positive and negative on screening test:
| Sonographic score modified from Vera (ref 11) and Kawai (ref 12)
| positive > 9 (10–14)
Berlanda, Ferrari, Mezzopane, et al., 2002 | Geographical location: | Age: | Symptomatic (n [%]): | 1) Test characteristics based on algorithm | | | | Comments:
#2180 | Milan, Italy | Median = 60; 47–69 (interquartile) for women with malignant masses | NR | | Dis+ | Dis- | Tot | —Present number of malignancies for pre and post menopausal but no other information provided to create 2×2.
| Dates: NR; 3-year period | Median = 32 and 27–43 for interquartile range | Detected by exam (n [%]): | T+ | 27 | 6 | 33 | —NOTE: N for 2×2 is masses NOT women.
| Size of population: | Menopausal status (n [%]): | NR | T- | 3 | 198 | 201 | —RI ≤ 0.6 cutoff not explained
| 215 women | Pre (< 45): 177 | Detected by imaging (n [%]): | Tot | 30 | 204 | 234 | —Masses with “appearance of cystic teratoma” considered benign regardless of morphology US score
| 234 masses | Peri (45–55): | NR | | | Lower | Upper | —Pre-study history (symptomatic vs asymptomatic) not described
| Other: | Post (> 55): 57 | Combination (n [%]): | | Value | 95% CI | 95% CI | Quality assessment:
| Prospective case series | Race/ethnicity (n [%]): | NR | Se | 90.0% | 79.3% | 100.0% | Reference standard: +
| Reference standard: | Italian | Additional data used for diagnosis: | Sp | 97.0% | 94.7% | 99.3% | Verification bias: +
| Histology | Risk factors (n [%]): | None | PPV | 81.8% | 68.7% | 95.0% | Test reliability/variability: -
| Reference standard applied to all test negatives?: | NR | | NPV | 98.5% | 96.8% | 100.0% | Sample size: -
| Assumed yes | Inclusion criteria: | | 2) Test characteristics based on morphological score (Ferrazzi) | | | | Statistical tests: +
| Test reliability established?: | Patients undergoing elective surgical treatment for adnexal masses | | | Dis+ | Dis- | Tot | Blinding: -
| NR | Exclusion criteria: | | T+ | 28 | 24 | 52 | Definition of +/- on screening test: +
| Statistical tests used: | NR | | T- | 2 | 180 | 182
| Student t-tests | | | Tot | 30 | 204 | 234
| Mann Witney U | | | | | Lower | Upper
| Fischers Exact | | | | Value | 95% CI | 95% CI
| McNemars | | | Se | 93.0% | 83.9% | 100.0%
| Blinding: | | | Sp | 88.0% | 83.5% | 92.5%
| NR | | | PPV | 53.8% | 40.3% | 67.4%
| Definition of positive and negative on screening test: | | | NPV | 98.9% | 97.4% | 100.0%
| Ferrazzi's morphological score (table 1) | | | 3) CA-125 > 35 U/ml
| Ultrasound | | | | Dis+ | Dis- | Tot
| 1 = ≤ 3 mm; septa = none, vegetations = none; echogenicity = Sololucent | | | T+ | 22 | 1 | 23
| 2 = > 3 mm, septa > 3 mm, low echogenicity | | | T- | 6 | 23 | 29
| 3 = septa > 3 mm, | | | Tot | 28 | 24 | 52
| 4 = irregular, mostly solid; vegetations ≤ 3, with echogenic areas | | | | | Lower | Upper
| 5 = irregular, non-applicable, > 3mm, with heterogeneous echogenic areas, solid | | | | Value | 95% CI | 95% CI
| Score ≥ 9 considered suspicious for malignancy | | | Se | 78.6% | 63.4% | 93.8%
| Additional factors considered | | | Sp | 95.8% | 87.8% | 100.0%
| Mean diameter ≥ 10 cm; immobility, bilaterality, presence of ascites, resistance index < 0.6 and serum CA-125 > 35 IUml | | | PPV | 95.7% | 87.3% | 100.0%
| Note: additional factors used to develop an algorithm. Algorithm compared to morphological score. | | | NPV | 79.3% | 64.6% | 94.1%
| Low risk - masses with score < 9 mm and typical cystic teratomas | | | 4) RI ≤ 0.6
| Moderate risk | | | | Dis+ | Dis- | Tot
| ≥ 9 suspicious for malignancy, absence of any one of the additional criteria defined above | | | T+ | 19 | 6 | 25
| High risk | | | T- | 9 | 18 | 27
| ≥ 9 and any of the above factors. | | | Tot | 28 | 24 | 52
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 67.9% | 50.6% | 85.2%
| | | | Sp | 75.0% | 57.7% | 92.3%
| | | | PPV | 76.0% | 59.3% | 92.7%
| | | | NPV | 66.7% | 48.9% | 84.4%
Bromley, Goodman, and Benacerraf, 1994 | Geographical location: | Age: | Symptomatic (n [%]): | 1) Scoring system | | | | Comments:
#4630 | Boston, MA | NR | NR | | Dis+ | Dis- | Tot | —Unclear where RI 0.6 came from
| Dates: Mar 1992-Apr 1993 | Menopausal status (n [%]): | Detected by exam (n [%]): | T+ | 11 | 10 | 21 | —Borderline tumors in malignant group
| Size of population: | Post (> 55): 100% | NR | T- | 1 | 11 | 12 | — 33 sonographic masses in 1 year seems rather low for tertiary women's hospital
| 33 | Race/ethnicity (n [%]): | Detected by imaging (n [%]): | Tot | 12 | 21 | 33 | —Pre-study history (symptomatic vs asymptomatic) not described
| Other | NR | NR | | | Lower | Upper | Quality assessment:
| Prospective series | Risk factors (n [%]): | Combination (n [%]): | | Value | 95% CI | 95% CI | Reference standard: +
| Reference standard: | NR | NR | Se | 91.0% | 74.8% | 100.0% | Verification bias: +
| Pathology | Inclusion criteria: | Additional data used for diagnosis: | Sp | 52.0% | 30.6% | 73.4% | Test reliability/variability:-
| Reference standard applied to all test negatives?: | Pelvic masses diagnosed by sonography and histopathologic verification of disease | Scanned transabdominally and transvaginally. | PPV | 52.4% | 31.0% | 73.7% | Sample size: -
| Yes | Consecutive cases | | NPV | 91.7% | 76.0% | 100.0% | Statistical tests: -
| Test reliability established?: | Exclusion criteria: | | 2) Resistance index using 0.6 | | | | Blinding: -
| NR | NR | | | Dis+ | Dis- | Tot | Definition of +/- on screening test: +
| Statistical tests used: | | | T+ | 8 | 4 | 12
| None stated | | | T- | 4 | 17 | 21
| Se, Sp, PPV, NPV | | | Tot | 12 | 21 | 33
| Blinding: | | | | | Lower | Upper
| NR | | | | Value | 95% CI | 95% CI
| Definition of positive and negative on screening test: | | | Se | 66.0% | 39.2% | 92.8%
| Sonography | | | Sp | 81.0% | 64.2% | 97.8%
| Clear cyst < 3 cm -1 | | | PPV | 66.7% | 40.0% | 93.3%
| Clear cyst ≥ 3 cm - 2 | | | NPV | 81.0% | 64.2% | 97.7%
| Cyst with slight irregular wall on one side 3
| Cyst with uniform low-level echoes or a single thin septation - 4
| Solid ovarian enlargement; cyst with irregular borders, nonspecific ovarian masses 5–6
| Multiple septations and nodular cystic mass 7–9
| 7 = less nodularity; 9 = more nodules and septations
| Same as 7–9 with ascites 10
| Doppler
| Resistance index = (systolic peak - diastolic trough)/ systolic peak
| Lowest resistance index used
| RI < 0.6
Brown, Doubilet, Miller, et al., 1998 | Geographical location: | Age: | Symptomatic (n [%]): | 1) Malignancy score - cutoff 453 | | | | Comments:
#3350 | Boston, MA | Mean (SD): 39.9 (12.7) | NR | AUC 0.98±0.01 | | | | —No model validation
| Dates: Jul 1991-Jul 1996 | Range: 16–78 | Detected by exam (n [%]): | | Dis+ | Dis- | Tot | —Pre-study history (symptomatic vs asymptomatic) not described
| Size of population: | Menopausal status (n [%]): | NR | T+ | 26 | 13 | 39 | Quality assessment:
| 194 | Pre (< 45): 135 (69.6%) | Detected by imaging (n [%]): | T- | 2 | 170 | 172 | Reference standard: +
| Other | Post (> 55): 38 (19.6%) | NR | Tot | 28 | 183 | 211 | Verification bias: +
| Consecutive patients | don't add to 100% because 21 (10.8%) had hysterectomy | Combination (n [%]): | | | Lower | Upper | Test reliability/variability: -
| Reference standard: | Race/ethnicity (n [%]): | NR | | Value | 95% CI | 95% CI | Sample size: -
| Histopathology | NR | Additional data used for diagnosis: | Se | 93.0% | 83.5% | 100.0% | Statistical tests: +
| Reference standard applied to all test negatives?: | Risk factors (n [%]): | NR | Sp | 93.0% | 89.3% | 96.7% | Blinding: -
| No (but negatives without surgery had followup US that demonstrated resolution) | NR | Malignancy score based on logistic regression model derived from gray-scale and Doppler sonography features | PPV | 66.7% | 51.9% | 81.5% | Definition of +/- on screening test: - variables in model not specified, no independent validation
| Test reliability established?: | Inclusion criteria: | Solid component | NPV | 98.8% | 97.2% | 100.0%
| Yes | All adnexal masses scanned at the institution where both gray-scale and Doppler sonography had been done and | None (0) | 2) Malignancy score - cutoff 433
| Statistical tests used: | Exclusion criteria: | Hyperechoic (13) | AUC 0.98±0.01
| Mann-Whitney U test | Pregnant masses | non-hyperechoic (394) | | Dis+ | Dis- | Tot
| Fisher exact test | Premenopausal patients > 10 days after LMP | Fluid component (anechoic, echogenic, none) | T+ | 28 | 26 | 54
| Chi-square | Simple cysts < 2 cm in premenopausal women | Septations | T- | 0 | 157 | 157
| Stepwise logistic regression | Extraovarian masses on US | Thin (0) | Tot | 28 | 183 | 211
| ROC curves | | Thick (22) | | | Lower | Upper
| Blinding: | | None (38) | | Value | 95% CI | 95% CI
| Yes | | Wall (thin, thick, none) | Se | 100.0% | 89.3% | 100.0%
| US done prospectively, scale done after by blinded individual | | Free fluid | Sp | 85.8% | 80.7% | 90.9%
| Definition of positive and negative on screening test: | | Present (38) | PPV | 51.9% | 38.5% | 65.2%
| See column 3 | | Absent (0) | NPV | 100.0% | 98.1% | 100.0%
| | | Bilateral masses (yes, no)
| | | Size, average (cm)
| | | Size, maximum (cm)
| | | Flow location
| | | Central (37)
| | | Peripheral only (1)
| | | None detected (0)
Buckshee, Temsu, Bhatla, et al., 1998 | Geographical location: | Age: | Symptomatic (n [%]): | 1) PE (diagnosed as malignant = T+) | | | | Comments:
#710 | New Delhi, India | 20–30: n = 10 | NR | | Dis+ | Dis- | Tot | —Unclear how patients were chosen given non-consecutive enrollment
| Dates: May 1995-Apr 1997 | 31–40: n = 13 | Detected by exam (n [%]): | T+ | 7 | 3 | 10 | —Did blind PE to US
| Size of population: | 41–50: n = 6 | NR | T- | 2 | 24 | 26 | —This study validates previous measures PI and Sassone
| 34 individuals | > 50: n = 5 | Detected by imaging (n [%]): | Tot | 9 | 27 | 36 | —Pre-study history (symptomatic vs asymptomatic) not described
| 36 tumors | Menopausal status (n [%]): | NR | | | Lower | Upper | Quality assessment:
| Other | Pre (< 40): 23 (67.6%) | Combination (n [%]): | | Value | 95% CI | 95% CI | Reference standard: +
| Reference standard: | Peri (41–50): 6 (17.6) | NR | Se | 77.8% | 50.6% | 100.0% | Verification bias: +
| Histopathology | Post (> 50): 5 (14.7%) | Additional data used for diagnosis: | Sp | 88.9% | 77.1% | 100.0% | Test reliability/variability: -
| Reference standard applied to all test negatives?: | Race/ethnicity (n [%]): | NR | PPV | 70.0% | 41.6% | 98.4% | Sample size: -
| Yes | NR | | NPV | 92.3% | 82.1% | 100.0% | Statistical tests: +
| Test reliability established?: | Risk factors (n [%]): | | 2) TVUS score (≥ 9 indicates T+) Sassone et al. | | | | Blinding: +
| No for PE | Family history: 1 (2.9%) | | | Dis+ | Dis- | Tot | Definition of +/- on screening test: +
| Yes for US | Inclusion criteria: | | T+ | 9 | 4 | 13
| Statistical tests used: | Women with presumed adnexal mass going to surgery | | T- | 0 | 23 | 23
| Fisher's exact test | Exclusion criteria: | | Tot | 9 | 27 | 36
| Se, Sp | Women with proven diagnosis of malignancy/metastatic disease on ultrasound or CT | | | | Lower | Upper
| Blinding: | | | | Value | 95% CI | 95% CI
| No but prospective enrollment | | | Se | 100.0% | 66.7% | 100.0%
| PE was blinded to US result | | | Sp | 85.2% | 71.8% | 98.6%
| Definition of positive and negative on screening test: | | | PPV | 69.2% | 44.1% | 94.3%
| PE - clinical impression of benign or malignant | | | NPV | 100.0% | 87.0% | 100.0%
| Gray-scale sonography - Sassone criteria ≥ 9 malignant | | | 3) Pulsatility Index (< 1 indicates T+)
| PI < 1 malignant | | | | Dis+ | Dis- | Tot
| | | | T+ | 6 | 1 | 7
| | | | T- | 3 | 26 | 29
| | | | Tot | 9 | 27 | 36
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 66.7% | 35.9% | 97.5%
| | | | Sp | 96.3% | 89.2% | 100.0%
| | | | PPV | 85.7% | 59.8% | 100.0%
| | | | NPV | 89.7% | 78.6% | 100.0%
Buist, Golding, Burger, et al., 1994 | Geographical location: | Age: | Symptomatic (n [%]): | Data are for primary cancer | | | | Comments:
#960 | The Netherlands | Median: 60 | NR | Recurrent presented but not included here. | | | | —PE by gynecological oncologist
| Dates: Nov 1988-Sep 1992 | Range: 24–84 | Detected by exam (n [%]): | 1) CT - reviewer a | | | | —Population “clinically suspected of having primary or recurrent ovarian CA”-likely to increase sensitivity of unblinded physical exam
| Size of population: | Menopausal status (n [%]): | NR | | Dis+ | Dis- | Tot | —45 with r/o primary cancer, 19 with r/o recurrence (2×2 tables for r/o primary group)
| 64 | NR | Detected by imaging (n [%]): | T+ | 26 | 10 | 36 | —Imaging used descriptive yes/no for cancer - no scoring system used for test
| Other | Race/ethnicity (n [%]): | NR | T- | 1 | 8 | 9 | —No CA-125 level stated
| Prospective series | NR | Combination (n [%]): | Tot | 27 | 18 | 45 | —No PE criteria stated
| Reference standard: | Risk factors (n [%]): | NR | | | Lower | Upper | —Pre-study history (symptomatic vs asymptomatic) not described
| Pathology | NR | Additional data used for diagnosis: | | Value | 95% CI | 95% CI | Quality assessment:
| Reference standard applied to all test negatives?: | Inclusion criteria: | NR | Se | 96.0% | 88.6% | 100.0% | Reference standard: +
| Yes | Clinically suspected of having primary or recurrent cancer | | Sp | 44.0% | 21.1% | 66.9% | Verification bias: +
| Test reliability established?: | Exclusion criteria: | | PPV | 72.2% | 57.6% | 86.9% | Test reliability/variability: +
| Yes | Declined participation, contraindications for one of the diagnostic methods or organizational reasons prevented all methods being performed before surgery | | NPV | 88.9% | 68.4% | 100.0% | Sample size: -; wide confidence intervals
| Statistical tests used: | | | 2) CT - reviewer b | | | | Statistical tests: +
| ROC curves | | | | Dis+ | Dis- | Tot | Blinding: + for final results, but examiners all knew patient suspected of having disease
| Fisher's exact | | | T+ | 24 | 3 | 27 | Definition of +/- on screening test: -
| Chi-square | | | T- | 3 | 15 | 18
| Se, Sp | | | Tot | 27 | 18 | 45
| Blinding: | | | | | Lower | Upper
| Yes | | | | Value | 95% CI | 95% CI
| Definition of positive and negative on screening test: | | | Se | 89.0% | 77.2% | 100.0%
| NR | | | Sp | 83.0% | 65.6% | 100.0%
| | | | PPV | 88.9% | 77.0% | 100.0%
| | | | NPV | 83.3% | 66.1% | 100.0%
| | | | 3) MRI - reviewer a
| | | | | Dis+ | Dis- | Tot
| | | | T+ | 26 | 12 | 38
| | | | T- | 1 | 6 | 7
| | | | Tot | 27 | 18 | 45
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 96.0% | 88.6% | 100.0%
| | | | Sp | 33.0% | 11.3% | 54.7%
| | | | PPV | 68.4% | 53.6% | 83.2%
| | | | NPV | 85.7% | 59.8% | 100.0%
| | | | 4) MRI - reviewer b
| | | | | Dis+ | Dis- | Tot
| | | | T+ | 26 | 1 | 27
| | | | T- | 1 | 17 | 18
| | | | Tot | 27 | 18 | 45
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 96.0% | 88.6% | 100.0%
| | | | Sp | 94.0% | 83.0% | 100.0%
| | | | PPV | 96.3% | 89.2% | 100.0%
| | | | NPV | 94.4% | 83.9% | 100.0%
| | | | 5) US
| | | | | Dis+ | Dis- | Tot
| | | | T+ | 24 | 10 | 34
| | | | T- | 3 | 8 | 11
| | | | Tot | 27 | 18 | 45
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 89.0% | 77.2% | 100.0%
| | | | Sp | 44.0% | 21.1% | 66.9%
| | | | PPV | 70.6% | 55.3% | 85.9%
| | | | NPV | 72.7% | 46.4% | 99.0%
| | | | 6) Physical Exam
| | | | | Dis+ | Dis- | Tot
| | | | T+ | 26 | 1 | 27
| | | | T- | 1 | 17 | 18
| | | | Tot | 27 | 18 | 45
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 96.0% | 88.6% | 100.0%
| | | | Sp | 94.0% | 83.0% | 100.0%
| | | | PPV | 96.3% | 89.2% | 100.0%
| | | | NPV | 94.4% | 83.9% | 100.0%
| | | | 7) CA-125
| | | | | Dis+ | Dis- | Tot
| | | | T+ | 22 | 6 | 28
| | | | T- | 5 | 12 | 17
| | | | Tot | 27 | 18 | 45
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 81.0% | 66.2% | 95.8%
| | | | Sp | 67.0% | 45.3% | 88.7%
| | | | PPV | 78.6% | 63.4% | 93.8%
| | | | NPV | 70.6% | 48.9% | 92.2%
| | | | Kappa for inter-observer reliability:
| | | | CT = 0.28
| | | | MRI = 0.41
Buy, Ghossain, Hugol, et al., 1996 | Geographical location: | Age: | Symptomatic (n [%]): | 1) Conventional sonography - indeterminate masses classified as malignant | | | | Comments:
#4030 | Paris, France | Benign | NR | | Dis+ | Dis- | Tot | —Unable to stratify
| Dates: Jan 1993 - Dec 1994 | Mean: 40 | Detected by exam (n [%]): | T+ | 22 | 16 | 38 | —Menopause not defined
| Size of population: | Range: 22–73 | NR | T- | 3 | 74 | 77 | —No scoring system for US - descriptive only
| 160 patients | Menopausal = 28 | Detected by imaging (n [%]): | Tot | 25 | 90 | 115 | —Borderline on both US and on path grouped in with malignant in analysis
| 115 met inclusion criteria | Borderline | NR | | | Lower | Upper | —Pre-study history (symptomatic vs asymptomatic) not described
| Other | 47 and 50 years | Combination (n [%]): | | Value | 95% CI | 95% CI | Quality assessment:
| Prospective series | Both premenopausal | NR | Se | 88.0% | 75.3% | 100.0% | Reference standard: +
| Reference standard: | Malignant | Additional data used for diagnosis: | Sp | 82.0% | 74.1% | 89.9% | Verification bias: +
| Pathology | 57 mean; 22–84 | NR | PPV | 57.9% | 42.2% | 73.6% | Test reliability/variability: -
| Reference standard applied to all test negatives?: | Menopausal =15 | | NPV | 96.1% | 91.8% | 100.0% | Sample size: -
| Yes | Menopausal status (n [%]): | | 2) Color Doppler and sonography | | | | Statistical tests: +
| Test reliability established?: | Pre (< 45): 72 (63%) | | | Dis+ | Dis- | Tot | Blinding: -
| No | Post (> 55): 43 (37%) | | T+ | 22 | 3 | 25 | Definition of +/- on screening test: +
| Statistical tests used: | Race/ethnicity (n [%]): | | T- | 3 | 87 | 90
| Mann Witney | NR | | Tot | 25 | 90 | 115
| McNemar | Risk factors (n [%]): | | | | Lower | Upper
| Blinding: | NR | | | Value | 95% CI | 95% CI
| NR | Inclusion criteria: | | Se | 88.0% | 75.3% | 100.0%
| Definition of positive and negative on screening test: | Adnexal mass suspected by physical exam or discovered during previous sonography | | Sp | 97.0% | 93.5% | 100.0%
| Sonography | Only patients who had laparoscopy | | PPV | 88.0% | 75.3% | 100.0%
| Borderline or malignant | Laparotomy (not laproscopy) included. | | NPV | 96.7% | 93.0% | 100.0%
| Echogenic structure against the wall of the cyst present; large irregular homogeneous or heterogeneous echogenic structure | Exclusion criteria: | | 3) Resistive Index
| Irregular thickened (3 mm) wall or septum present. | NR | | | Dis+ | Dis- | Tot
| Benign - mass did not present with any of the findings of malignant tumors, or pattern typical of a benign ovarian mass. | | | T+ | 5 | 3 | 8
| Method 2. Morphology + color Doppler | | | T- | 21 | 87 | 108
| Presence of color flow in echogenic portion charac. As malignant - considered malignant | | | Tot | 25 | 90 | 116
| Absence of color flow - considered benign | | | | | Lower | Upper
| If mass classified as benign using morphology then malignant if color flow in a regular wall, regular septum or regular solid mass - benign. | | | | Value | 95% CI | 95% CI
| No color flow - benign. | | | Se | 18.0% | 2.9% | 33.1%
| Method 3. Spectral Doppler analysis | | | Sp | 97.0% | 93.5% | 100.0%
| Absence of arterial flow - considered benign. | | | PPV | 62.5% | 29.0% | 96.0%
| Measured RI, PI and PSV (no definition provided). Lowest values retained. | | | NPV | 80.6% | 73.1% | 88.0%
| Mass malignant if Resistive Index ≤ 0.4; Pulsatility Index ≤ 1 and Peak systolic velocity ≥ 15 cm/sec. | | | 4) Pulsatility Index
| | | | | Dis+ | Dis- | Tot
| | | | T+ | 18 | 3 | 21
| | | | T- | 7 | 87 | 94
| | | | Tot | 25 | 90 | 115
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 71.0% | 53.2% | 88.8%
| | | | Sp | 97.0% | 93.5% | 100.0%
| | | | PPV | 85.7% | 70.7% | 100.0%
| | | | NPV | 92.6% | 87.2% | 97.9%
| | | | 5) Peak systolic velocity
| | | | | Dis+ | Dis- | Tot
| | | | T+ | 12 | 3 | 15
| | | | T- | 13 | 87 | 100
| | | | Tot | 25 | 90 | 115
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 47.0% | 27.4% | 66.6%
| | | | Sp | 97.0% | 93.5% | 100.0%
| | | | PPV | 80.0% | 59.8% | 100.0%
| | | | NPV | 87.0% | 80.4% | 93.6%
Canis, Pouly, Wattiez, et al., 1997 | Geographical location: | Age: | Symptomatic (n [%]): | 1) Ultrasound results; low malignant potential = benign | | | | Comments:
#3710 | Clermont-Ferrand, France | NR | NR | | Dis+ | Dis- | Tot | —Clinical history not described
| Dates: Jan 1992-Dec 1994 | Menopausal status (n [%]): | Detected by exam (n [%]): | T+ | 29 | 218 | 247 | —Other test results (CA-125) not given
| Size of population: | NR | NR | T- | 1 | 310 | 311 | —Not stated whether TVUS or abdominal US
| 558 | Race/ethnicity (n [%]): | Detected by imaging (n [%]): | Tot | 30 | 528 | 558 | Quality assessment:
| Other | NR | NR | | | Lower | Upper | Reference standard:+
| Case series | Risk factors (n [%]): | Combination (n [%]): | | Value | 95% CI | 95% CI | Verification bias:+
| Reference standard: | NR | NR | Se | 96.7% | 90.2% | 100.0% | Test reliability/variability: -
| Surgery | Inclusion criteria: | Additional data used for diagnosis: | Sp | 58.7% | 54.5% | 62.9% | Sample size: +
| Reference standard applied to all test negatives?: | NR | NR | PPV | 11.7% | 7.7% | 15.8% | Statistical tests: +
| Yes | Exclusion criteria: | | NPV | 99.7% | 99.0% | 100.0% | Blinding: -
| Test reliability established?: | Masses discovered at surgery | | 2) Low malignant potential = cancer | | | | Definition of +/- on screening test: +
| No | | | | Dis+ | Dis- | Tot
| Statistical tests used: | | | T+ | 43 | 204 | 247
| Se, Sp | | | T- | 2 | 309 | 311
| Blinding: | | | Tot | 45 | 513 | 558
| No | | | | | Lower | Upper
| Definition of positive and negative on screening test: | | | | Value | 95% CI | 95% CI
| Ultrasound “suspicious” if solid, mixed, mixed with calcified area, vegetations, cyst wall ≥ 3 mm, thick septa ≥ 3 mm, > 3 septae, multicystic, or ascites”; otherwise considered benign | | | Se | 95.6% | 89.5% | 100.0%
| | | | Sp | 60.2% | 56.0% | 64.5%
| | | | PPV | 17.4% | 12.7% | 22.1%
| | | | NPV | 99.4% | 98.5% | 100.0%
Carter, Iles, Neven, et al., 1993 | Geographical location: | Age: | Not specified | 1) CA - 125 | | | | Comments:
#6370 | England | NR | Symptomatic (n [%]): | Not enough data provided to stratify table by menopausal status | | | | ——Pre-study history (symptomatic vs. asymptomatic) not described
| Dates: NR | Menopausal status (n [%]): | NR | | Dis+ | Dis- | Tot | —Unclear how patients selected
| Size of population: | Pre (< 45): 86 | Detected by exam (n [%]): | T+ | 77 | 1 | 78 | —Recurrent disease included in sample
| 152 | Post (> 55): 66 | NR | T- | 10 | 64 | 74 | —CA-125 cutoff not clearly defined (35? 37.2?)
| Study type NR | Race/ethnicity (n [%]): | Detected by imaging (n [%]): | Tot | 87 | 65 | 152 | Quality assessment:
| Reference standard: | NR | NR | | | Lower | Upper | Reference standard: +
| Histology | Risk factors (n [%]): | Combination (n [%]): | | Value | 95% CI | 95% CI | Verification bias: +
| Reference standard applied to all test negatives?: | None | NR | Se | 88.5% | 81.8% | 95.2% | Test reliability/variability: +
| Yes | Inclusion criteria: | Additional data used for diagnosis: | Sp | 98.5% | 95.5% | 100.0% | Sample size: +
| Test reliability established?: | Presentation with pelvic mass | NR | PPV | 98.7% | 96.2% | 100.0% | Statistical tests: +
| For CA-125 | Exclusion criteria: | | NPV | 86.5% | 78.7% | 94.3% | Blinding: -
| Statistical tests used: | NR | | | | | | Definition of +/- on screening test: -
| None
| Blinding:
| NR
| Definition of positive and negative on screening test:
| “95% of normal blood samples have a CA-125 level < 37.2 u/ml” but not necessarily used
Carter, Lau, Fowler, et al., 1995 | Geographical location: | Age: | Symptomatic (n [%]): | 1) PI < 1.0 (AUC = 0.732 ± 0.069) | | | | Comments:
#4240 | Minneapolis, MN | Mean: 48.3 | NR | | Dis+ | Dis- | Tot | —No results by menopausal status
| Dates: NR | Menopausal status (n [%]): | Detected by exam (n [%]): | T+ | 13 | 21 | 34 | —Pre-study history (symptomatic vs. asymptomatic) not described
| Size of population: | Pre (< 45): 72 (58.5%) | NR | T- | 10 | 79 | 89 | Quality assessment:
| 123 women | Post (> 55): 51(41.5%) | Detected by imaging (n [%]): | Tot | 23 | 100 | 123 | Reference standard: +
| Other | Race/ethnicity (n [%]): | NR | | | Lower | Upper | Verification bias: +
| Consecutive | NR | Combination (n [%]): | | Value | 95% CI | 95% CI | Test reliability/variability: +/-
| Reference standard: | Risk factors (n [%]): | NR | Se | 57.0% | 36.8% | 77.2% | Sample size: -
| Histopathology or 12 month followup | NR | Additional data used for diagnosis: | Sp | 79.0% | 71.0% | 87.0% | Statistical tests: +
| Reference standard applied to all test negatives?: | Inclusion criteria: | NR | PPV | 38.2% | 21.9% | 54.6% | Blinding: +
| No, but those without operative intervention were followed by US for 12 months | Women with suspected adnexal mass presenting to University of Minn women's hospital | | NPV | 88.8% | 82.2% | 95.3% | Definition of +/- on screening test: +
| Test reliability established?: | Exclusion criteria: | | 2) RI < 0.4 (AUC = 0.684 ± 0.068)
| Yes | NR (everyone else) | | | Dis+ | Dis- | Tot
| Statistical tests used: | | | T+ | 5 | 4 | 9
| Se, Sp | | | T- | 18 | 96 | 114
| Chi-squared | | | Tot | 23 | 100 | 123
| ROC | | | | | Lower | Upper
| Blinding: | | | | Value | 95% CI | 95% CI
| NR but prospective study (but not blinded to clinical history) | | | Se | 22.0% | 5.1% | 38.9%
| Definition of positive and negative on screening test: | | | Sp | 96.0% | 92.2% | 99.8%
| Calculated from ROC curves | | | PPV | 55.6% | 23.1% | 88.0%
| Best P I< 1.0 | | | NPV | 84.2% | 77.5% | 90.9%
| RI < 0.4 | | | 2×2 table also calculable for
| | | | PI at cutoffs of 0.6, 0.8 and 1.4
| | | | RI at cutoffs of 0.6, 0.8 and 1.0
Caruso, Caforio, Testa, et al., 1996 | Geographical location: | Age: | Symptomatic (n [%]): | 1) Sasonne's criteria | | | | Comments:
#3810 | Rome, Italy | Mean (SD): 38.4 (16.5) | NR | | Dis+ | Dis- | Tot | —Aside from Valentin scoring system (which the authors described as “arbitrary”), no description of other scoring systems
| Dates: NR | Menopausal status (n [%]): | Detected by exam (n [%]): | T+ | 21 | 27 | 48 | —Their “vascular scoring system” - mostly subjective measurements save RI of 0.43 as RI cutoff.
| Size of population: | Pre: 88 (70.5%) | NR | T- | 0 | 74 | 74 | —Menopause not defined and unable to stratify. Statement in text must be error (“the % of postmenopausal women with benign and malignant lesions was 21 and 71% respectively”)
| 122 | Post: 36 (29.5%) | Detected by imaging (n [%]): | Tot | 21 | 101 | 122 | —Reported Se/Sp for Sassone criteria (Table 5) do not agree precisely with data reported in Fig 3
| Other | Race/ethnicity (n [%]): | NR | | | Lower | Upper | Quality assessment:
| Consecutive patients with diagnosis of adnexal mass scheduled for surgery | NR | Combination (n [%]): | | Value | 95% CI | 95% CI | Reference standard: +
| Reference standard: | Risk factors (n [%]): | NR | Se | 100.0% | 85.7% | 100.0% | Verification bias: +
| Histopathology | NR | Additional data used for diagnosis: | Sp | 73.3% | 64.6% | 81.9% | Test reliability/variability: ? for Sassonne, De Preist and Valentin (references given but no discussion of reliability)
| Reference standard applied to all test negatives?: | Inclusion criteria: | NR | PPV | 43.8% | 29.7% | 57.8% | + for “vascular score” - intraobserver CV was calculated for RI portion of the score on 10 patients and was 3.5 (+/-%)
| Yes | 122 consecutive patients with diagnosis of adnexal mass scheduled to undergo surgery at the study hospital | | NPV | 100.0% | 95.9% | 100.0% | Sample size: -
| Test reliability established?: | Exclusion criteria: | | 2) DePriest Score | | | | Statistical tests: +
| Sasonne's [3] - yes | NR | | | Dis+ | Dis- | Tot | Blinding: - to clinical history but prospective in that US preceded surgery
| DePriest {1} - ? | | | T+ | 21 | 31 | 52 | Definition of +/- on screening test: + for Valentin and vascular
| Valentine [2] - ? | | | T- | 0 | 70 | 70 | Others assumed from literature
| “Vascular score” - NO | | | Tot | 21 | 101 | 122
| Statistical tests used: | | | | | Lower | Upper
| Student's t test | | | | Value | 95% CI | 95% CI
| Fisher's exact test | | | Se | 100.0% | 85.7% | 100.0%
| Blinding: | | | Sp | 69.3% | 60.3% | 78.3%
| NR but US prior to surgery | | | PPV | 40.4% | 27.0% | 53.7%
| Definition of positive and negative on screening test: | | | NPV | 100.0% | 95.7% | 100.0%
| Sasonne and DePriest - not described | | | 3) Valentin score
| Valentine positive ≥ 3 (where 1 = unilocular cyst, 2 = multilocular cyst, 3 = unilocular solid cyst, 4 = multilocular solid tumor, 5 = solid tumor) | | | | Dis+ | Dis- | Tot
| “Vascular score” - [table1] ≥ 5 is positive (where 1 for vessels present, vascular location 1 for pericystic 2 for in solid part, 2 for randomly dispersed vessels, 2 for “smooth waveform”, 2 for lowest RI < 0.430 | | | T+ | 21 | 39 | 60
| | | | T- | 0 | 62 | 62
| | | | Tot | 21 | 101 | 122
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 100.0% | 85.7% | 100.0%
| | | | Sp | 61.4% | 51.9% | 70.9%
| | | | PPV | 35.0% | 22.9% | 47.1%
| | | | NPV | 100.0% | 95.2% | 100.0%
| | | | 4) Vascular score
| | | | | Dis+ | Dis- | Tot
| | | | T+ | 21 | 8 | 29
| | | | T- | 0 | 93 | 93
| | | | Tot | 21 | 101 | 122
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 100.0% | 85.7% | 100.0%
| | | | Sp | 92.1% | 86.8% | 97.3%
| | | | PPV | 72.4% | 56.1% | 88.7%
| | | | NPV | 100.0% | 96.8% | 100.0%
| | | | 5) Vascular score excluding the 6 patients with a score .+5 studied in luteal phase
| | | | | Dis+ | Dis- | Tot
| | | | T+ | 18 | 4 | 22
| | | | T- | 0 | 93 | 93
| | | | Tot | 18 | 97 | 115
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 100.0% | 83.3% | 100.0%
| | | | Sp | 96.0% | 92.1% | 99.9%
| | | | PPV | 81.8% | 65.7% | 97.9%
| | | | NPV | 100.0% | 96.8% | 100.0%
Chalas, Welshinger, Engellener, et al., 1992 | Geographical location: | Age: | Symptomatic (n [%]): | 1) CA-125 > 35 | | | | Comments:
#5100 | Stony Brook, NY | NR | NR | | Dis+ | Dis- | Tot | —LMP tumors grouped in with malignant
| Dates: May 1980-Apr 1990 | Menopausal status (n [%]): | Detected by exam (n [%]): | T+ | 60 | 8 | 68 | —Although Se, Sp reported for CA-125 and platelets for age > 50, no other numbers reported (no n); cannot do 2×2 table; reported Se for CA-125 74% < 50, 85% > 50, Sp 83% < 50, 88% > 50; for thrombocytosis, Se < 50 50%, > 50 60%; Sp < 50 83%, > 50 87%
| Size of population: | NR | NR | T- | 14 | 48 | 62 | —Se, Sp in abstract differ from those in table VI (which is consistent with calculations from table V)
| 288 (47 excluded) | Race/ethnicity (n [%]): | Detected by imaging (n [%]): | Tot | 74 | 56 | 130 | —Clinical presentation not described
| Other | NR | NR | | | Lower | Upper | Quality assessment:
| Series of patients at single center with pelvic mass who were operated on | Risk factors (n [%]): | Combination (n [%]): | | Value | 95% CI | 95% CI | Reference standard: +
| Reference standard: | NR | NR | Se | 81.1% | 72.2% | 90.0% | Verification bias: +
| Histopathology | Inclusion criteria: | Additional data used for diagnosis: | Sp | 85.7% | 76.5% | 94.9% | Test reliability/variability: +/-
| Reference standard applied to all test negatives?: | Women with pelvic mass diagnosis who underwent surgery in hospital during time frame | NR | PPV | 88.2% | 80.6% | 95.9% | Sample size: -
| Yes | Exclusion criteria: | | NPV | 77.4% | 67.0% | 87.8% | Statistical tests: +
| Test reliability established?: | 47 excluded because | | 2) Platelets > 400,000/microliter | | | | Blinding: +
| Yes for CA-125 | 1) lack of preop platelet count | | | Dis+ | Dis- | Tot | Definition of +/- on screening test: +
| No for platelet count | 2) underlying condition associated with thrombocytosis | | T+ | 78 | 16 | 94
| Statistical tests used: | | | T- | 61 | 86 | 147
| Chi-square | | | Tot | 139 | 102 | 241
| Se, Sp | | | | | Lower | Upper
| Blinding: | | | | Value | 95% CI | 95% CI
| NR | | | Se | 56.1% | 47.9% | 64.4%
| But prospective | | | Sp | 84.3% | 77.3% | 91.4%
| Definition of positive and negative on screening test: | | | PPV | 83.0% | 75.4% | 90.6%
| CA-125 > 35U/mL | | | NPV | 58.5% | 50.5% | 66.5%
| Platelets > 400,000/pico L
Chen, Schwartz, and Li, 1990 | Geographical location: | Age: 20–42 for healthy blood donors - age not provided for 92 patients with benign pelvic masses and 41 patients with malignant masses of whom 16 had ovarian cancer | Symptomatic (n [%]): | 1) CA-125 - serum (among the 92 women with benign masses and 16 patients with ovarian cancer) | | | | Comments:
#5330 | China | Menopausal status (n [%]): | NR | | Dis+ | Dis- | Tot | —Knew in advance what the diagnosis was, so don't know how this impacted outcomes.
| Dates: NR | NR | Detected by exam (n [%]): | T+ | 15 | 37 | 52 | —CA-125 ≥ 65 = +
| Size of population: | Race/ethnicity (n [%]): | NR | T- | 1 | 55 | 56 | —Borderline included in malignant
| 188 | NR | Detected by imaging (n [%]): | Tot | 16 | 92 | 108 | —Not prospective
| Other | Risk factors (n [%]): | NR | | | Lower | Upper | —Clinical presentation not described
| Convenience sample | NR | Combination (n [%]): | | Value | 95% CI | 95% CI | Quality assessment:
| Reference standard: | Inclusion criteria: | NR | Se | 93.8% | 82.0% | 100.0% | Reference standard: +
| Histology | 55 health female blood donors | Additional data used for diagnosis: | Sp | 59.8% | 49.8% | 69.8% | Verification bias: +
| Reference standard applied to all test negatives?: | 92 patients with benign pelvic masses | NR | PPV | 28.8% | 16.5% | 41.2% | Test reliability/variability: -
| Yes | 41 patients with malignant masses | | NPV | 98.2% | 94.7% | 100.0% | Sample size: -
| Test reliability established?: | Exclusion criteria: | | | | | | Only 8 ovarian cancers
| Yes | NR | | | | | | Statistical tests: +
| Statistical tests used: | | | | | | | Blinding: -
| Regression analyses | | | | | | | Definition of +/- on screening test: +
| Chi-square
| Blinding:
| NR
| Definition of positive and negative on screening test:
| CA-125 (serum) > 65 U/ml considered positive
Chen, Schwartz, Li, et al., 1988 | Geographical location: | Age: | Symptomatic (n [%]): | 1) CA-125 for 211 operative patients (> 35 U/ml = T+) | | | | Comments:
#6870 | Changsha, China | Mean (SD): | NR | | Dis+ | Dis- | Tot | —No follow up on “normal” patient group (especially the 2 with CA-125 > 35) therefore excluded from 2×2 table
| Dates: Sep 1985 - Aug 1986 | Benign masses 38 (11) | Detected by exam (n [%]): | T+ | 48 | 61 | 109 | —Borderline masses included in malignant group (there were 4)
| Size of population: | Malignant 43 (5) | NR | T- | 10 | 92 | 102 | —No description of how subjects chosen (consecutive NR)
| 211 preoperative | Menopausal status (n [%]): | Detected by imaging (n [%]): | Tot | 58 | 153 | 211 | —Most analyses use CA-125 > 65 as abnormal
| 44 normal patients | NR | NR | | | Lower | Upper | —This study illustrates the impact of excluding non-ovarian malignancies from the analysis
| Other | Race/ethnicity (n [%]): | Combination (n [%]): | | Value | 95% CI | 95% CI | Quality assessment:
| “Screening” for “normal” patients (but no follow up described) | NR | NR | Se | 82.8% | 73.1% | 92.5% | Reference standard: +
| For 211 - diagnosis of mass undergoing surgery at the hospital | Risk factors (n [%]): | Additional data used for diagnosis: | Sp | 60.1% | 52.3% | 67.9% | Verification bias: +
| Reference standard: | NR | NR | PPV | 44.0% | 34.7% | 53.4% | Test reliability/variability: +
| Histopathology | Inclusion criteria: | | NPV | 90.2% | 84.4% | 96.0% | Sample size: - not described
| Reference standard applied to all test negatives?: | “Normal” - normal physical exam and LFTs | | 2) CA-125 (> 35 U/ml = T+) limited to patients with epithelial ovarian cancer (excludes non-ovarian malignancies) | | | | Statistical tests: +
| Not to “normal” comparison group but to all of 211 preop patients. | 211 - “pelvic mass” who had surgery | | | Dis+ | Dis- | Tot | Blinding: - but testing before surgery
| Test reliability established?: | Exclusion criteria: | | T+ | 30 | 61 | 91 | Definition of +/- on screening test: +
| Yes | | | T- | 0 | 92 | 92
| Statistical tests used: | | | Tot | 30 | 153 | 183
| Se, Sp | | | | | Lower | Upper
| Blinding: | | | | Value | 95% CI | 95% CI
| NR but testing preceded surgery | | | Se | 100.0% | 90.0% | 100.0%
| Definition of positive and negative on screening test: | | | Sp | 60.1% | 52.3% | 67.9%
| CA-125 > 35 (see comments) | | | PPV | 33.0% | 23.3% | 42.6%
| | | | NPV | 100.0% | 96.7% | 100.0%
| | | | 2×2 tables also provided for cutoffs of > 65 U/ml and > 194 U/ml
Chou, Chang, Yao, et al., 1994 | Geographical location: | Age: | Symptomatic (n [%]): | 1) RI < 0.5 | | | | Comments:
#10930 | Taiwan, China | Mean: 38 | NR | | Dis+ | Dis- | Tot | —5 patients were premenarchal
| Dates: Jan 1991 - Feb 1993 | Range: 11–85 | Detected by exam (n [%]): | T+ | 22 | 7 | 29 | —Unclear why the 6 patients were excluded (did they have a diagnosis of ovarian cancer from previous surgery, etc?)
| Size of population: | Menopausal status (n [%]): | NR | T- | 3 | 76 | 79 | —Clinical pathway not described
| 108 | Pre (< 45): 89 (82.4%) | Detected by imaging (n [%]): | Tot | 25 | 83 | 108 | —Mostly TVUS, however, abdominal used for “those patients who had no sexual experience” - not stated how many there were
| Case Series | Post (> 55): 19 (17.6%) | NR | | | Lower | Upper | Quality assessment:
| Reference standard: | Race/ethnicity (n [%]): | Combination (n [%]): | | Value | 95% CI | 95% CI | Reference standard: +
| Histopathology | NR | NR | Se | 88.0% | 75.3% | 100.0% | Verification bias: +
| Reference standard applied to all test negatives?: | Risk factors (n [%]): | Additional data used for diagnosis: | Sp | 92.0% | 86.2% | 97.8% | Test reliability/variability: -
| Yes | NR | NR | PPV | 75.9% | 60.3% | 91.4% | Sample size: -
| Test reliability established?: | Inclusion criteria: | | NPV | 96.2% | 92.0% | 100.0% | Statistical tests: +
| Yes | Scheduled for surgery in time frame for mass | | 2) CA-125 > 35U/ml | | | | Blinding: -
| Statistical tests used: | Exclusion criteria: | | | Dis+ | Dis- | Tot | Definition of +/- on screening test: +
| Se, Sp | 6 excluded: 3 with ovarian CA, 1 with borderline tumor, and 2 with chronic tubal pregnancy | | T+ | 23 | 21 | 44
| Blinding: | | | T- | 2 | 62 | 64
| NR | | | Tot | 25 | 83 | 108
| Definition of positive and negative on screening test: | | | | | Lower | Upper
| RI > 0.5 | | | | Value | 95% CI | 95% CI
| CA-125 > 35U/ml | | | Se | 92.0% | 81.4% | 100.0%
| | | | Sp | 75.0% | 65.7% | 84.3%
| | | | PPV | 52.3% | 37.5% | 67.0%
| | | | NPV | 96.9% | 92.6% | 100.0%
| | | | 3) Combined CA-125 and RI
| | | | | Dis+ | Dis- | Tot
| | | | T+ | 25 | 2 | 27
| | | | T- | 0 | 81 | 81
| | | | Tot | 25 | 83 | 108
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 100.0% | 88.0% | 100.0%
| | | | Sp | 97.0% | 93.3% | 100.0%
| | | | PPV | 92.6% | 82.7% | 100.0%
| | | | NPV | 100.0% | 96.3% | 100.0%
Cohen, Escobar, Scharm, et al., 2001 | Geographical location: | Age: | Symptomatic (n [%]): | 1) 2D TVUS | | | | Comments:
#2460 | Chicago, IL | Mean (SD): | NR | | Dis+ | Dis- | Tot | —Very poor description of what constituted a positive test - questionable reproducibility
| Dates: Apr 1999-Jun 2000 | Pre - 32 | Detected by exam (n [%]): | T+ | 14 | 26 | 40 | —Doppler measurements not done in 2D modality only in 3D - so the study is comparing both 2D to 3D and no Doppler to Doppler.
| Size of population: | Post - 59 | NR | T- | 0 | 31 | 31 | —No use of quantitative Doppler criteria, e.g., RI or PI
| 71 women | Range: 22–80 | Detected by imaging (n [%]): | Tot | 14 | 57 | 71 | —No discussion of inter-, intra-observer reliability (especially given poor description of positive test)
| Other | Menopausal status (n [%]): | NR | | | Lower | Upper | —1 borderline tumor and 2 metastatic colon cancer included in 14 malignant cases
| Women referred for surgery at the same hospital | Pre: 40 | Combination (n [%]): | | Value | 95% CI | 95% CI | Quality assessment:
| Reference standard: | Post: 31 | NR | Se | 100.0% | 78.6% | 100.0% | Reference standard: +
| Histopathology | Race/ethnicity (n [%]): | Additional data used for diagnosis: | Sp | 54.0% | 41.1% | 66.9% | Verification bias: +
| Reference standard applied to all test negatives?: | NR | NR | PPV | 35.0% | 20.2% | 49.8% | Test reliability/variability: -
| Yes | Risk factors (n [%]): | | NPV | 100.0% | 90.3% | 100.0% | Sample size: -
| Test reliability established?: | NR | | 2) 2D plus 3D TVUS | | | | Statistical tests: +
| No - see comments | Inclusion criteria: | | | Dis+ | Dis- | Tot | Blinding: +
| Statistical tests used: | Known “complex” pelvic mass referred for preoperative US | | T+ | 14 | 14 | 28 | Definition of +/- on screening test: - poor definition
| Se, Sp | Exclusion criteria: | | T- | 0 | 43 | 43
| PPV, NPV | NR | | Tot | 14 | 57 | 71
| Blinding: | | | | | Lower | Upper
| No but US preoperative | | | | Value | 95% CI | 95% CI
| Definition of positive and negative on screening test: | | | Se | 100.0% | 78.6% | 100.0%
| “Any multiloculated, complex, or solid mass in which the echo architecture was not highly suggestive of benign histology was categorized as malignant” | | | Sp | 75.0% | 63.8% | 86.2%
| For 3D Doppler “masses with central vascular flow, vascular flow with in excrescences, or flow within septations were graded malignant” based on modified system by Guerriero (ref 9) | | | PPV | 50.0% | 31.5% | 68.5%
| | | | NPV | 100.0% | 93.0% | 100.0%
Davies, Jacobs, Woolas, et al., 1993 | Geographical location: | Age: | Symptomatic (n [%]): | 1) CA-125 > 30 U/mL | | | | Comments:
#4720 | London | NR | NR | | Dis+ | Dis- | Tot | —Standard CA-125 cutoff of 35 not examined
| Dates: NR | Menopausal status (n [%]): | Detected by exam (n [%]): | T+ | 28 | 22 | 50 | —US scoring system for RMI (Jacobs) not often used in other contexts
| Size of population: | Pre (< 45): 86 (69.4%) | NR | T- | 9 | 65 | 74 | —Clinical presentation not described
| 124 | Post (> 55): 38 (30.6%) | Detected by imaging (n [%]): | Tot | 37 | 87 | 124 | Quality assessment:
| Other | Race/ethnicity (n [%]): | NR | | | Lower | Upper | Reference standard: +
| Case series - Retrospective review of consecutive analysis of women with diagnosis of mass admitted to hospital for surgery | NR | Combination (n [%]): | | Value | 95% CI | 95% CI | Verification bias: +
| Reference standard: | Risk factors (n [%]): | NR | Se | 76.0% | 62.2% | 89.8% | Test reliability/variability: +; discussed
| Histopathology | NR | Additional data used for diagnosis: | Sp | 75.0% | 65.9% | 84.1% | Sample size: -
| Reference standard applied to all test negatives?: | Inclusion criteria: | NR | PPV | 56.0% | 42.2% | 69.8% | Statistical tests: +
| Yes | Consecutive women admitted to hospital for surgery in time frame | | NPV | 87.8% | 80.4% | 95.3% | Blinding: +
| Test reliability established?: | Exclusion criteria: | | 2) CA-125 > 50U/mL | | | | Definition of +/- on screening test: +
| Yes | NR | | | Dis+ | Dis- | Tot
| Statistical tests used: | | | T+ | 26 | 13 | 39
| RMI | | | T- | 11 | 74 | 85
| Se, Sp | | | Tot | 37 | 87 | 124
| Chi-square | | | | | Lower | Upper
| Students t test | | | | Value | 95% CI | 95% CI
| Mann-Whitney U test | | | Se | 70.0% | 55.2% | 84.8%
| Blinding: | | | Sp | 85.0% | 77.5% | 92.5%
| NR | | | PPV | 66.7% | 51.9% | 81.5%
| Definition of positive and negative on screening test: | | | NPV | 87.1% | 79.9% | 94.2%
| NR - because test of RMI, various cutoff values analyzed | | | 3) US > 1
| | | | | Dis+ | Dis- | Tot
| | | | T+ | 37 | 62 | 99
| | | | T- | 0 | 25 | 25
| | | | Tot | 37 | 87 | 124
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 100.0% | 91.9% | 100.0%
| | | | Sp | 29.0% | 19.5% | 38.5%
| | | | PPV | 37.4% | 27.8% | 46.9%
| | | | NPV | 100.0% | 88.0% | 100.0%
| | | | 4) US 3
| | | | | Dis+ | Dis- | Tot
| | | | T+ | 32 | 23 | 55
| | | | T- | 5 | 64 | 69
| | | | Tot | 37 | 87 | 124
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 87.0% | 76.2% | 97.8%
| | | | Sp | 74.0% | 64.8% | 83.2%
| | | | PPV | 58.2% | 45.1% | 71.2%
| | | | NPV | 92.8% | 86.6% | 98.9%
| | | | 5) Menopausal status alone
| | | | | Dis+ | Dis- | Tot
| | | | T+ | 32 | 36 | 68
| | | | T- | 5 | 51 | 56
| | | | Tot | 37 | 87 | 124
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 87.0% | 76.2% | 97.8%
| | | | Sp | 59.0% | 48.7% | 69.3%
| | | | PPV | 47.1% | 35.2% | 58.9%
| | | | NPV | 91.1% | 83.6% | 98.5%
DePriest, Gallion, Pavlik, et al., 1997 | Geographical location: | Age: | Symptomatic (n [%]): | 1) TVUS | | | | Comments:
#3650 | Kentucky | Mean: 58 | 0 (0%) | | Dis+ | Dis- | Tot | —Data not provided to stratify by menopausal status
| Dates: Dec 1987-Dec 1993 | Range: 30–92 | Detected by exam (n [%]): | T+ | 6 | 84 | 90 | —None of the cases with primary ovarian cancer who had CA-125 drawn had level > 35
| Size of population: | Menopausal status (n [%]): | NR | T- | 1 | 6379 | 6380 | —DePriest morphology index used
| 6470 | Numbers of women by menopausal status not specified although used as an entry criterion. | Detected by imaging (n [%]): | Tot | 7 | 6463 | 6470 | 90 operative cases
| Screening study | Race/ethnicity (n [%]): | NR | | | Lower | Upper | —% followup of normals not described
| Reference standard: | NR | Combination (n [%]): | | Value | 95% CI | 95% CI | Quality assessment:
| Histology and follow up | Risk factors (n [%]): | NR | Se | 85.7% | 59.8% | 100.0% | Reference standard: +
| Reference standard applied to all test negatives?: | Family history: | Additional data used for diagnosis: | Sp | 98.7% | 98.4% | 99.0% | Verification bias: -
| Followup applied | Ovarian cancer = 1597 (24%) | NR | PPV | 6.7% | 1.5% | 11.8% | Test reliability/variability: -
| Test reliability established?: | Breast cancer = 1976 (30%) | | NPV | 100.0% | 100.0% | 100.0% | Sample size: +
| NR | Colon cancer = 990 (15%) | | 2) For operative cases with morphology index < 4 | | | | Statistical tests: +
| Statistical tests used: | Inclusion criteria: | | | Dis+ | Dis- | Tot | Blinding: +; prospective US
| Fischers exact test | Asymptomatic postmenopausal women > 50 years of age | | T+ | 7 | 34 | 41 | Definition of +/- on screening test: +
| Blinding: | Asymptomatic women > 30 years of age with a documented history of ovarian cancer in at least one primary or secondary relative. | | T- | 0 | 49 | 49
| NR | Exclusion criteria: | | Tot | 7 | 83 | 90
| Definition of positive and negative on screening test: | Known ovarian tumor or personal history of ovarian cancer. | | | | Lower | Upper
| Ultrasound | | | | Value | 95% CI | 95% CI
| Ovarian volume >10 cm^3^ for postmenopausal women and > 20 cm^3^ for premenopausal | | | Se | 100.0% | 57.1% | 100.0%
| Cystic tumor with internal papillary or complex projections into its lumen was considered abnormal. | | | Sp | 59.0% | 48.5% | 69.6%
| Used an algorithm for disease detection | | | PPV | 17.1% | 5.6% | 28.6%
| If TVUS abnormal, repeat 4–6 weeks. If that's abnormal used additional tests and then surgery. If normal repeat TVUS in one year. | | | NPV | 100.0% | 93.9% | 100.0%
| If TVUS initially normal, repeat in one year.
DePriest, Shenson, Fried, et al., 1993 | Geographical location: | Age: | Symptomatic (n [%]): | 1) DePriest ≥ 5 | | | | Comments:
#6390 | Lexington, Kentucky USA | Mean (SD): pre 30.9 | NR | | Dis+ | Dis- | Tot | —Only n for postmenopause reported, unable to do stratified analysis
| University Hospital | Post 55.9 | Detected by exam (n [%]): | T+ | 13 | 28 | 41 | —No discussion of inter/intra observer variability
| Dates: Jan 1987 - Jan 1992 | Range: pre 3–47 | NR | T- | 0 | 80 | 80 | —No discussion of sample size calculation
| Size of population: | Post 44–74 | Detected by imaging (n [%]): | Tot | 13 | 108 | 121 | —Clinical presentation not described
| 121 | Menopausal status (n [%]): | NR | | | Lower | Upper | Quality assessment:
| Other | Pre (< 45): 62 (51.2%) | Combination (n [%]): | | Value | 95% CI | 95% CI | Reference standard: +
| Case series | Post (> 55): 59 (48.8%) | NR | Se | 100.0% | 76.9% | 100.0% | Verification bias: +
| Reference standard: | Race/ethnicity (n [%]): | Additional data used for diagnosis: | Sp | 74.1% | 65.8% | 82.3% | Test reliability/variability: -
| Histopathology | NR | NR | PPV | 31.7% | 17.5% | 46.0% | Sample size: -
| Reference standard applied to all test negatives?: | Risk factors (n [%]): | | NPV | 100.0% | 96.3% | 100.0% | Statistical tests: +/-
| Yes | NR | | | | | | Blinding: +/-
| Test reliability established?: | Inclusion criteria: | | | | | | Definition of +/- on screening test: +
| No | Prospecitive women with mass who had surgery in time frame
| Statistical tests used: | Exclusion criteria:
| T test for means | NR
| Chi-square and Fisher's exact test for proportions
| Blinding:
| NR (but prospective)
| Definition of positive and negative on screening test:
| Morphology index score ≥ 5 (Table 1)
DePriest, van Nagell Jr., Gallion, et al., 1993 | Geographical location: | Age: | Symptomatic (n [%]): | 1) US score ≥ 5 | | | | Comments:
#6880 | Kentucky USA | Mean: 60 | 0 (0%) | | Dis+ | Dis- | Tot | —Screening study
| University | Range: 33–90 | Detected by exam (n [%]): | T+ | 3 | 6 | 9 | —Test negatives had repeat US in 1 year (don't report compliance with follow up US, or results of those US)
| Dates: Nov 1987 - June 1992 | Menopausal status (n [%]): | NA | T- | 0 | 15 | 15 | —No discussion of reliability of DePriest index
| Size of population: | NR | Detected by imaging (n [%]): | Tot | 3 | 21 | 24 | Quality assessment:
| 44/3220 | Race/ethnicity (n [%]): | NA | | | Lower | Upper | Reference standard: +
| Screening study | NR | Combination (n [%]): | | Value | 95% CI | 95% CI | Verification bias: +/-
| Reference standard: | Risk factors (n [%]): | NR | Se | 100.0% | 0.0% | 100.0% | Test reliability/variability: -
| For women with abnormal TVUS - pathology | Family history: | Additional data used for diagnosis: | Sp | 71.4% | 52.1% | 90.8% | Sample size: -
| Reference standard applied to all test negatives?: | 502 (15.6%) ovarian CA | NR | PPV | 33.3% | 2.5% | 64.1% | Statistical tests: +/-
| No | 1034 (32.1%) breast CA | | NPV | 100.0% | 80.0% | 100.0% | Blinding: +
| Test reliability established?: | 678 (21.1%) colon CA | | | | | | Definition of +/- on screening test: +
| No | Inclusion criteria:
| Statistical tests used: | Volunteers for screening program at U of K
| Fischer's exact test | Exclusion criteria:
| Blinding: | Individuals with prior history of ovarian cancer or pelvic radiation
| NR - prospective
| Definition of positive and negative on screening test:
| US - ovarian volume > 10 cm^3^ or “cystic ovarian tumor with a papillary projection into its lumen”
| Also DePriest score also used (but unclear how used at what cutoff)
DePriest, Varner, Powell, et al., 1994 | Geographical location: | Age: | Symptomatic (n [%]): | 1) RI ≥ 0.5 | | | | Comments:
#10950 | USA | For benign tumors mean 44.9 with range (16–84) | NR | | Dis+ | Dis- | Tot | —LMP grouped in with malignant
| Dates: NR | For malignant mean 53.8 (25–78) | Detected by exam (n [%]): | T+ | 39 | 46 | 85 | —Good data on reliability/variability
| Size of population: | Menopausal status (n [%]): | NR | T- | 5 | 123 | 128 | —TVUS only
| 213 | NR | Detected by imaging (n [%]): | Tot | 44 | 169 | 213 | Quality assessment:
| Retrospective chart review with re-analysis of US data | Race/ethnicity (n [%]): | NR | | | Lower | Upper | Reference standard: +
| Reference standard: | NR | Combination (n [%]): | | Value | 95% CI | 95% CI | Verification bias: +
| Histopathology | Risk factors (n [%]): | NR | Se | 89.0% | 79.8% | 98.2% | Test reliability/variability:+
| Reference standard applied to all test negatives?: | NR | Additional data used for diagnosis: | Sp | 73.0% | 66.3% | 79.7% | Sample size: -
| Yes | Inclusion criteria: | NR | PPV | 45.9% | 35.3% | 56.5% | Statistical tests: +
| Test reliability established?: | NR | | NPV | 96.1% | 92.7% | 99.5% | Blinding: +
| Yes | Exclusion criteria: | | | | | | Definition of +/- on screening test: +
| Statistical tests used: | 11 patients excluded due to lack of US or surgical information
| Kappa statistic,
| Regression analysis
| Blinding:
| Yes
| Definition of positive and negative on screening test:
| DePriest morphology index score >=5
Dowd, Quinn, Rome, et al., 1993 | Geographical location: | Age: | Symptomatic (n [%]): | 1) CA-125 premenopausal | | | | Comments:
#4680 | Melbourne, AU | Range: 15–35 for premenopausal | NR | | Dis+ | Dis- | Tot | —Unable to construct 2×2 tables for stratified US results; reported values for premenopausal women: Sensitivity 63%, specificity 89%; postmenopausal, sensitivity 87%, specificity 75%
| Dates: 1978 to 1989 | Range: 40 –89 for post | Detected by exam (n [%]): | T+ | 32 | 21 | 53 | —LMP tumors grouped in with malignant
| Size of population: | Menopausal status (n [%]): | NR | T- | 11 | 57 | 68 | —Clinical presentation not described
| 264 patients total although not all had ultrasound, CA-125 and exam results | Pre (< 45): 121 | Detected by imaging (n [%]): | Tot | 43 | 78 | 121 | Quality assessment:
| Other | Post (> 55): 143 | NR | | | Lower | Upper | Reference standard: +
| Retrospective chart review | Race/ethnicity (n [%]): | Combination (n [%]): | | Value | 95% CI | 95% CI | Verification bias: +
| Reference standard: | NR | NR | Se | 74.0% | 60.9% | 87.1% | Test reliability/variability:
| Pathology | Risk factors (n [%]): | Additional data used for diagnosis: | Sp | 73.0% | 63.1% | 82.9% | Sample size: +
| Reference standard applied to all test negatives?: | NR | NR | PPV | 60.4% | 47.2% | 73.5% | Statistical tests: +
| Yes | Inclusion criteria: | | NPV | 83.8% | 75.1% | 92.6% | Blinding: - to clinical history
| Test reliability established?: | Patients who had CA-125 performed in presence of pelvic mass | | 2) CA-125 post menopausal | | | | Definition of +/- on screening test: +
| NR | Exclusion criteria: | | | Dis+ | Dis- | Tot
| Statistical tests used: | Test performed for screening purposes only, in absence of pelvic mass excluded | | T+ | 80 | 9 | 89
| Chi square or Fishers | Inadequate documentation for pathology. | | T- | 13 | 41 | 54
| Blinding: | | | Tot | 93 | 50 | 143
| Tried to predict disease outcome based on clinical exam and ultrasound | | | | | Lower | Upper
| Definition of positive and negative on screening test: | | | | Value | 95% CI | 95% CI
| CA ≤ 35 u/ml considered normal | | | Se | 86.0% | 78.9% | 93.1%
| US impression of reviewer drawn from US report (not film review): “simple, smooth, and/or unilateral likely to be benign; “solid or mixed consistency, bilateral, irregular or associated ascites...likely malignancy” | | | Sp | 82.0% | 71.4% | 92.6%
| Clinical exam: “mass hard, irregular, fixed, attached to other structures.” | | | PPV | 89.9% | 83.6% | 96.2%
| | | | NPV | 75.9% | 64.5% | 87.3%
| | | | 3) CA-125 all patients
| | | | | Dis+ | Dis- | Tot
| | | | T+ | 112 | 30 | 142
| | | | T- | 24 | 98 | 122
| | | | Tot | 136 | 128 | 264
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 82.4% | 75.9% | 88.8%
| | | | Sp | 76.6% | 69.2% | 83.9%
| | | | PPV | 78.9% | 72.2% | 85.6%
| | | | NPV | 80.3% | 73.3% | 87.4%
| | | | 4) Ultrasound all patients
| | | | | Dis+ | Dis- | Tot
| | | | T+ | 61 | 17 | 78
| | | | T- | 14 | 90 | 104
| | | | Tot | 75 | 108 | 183
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 81.0% | 72.1% | 89.9%
| | | | Sp | 84.0% | 77.1% | 90.9%
| | | | PPV | 78.0% | 68.8% | 87.2%
| | | | NPV | 86.0% | 79.3% | 92.7%
Einhorn, Bast Jr., Knapp, et al., 1986 | Geographical location: | Age: | Symptomatic (n [%]): | 1) CA-125 > 35 (excluding non-ovarian primary) | | | | Comments:
#6860 | Sweden | NR | NR | | Dis+ | Dis- | Tot | —Borderline tumors included in malignant
| Dates: Since 1983 - dates unclear | Menopausal status (n [%]): | Detected by exam (n [%]): | T+ | 14 | 9 | 23 | —Slight difference in 2×2 table specificity calculated here (89%) and from text (93%)
| Size of population: | NR | NR | T- | 4 | 73 | 77 | —No statistical tests of significance
| 100 | Race/ethnicity (n [%]): | Detected by imaging (n [%]): | Tot | 18 | 82 | 100 | Quality assessment:
| Other | Swedish | NR | | | Lower | Upper | Reference standard: +
| Retrospective comparison of serum samples with operative outcomes | Risk factors (n [%]): | Combination (n [%]): | | Value | 95% CI | 95% CI | Verification bias: +
| Reference standard: | NR | NR | Se | 77.8% | 58.6% | 97.0% | Test reliability/variability: +
| Histopathology | Inclusion criteria: | Additional data used for diagnosis: | Sp | 89.0% | 82.3% | 95.8% | Sample size: -
| Reference standard applied to all test negatives?: | Patients with pelvic mass who had surgery | NR | PPV | 60.9% | 40.9% | 80.8% | Statistical tests: -
| Yes | For whom banked serum present | | NPV | 94.8% | 89.8% | 99.8% | Blinding: -
| Test reliability established?: | Exclusion criteria: | | 2) CA-125 > 35 (includes metastatic disease) | | | | Definition of +/- on screening test: +
| Yes | NR | | | Dis+ | Dis- | Tot
| Statistical tests used: | | | T+ | 18 | 5 | 23
| Se, Sp | | | T- | 5 | 72 | 77
| Blinding: | | | Tot | 23 | 77 | 100
| NR | | | | | Lower | Upper
| Definition of positive and negative on screening test: | | | | Value | 95% CI | 95% CI
| CA-125 > 35 U/ml | | | Se | 78.3% | 61.4% | 95.1%
| | | | Sp | 93.5% | 88.0% | 99.0%
| | | | PPV | 78.3% | 61.4% | 95.1%
| | | | NPV | 93.5% | 88.0% | 99.0%
| | | | 2) CA-125 > 35 (classifying borderline as “benign”
| | | | | Dis+ | Dis- | Tot
| | | | T+ | 16 | 7 | 23
| | | | T- | 5 | 72 | 77
| | | | Tot | 21 | 79 | 100
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 76.2% | 58.0% | 94.4%
| | | | Sp | 91.1% | 84.9% | 97.4%
| | | | PPV | 69.6% | 50.8% | 88.4%
| | | | NPV | 93.5% | 88.0% | 99.0%
Ekerhovd, Wienerroith, Staudach, et al, 2001 | Geographical location: | Age: | Symptomatic (n [%]): | 1) Low malignant potential = benign, presence of solid areas or papillations = positive test | | | | Comments:
#8780 | Salzburg, Austria, and Goteborg, Sweden | Range: 14–90 | NR | | Dis+ | Dis- | Tot | —TVUS only
| Dates: Jan 1992-Dec 1997 | NR for entire group | Detected by exam (n [%]): | T+ | 13 | 631 | 644 | Quality assessment:
| Size of population: | Menopausal status (n [%]): | NR | T- | 4 | 656 | 660 | Reference standard: +
| 1304 | Pre (< 45): 927 (71.1%) | Detected by imaging (n [%]): | Tot | 17 | 1287 | 1304 | Verification bias: +
| Other | Post (> 55):377 (28.9%) | NR | | | Lower | Upper | Test reliability/variability: -
| Case series of all women with unilocular adnexal cyst on transvaginal US | Race/ethnicity (n [%]): | Combination (n [%]): | | Value | 95% CI | 95% CI | Sample size: +
| Reference standard: | NR | NR | Se | 76.5% | 56.3% | 96.6% | Statistical tests:+
| Surgery | Risk factors (n [%]): | Additional data used for diagnosis: | Sp | 51.0% | 48.2% | 53.7% | Blinding: -
| Reference standard applied to all test negatives?: | NR | NR | PPV | 2.0% | 0.9% | 3.1% | Definition of +/- on screening test: +
| Yes | Inclusion criteria: | | NPV | 99.4% | 98.8% | 100.0%
| Test reliability established?: | Scheduled for surgery and unilocular cyst | | 2) Low malignant potential = cancer
| No | Exclusion criteria: | | | Dis+ | Dis- | Tot
| Statistical tests used: | Presence of internal septae | | T+ | 24 | 620 | 644
| t-test, chi-square | | | T- | 7 | 653 | 660
| Blinding: | | | Tot | 31 | 1273 | 1304
| Definition of positive and negative on screening test: | | | | | Lower | Upper
| Suspicious: unilocular with small solid areas or papillary formation | | | | Value | 95% CI | 95% CI
| Benign: Simple cysts | | | Se | 77.4% | 62.7% | 92.1%
| | | | Sp | 51.3% | 48.6% | 54.0%
| | | | PPV | 3.7% | 2.3% | 5.2%
| | | | NPV | 98.9% | 98.2% | 99.7%
Fenchel, Grab, Nuessle, et al., 2002 | Geographical location: | Age: | Symptomatic (n [%]): | 1) Combined US and Doppler | | | | Comments:
#2220 | Ulm, Germany | Mean (SD):46(15) | 0 (0%) | | Dis+ | Dis- | Tot | —Three different US scores used (DePriest, Kawai, and RI) - although each is well described, how each contributed to the overall diagnosis for this study is not discussed (used in series, or in parallel?)
| University hospital | Range: 18–83 | Detected by exam (n [%]): | T+ | 11 | 35 | 46 | —Hospital referrals - not population-based
| Dates: May 1997 - Feb 1999 | Menopausal status (n [%]): | NR | T- | 1 | 52 | 53 | —Borderline tumors (LMP = 2) probably included in malignant category (unclear - but no examples of borderline in benign tumor descriptions)
| Size of population: | NR | Detected by imaging (n [%]): | Tot | 12 | 87 | 99 | —May be same patient population as Grab #2720
| 99 women | Race/ethnicity (n [%]): | NR | | | Lower | Upper | Quality assessment:
| Other | NR | Combination (n [%]): | | Value | 95% CI | 95% CI | Reference standard: +/-; length of time for followup for one non-surgical case not described
| Consecutive patients referred to hospital | Risk factors (n [%]): | NR | Se | 92.0% | 76.7% | 100.0% | Verification bias: -; not discussed
| Reference standard: | NR | Additional data used for diagnosis: | Sp | 60.0% | 49.7% | 70.3% | Test reliability/variability: + for component US tests, however it is unclear how these were grouped together for this study's single diagnostic assessment
| Histopathology | Inclusion criteria: | NR | PPV | 23.9% | 11.6% | 36.2% | Other tests -
| Reference standard applied to all test negatives?: | Consecutive, asymptomatic “sonographically suspect” (by referring physician adnexal mass referred to hospital | | NPV | 98.1% | 94.5% | 100.0% | Sample size: -
| 97 had histopathology, | Exclusion criteria: | | 2) MRI | | | | Statistical tests: +
| 1 had cytology | Pregnant women, clinical symptoms of malignancy, under 18 years | | | Dis+ | Dis- | Tot | Blinding: +
| 1 US follow up | | | T+ | 10 | 15 | 25 | Definition of +/- on screening test: +/-
| Test reliability established?: | | | T- | 2 | 72 | 74
| No for PET | | | Tot | 12 | 87 | 99
| Yes for US | | | | | Lower | Upper
| ? for MRI | | | | Value | 95% CI | 95% CI
| Statistical tests used: | | | Se | 83.0% | 61.7% | 100.0%
| Se, Sp, PPV, NPV | | | Sp | 83.0% | 75.1% | 90.9%
| Blinding: | | | PPV | 40.0% | 20.8% | 59.2%
| Yes | | | NPV | 97.3% | 93.6% | 100.0%
| Definition of positive and negative on screening test: | | | 3) FDG PET
| For PET - “interpreted visually in consensus” by “2 or 3 experiences nuclear med physicians | | | | Dis+ | Dis- | Tot
| For FDG uptake - “subjective” scale | | | T+ | 7 | 21 | 28
| US DePriest,(≥ 5), Kawai (9–12 = malignant) and Doppler RI < 0.45 = malignant | | | T- | 5 | 66 | 71
| | | | Tot | 12 | 87 | 99
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 58.0% | 30.1% | 85.9%
| | | | Sp | 76.0% | 67.0% | 85.0%
| | | | PPV | 25.0% | 9.0% | 41.0%
| | | | NPV | 93.0% | 87.0% | 98.9%
Ferdeghini, Gadducci, Prontera, et al., 1993 | Geographical location: | Age: | Symptomatic (n [%]): | 1) CA-125 | | | | Comments:
#4710 | Italy | Median (with range): | NR | | Dis+ | Dis- | Tot | —CA-125 ≥ 83 U/ml
| Dates: NR | Ovarian cancer = 60 (35–91) | Detected by exam (n [%]): | T+ | 42 | 9 | 51 | Quality assessment:
| Size of population: | Benign = 35 (13 – 76) | NR | T- | 12 | 120 | 132 | Reference standard: +
| 183 | Menopausal status (n [%]): | Detected by imaging (n [%]): | Tot | 54 | 129 | 183 | Verification bias: +
| Other | NR | NR | | | Lower | Upper | Test reliability/variability: -
| 2 retrospective samples: one if cancer one if benign - both consecutive | Race/ethnicity (n [%]): | Combination (n [%]): | | Value | 95% CI | 95% CI | Sample size: +
| Reference standard: | NR | NR | Se | 77.8% | 66.7% | 88.9% | Statistical tests:+
| Histology | Risk factors (n [%]): | Additional data used for diagnosis: | Sp | 93.0% | 88.6% | 97.4% | Blinding: +
| Reference standard applied to all test negatives?: | NR | NR | PPV | 82.4% | 71.9% | 92.8% | Definition of +/- on screening test: +
| Yes | Inclusion criteria: | | NPV | 90.9% | 86.0% | 95.8%
| Test reliability established?: | Had pre-operative levels of SIL-2R and CA-125
| No | Exclusion criteria:
| Statistical tests used: | Autoimmune or rheumatic disease
| Student t test
| Chi square
| Fishers exact test
| Blinding:
| NR
| Definition of positive and negative on screening test:
| CA-125 ≥ 83 U/ml.
Ferrazzi, Zanetta, Dordoni, et al., 1997 | Geographical location: | Age: | Symptomatic (n [%]): | 1) This study > 9 | | | | Comments:
#3570 | Milan, Italy | Mean (SD): 45 (16) | NR | | Dis+ | Dis- | Tot | —No discussion of inter/intra observer reliability variability with this new scoring system
| University | Range: 19–89 | Detected by exam (n [%]): | T+ | 60 | 86 | 146 | —No power calculation for study
| Dates: 1995-96 (2 yrs) | Menopausal status (n [%]): | NR | T- | 9 | 175 | 184 | —Good use of ROC curves and testing between curves
| Size of population: | NR | Detected by imaging (n [%]): | Tot | 69 | 261 | 330 | Quality assessment:
| 330 masses | Race/ethnicity (n [%]): | NR | | | Lower | Upper | Reference standard: +
| Other | NR | Combination (n [%]): | | Value | 95% CI | 95% CI | Verification bias: +
| Case series in multi-center | Risk factors (n [%]): | NR | Se | 87.0% | 79.1% | 94.9% | Test reliability/variability: -
| Reference standard: | NR | Additional data used for diagnosis: | Sp | 67.0% | 61.3% | 72.7% | Sample size: -
| Pathology | Inclusion criteria: | NR | PPV | 41.1% | 33.1% | 49.1% | Statistical tests: +
| Reference standard applied to all test negatives?: | Surgery within 7 days of US, detailed pathology available, women with mass in time frame at three hospitals in Italy | | NPV | 95.1% | 92.0% | 98.2% | Blinding: +
| Yes | Exclusion criteria: | | 2) Sassone > 9 | | | | Definition of +/- on screening test: +/-
| Test reliability established?: | NR | | | Dis+ | Dis- | Tot
| Sassone - yes | | | T+ | 51 | 91 | 142
| DePriest - yes | | | T- | 18 | 170 | 188
| This study - no | | | Tot | 69 | 261 | 330
| Statistical tests used: | | | | | Lower | Upper
| ROC curve | | | | Value | 95% CI | 95% CI
| Blinding: | | | Se | 74.0% | 63.7% | 84.3%
| NR - prospective | | | Sp | 65.0% | 59.2% | 70.8%
| Definition of positive and negative on screening test: | | | PPV | 35.9% | 28.0% | 43.8%
| Sassone (per original article) > 9 | | | NPV | 90.4% | 86.2% | 94.6%
| DePriest (per original article) > 5 | | | 3) DePriest
| This study - Table 2 > 9 | | | | Dis+ | Dis- | Tot
| | | | T+ | 61 | 157 | 218
| | | | T- | 8 | 104 | 112
| | | | Tot | 69 | 261 | 330
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 88.0% | 80.3% | 95.7%
| | | | Sp | 40.0% | 34.1% | 45.9%
| | | | PPV | 28.0% | 22.0% | 33.9%
| | | | NPV | 92.9% | 88.1% | 97.6%
Finkler, Benacerraf, Lavin, et al., 1988 | Geographical location: | Age: | Symptomatic (n [%]): | 1) Original ultrasound - premenopausal | | | | Comments:
#1230 | Boston, MA | Mean: 45.2 | NR | | Dis+ | Dis- | Tot | —Original US based on impression of cancer vs. benign only
| Dates: Nov 1986 to Apr 1987 | Range: 17–84 | Detected by exam (n [%]): | T+ | 2 | 2 | 4 | —“Specialist” US used scoring system
| Size of population: | Menopausal status | NR | T- | 16 | 54 | 70 | —Unclear if “specialist” US was blinded
| 131 consecutive patients | (n [%]): 74 | Detected by imaging (n [%]): | Tot | 18 | 56 | 74 | —Abdominal US - no TVUS
| 106 eventually retained | Pre (< 45): | NR | | | Lower | Upper | —CA-125 significantly improved positive and negative predictive values in postmenopausal women when added to clinical impression or prior ultrasound
| Other | Peri (45–55): | Combination (n [%]): | | Value | 95% CI | 95% CI | Quality assessment:
| Prospective series | Post (> 55): | NR | Se | 11.0% | 0.00% | 25.5% | Reference standard: +
| Reference standard: | Race/ethnicity (n [%]): | Additional data used for diagnosis: | Sp | 96.0% | 90.9% | 100.0% | Verification bias: +
| Pathology | NR | NR | PPV | 50.0% | 1.0% | 99.0% | Test reliability/variability: -
| Reference standard applied to all test negatives?: | Risk factors (n [%]): | | NPV | 77.1% | 67.3% | 87.0% | Sample size: - ; underpowered
| Yes | NR | | 2) Specialist ultrasound - premenopausal | | | | Statistical tests: +
| Test reliability established?: | Inclusion criteria: | | T+ | 9 | 2 | 11 | Blinding: -
| NR | Ovarian mass who were scheduled to under exploratory laparotomy | | T- | 9 | 54 | 63 | Definition of +/- on screening test: +
| Statistical tests used: | Had a pre-operative ultrasound | | Tot | 18 | 56 | 74
| Fisher's exact | Consecutive patients | | | | Lower | Upper
| Blinding: | Exclusion criteria: | | | Value | 95% CI | 95% CI
| Yes | Original ultrasound unavailable or uninterpretable. | | Se | 50.0% | 26.9% | 73.1%
| Definition of positive and negative on screening test: | Pregnant or with histologic cancer diagnosis | | Sp | 96.0% | 90.9% | 100.0%
| CA-125 > 35 U/mL considered positive US had two evaluations first (Table 1) Finkler score ≥ 7 = malignant second Primary US = impression only | | | PPV | 81.8% | 59.0% | 100.0%
| | | | NPV | 85.7% | 77.1% | 94.4%
| | | | 3) CA-125 - premenopausal
| | | | | Dis+ | Dis- | Tot
| | | | T+ | 9 | 17 | 26
| | | | T- | 9 | 39 | 48
| | | | Tot | 18 | 56 | 74
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 50.0% | 26.9% | 73.1%
| | | | Sp | 69.0% | 56.9% | 81.1%
| | | | PPV | 34.6% | 16.3% | 52.9%
| | | | NPV | 81.3% | 70.2% | 92.3%
| | | | 4) Original US - postmenopausal
| | | | | Dis+ | Dis- | Tot
| | | | T+ | 9 | 2 | 11
| | | | T- | 10 | 11 | 21
| | | | Tot | 19 | 13 | 32
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 47.0% | 24.6% | 69.4%
| | | | Sp | 85.0% | 65.6% | 100.0%
| | | | PPV | 81.8% | 59.0% | 100.0%
| | | | NPV | 52.4% | 31.0% | 73.7%
| | | | 5) Specialist US - postmenopausal
| | | | | Dis+ | Dis- | Tot
| | | | T+ | 15 | 1 | 16
| | | | T- | 4 | 12 | 16
| | | | Tot | 19 | 13 | 32
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 78.0% | 59.4% | 96.6%
| | | | Sp | 92.0% | 77.3% | 100.0%
| | | | PPV | 93.8% | 81.9% | 100.0%
| | | | NPV | 75.0% | 53.8% | 96.2%
| | | | 6) CA-125 - postmenopausal
| | | | | Dis+ | Dis- | Tot
| | | | T+ | 16 | 1 | 17
| | | | T- | 3 | 12 | 15
| | | | Tot | 19 | 13 | 32
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 84.0% | 67.5% | 100.0%
| | | | Sp | 92.0% | 77.3% | 100.0%
| | | | PPV | 94.1% | 82.9% | 100.0%
| | | | NPV | 80.0% | 59.8% | 100.0%
| | | | 7) CA-125 - all ages combined
| | | | | Dis+ | Dis- | Tot
| | | | T+ | 25 | 18 | 43
| | | | T- | 12 | 51 | 63
| | | | Tot | 37 | 69 | 106
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 67.6% | 52.5% | 82.7%
| | | | Sp | 73.9% | 63.6% | 84.3%
| | | | PPV | 58.1% | 43.4% | 72.9%
| | | | NPV | 81.0% | 71.3% | 90.6%
| | | | 8) US total
| | | | | Dis+ | Dis- | Tot
| | | | T+ | 24 | 55 | 79
| | | | T- | 22 | 68 | 90
| | | | Tot | 46 | 123 | 169
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 52.2% | 37.7% | 66.6%
| | | | Sp | 55.3% | 46.5% | 64.1%
| | | | PPV | 30.4% | 20.2% | 40.5%
| | | | NPV | 75.6% | 66.7% | 84.4%
Fleischer, Rodgers, Kepple, et al., 1992 | Geographical location: | Age: | Symptomatic (n [%]): | 1) Doppler | | | | Comments:
#6460 | Nashville, TN | NR | NR | | Dis+ | Dis- | Tot | —2×2 tables different if pull data from text or from Table 2
| Dates: NR | Menopausal status (n [%]): | Detected by exam (n [%]): | T+ | 17 | 1 | 18 | —Table 2 and text confuse positive/negative predictive value and sensitivity/specificity
| Size of population: | NR | NR | T- | 3 | 41 | 44 | Quality assessment:
| 62 | Race/ethnicity (n [%]): | Detected by imaging (n [%]): | Tot | 20 | 42 | 62 | Reference standard: +
| Other | NR | NR | | | Lower | Upper | Verification bias: +
| Case series | Risk factors (n [%]): | Combination (n [%]): | | Value | 95% CI | 95% CI | Test reliability/variability: +/-
| Reference standard: | NR | NR | Se | 85.0% | 69.4% | 100.0% | Sample size: -
| Pathology | Inclusion criteria: | Additional data used for diagnosis: | Sp | 97.6% | 93.0% | 100.0% | Statistical tests: -
| Reference standard applied to all test negatives?: | NR - mass - surgery - US | NR | PPV | 94.4% | 83.9% | 100.0% | Blinding: -
| Yes | Exclusion criteria: | | NPV | 93.2% | 85.7% | 100.0% | Definition of +/- on screening test: +
| Test reliability established?: | NR
| No
| Statistical tests used:
| Se, Sp
| Blinding:
| NR
| Definition of positive and negative on screening test:
| PI < 1.0
Franchi, Beretta, Ghezzi, et al., 1995 | Geographical location: | Age: | Symptomatic (n [%]): | 1) Premenopausal - CA-125 | | | | Comments:
#6270 | Italy | Median: 44 | NR | | Dis+ | Dis- | Tot | —ROC curves used to generate RI cutoff
| Dates: Jan 1991 to Dec 1993 | Range: 12–91 | Detected by exam (n [%]): | T+ | 8 | 26 | 34 | —CA-125 > 40 U/ml
| Size of population: | Menopausal status (n [%]): | NR | T- | 3 | 46 | 49 | —No US scoring system - descriptive only
| 129 | Pre (< 45): 83 (64.3%) | Detected by imaging (n [%]): | Tot | 11 | 72 | 83 | Quality assessment:
| Screening study | Peri (45–55): NR | NR | | | Lower | Upper | Reference standard: +
| Case series | Post (> 55): NR | Combination (n [%]): | | Value | 95% CI | 95% CI | Verification bias: +
| Reference standard: | Race/ethnicity (n [%]): | NR | Se | 72.7% | 46.4% | 99.0% | Test reliability/variability: -
| Pathology | Italian | Additional data used for diagnosis: | Sp | 63.8% | 52.7% | 74.9% | Sample size: +
| Reference standard applied to all test negatives?: | Risk factors (n [%]): | NR | PPV | 23.5% | 9.3% | 37.8% | Statistical tests: +
| Yes | NR | | NPV | 93.9% | 87.2% | 100.0% | Blinding: -
| Test reliability established?: | Inclusion criteria: | | 2) Premenopausal - Sonography | | | | Definition of +/- on screening test: +
| NR | Abnormal findings on pelvic exam and 2D sonographic features of adnexal mass | | | Dis+ | Dis- | Tot
| Statistical tests used: | Exclusion criteria: | | T+ | 8 | 10 | 18
| Mann-Witney U | NR | | T- | 3 | 62 | 65
| ROC curves | | | Tot | 11 | 72 | 83
| Blinding: | | | | | Lower | Upper
| US blinded to lab results | | | | Value | 95% CI | 95% CI
| Definition of positive and negative on screening test: | | | Se | 72.7% | 46.4% | 99.0%
| 2D Ultrasound: | | | Sp | 86.1% | 78.1% | 94.1%
| Maximum diameter (5 cm), solid areas, high echogenicity, multilocular appearance, irregular borders, papillary intracystic vegetations, presence of ascites | | | PPV | 44.4% | 21.5% | 67.4%
| Color Doppler Imaging | | | NPV | 95.4% | 90.3% | 100.0%
| RI = systolic peak - diastolic peak/systolic peak. Artery with lowest RI considered to indicate the malignant potential of the tumor. | | | 3) Combined ages
| RI < 0.65 | | | | Dis+ | Dis- | Tot
| CA-125 ≥ 40UI/ml suspected of malignant pelvic tumor | | | T+ | 31 | 15 | 46
| | | | T- | 6 | 77 | 83
| | | | Tot | 37 | 92 | 129
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 83.8% | 71.9% | 95.7%
| | | | Sp | 83.7% | 76.1% | 91.2%
| | | | PPV | 67.4% | 53.8% | 80.9%
| | | | NPV | 92.8% | 87.2% | 98.3%
| | | | 4) Premenopausal - Color Doppler Imaging
| | | | | Dis+ | Dis- | Tot
| | | | T+ | 9 | 20 | 29
| | | | T- | 2 | 52 | 54
| | | | Tot | 11 | 72 | 83
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 81.8% | 59.0% | 100.0%
| | | | Sp | 72.2% | 61.9% | 82.5%
| | | | PPV | 31.0% | 14.2% | 47.9%
| | | | NPV | 96.3% | 91.3% | 100.0%
| | | | 5) Color Doppler Imaging - combined ages
| | | | | Dis+ | Dis- | Tot
| | | | T+ | 30 | 26 | 56
| | | | T- | 7 | 66 | 73
| | | | Tot | 37 | 92 | 129
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 81.1% | 68.5% | 93.7%
| | | | Sp | 71.7% | 62.5% | 80.9%
| | | | PPV | 53.6% | 40.5% | 66.6%
| | | | NPV | 90.4% | 83.7% | 97.2%
| | | | 6) Postmenopausal - CA-125
| | | | | Dis+ | Dis- | Tot
| | | | T+ | 20 | 3 | 23
| | | | T- | 6 | 17 | 23
| | | | Tot | 26 | 20 | 46
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 76.9% | 60.7% | 93.1%
| | | | Sp | 85.0% | 69.4% | 100.0%
| | | | PPV | 87.0% | 73.2% | 100.0%
| | | | NPV | 73.9% | 56.0% | 91.9%
| | | | 7) All ages CA-125
| | | | | Dis+ | Dis- | Tot
| | | | T+ | 28 | 29 | 57
| | | | T- | 9 | 63 | 72
| | | | Tot | 37 | 92 | 129
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 75.7% | 61.9% | 89.5%
| | | | Sp | 68.5% | 59.0% | 78.0%
| | | | PPV | 49.1% | 36.1% | 62.1%
| | | | NPV | 87.5% | 79.9% | 95.1%
| | | | 8) Postmenopausal - Sonography
| | | | | Dis+ | Dis- | Tot
| | | | T+ | 23 | 5 | 28
| | | | T- | 3 | 15 | 18
| | | | Tot | 26 | 20 | 46
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 88.5% | 76.2% | 100.0%
| | | | Sp | 75.0% | 56.0% | 94.0%
| | | | PPV | 82.1% | 68.0% | 96.3%
| | | | NPV | 83.3% | 66.1% | 100.0%
| | | | 9) Postmenopausal - Color Doppler Imaging
| | | | | Dis+ | Dis- | Tot
| | | | T+ | 21 | 6 | 27
| | | | T- | 5 | 14 | 19
| | | | Tot | 26 | 20 | 46
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 81.8% | 67.0% | 96.6%
| | | | Sp | 72.2% | 52.6% | 91.8%
| | | | PPV | 77.8% | 62.1% | 93.5%
| | | | NPV | 73.7% | 53.9% | 93.5%
Gadducci, Baicchi, Marrai, et al., 1996 | Geographical location: | Age: | Symptomatic (n [%]): | 1) CA-125 > 65 U/ml - premenopause | | | | Comments:
#6230 | Pisa, Italy | NR | NR | | Dis+ | Dis- | Tot | —Most of the 124 patients in this study were included in Gadducci et al., 1988 (#6650)
| University Hospital | Menopausal status (n [%]): | Detected by exam (n [%]): | T+ | 8 | 4 | 12 | —Age breakdown or definition of menopause not described - however, this article stratifies results by menopausal status.
| Dates: NR | Pre: 57 (47.1%) | NR | T- | 4 | 41 | 45 | —Cutoff for CA-125 is > 65 U/ml
| Size of population: | Post: 64 (52.9%) | Detected by imaging (n [%]): | Tot | 12 | 45 | 57 | —D-Dimer - cutoff had been previously evaluated in other study (using most of the same patients) by same authors [Reference 22]
| 124 women (3 excluded = 121) | Race/ethnicity (n [%]): | NR | | | Lower | Upper | —D-dimer performance characteristic likely overestimated since these data are not independent of the data used to select cutoff value.
| Other | NR | Combination (n [%]): | | Value | 95% CI | 95% CI | Quality assessment:
| Consecutive patients referred for surgery with diagnosis of ovarian mass | Risk factors (n [%]): | NR | Se | 66.7% | 40.0% | 93.4% | Reference standard: +
| Reference standard: | NR | Additional data used for diagnosis: | Sp | 91.1% | 82.8% | 99.4% | Verification bias: +
| Histopathology | Inclusion criteria: | NR | PPV | 66.7% | 40.0% | 93.3% | Test reliability/variability: +
| Reference standard applied to all test negatives?: | Consecutive women with clinical diagnosis of ovarian mass to undergo surgery | | NPV | 91.1% | 82.8% | 99.4% | Sample size: - not discussed
| Yes | Exclusion criteria: | | 2) D-Dimer - premenopause | | | | Statistical tests: +
| Test reliability established?: | Cardiovascular disease, diabetes, acute or chronic inflammatory disease, previous malignancy, or previous episodes of thrombophlebitis or thromboembolia. | | | Dis+ | Dis- | Tot | Blinding: -
| Yes | 2 patients excluded for uterine fibroid (after surgery) | | T+ | 12 | 4 | 16 | Definition of +/- on screening test: +
| Statistical tests used: | 1 excluded for leiomyosarcoma, of small bowel | | T- | 0 | 41 | 41
| Mann-Whitney U test | | | Tot | 12 | 45 | 57
| Spearman rank correlation test | | | | | Lower | Upper
| Logistic regression | | | | Value | 95% CI | 95% CI
| ROC curves | | | Se | 100.0% | 75.0% | 100.0%
| Blinding: | | | Sp | 91.1% | 82.8% | 99.4%
| No - but consecutive enrollment | | | PPV | 75.0% | 53.8% | 96.2%
| Definition of positive and negative on screening test: | | | NPV | 100.0% | 92.7% | 100.0%
| CA-125 > 65 U/ml | | | 3) D-Dimer - combined ages
| D-Dimer > 416 ng/ml | | | | Dis+ | Dis- | Tot
| | | | T+ | 51 | 11 | 62
| | | | T- | 5 | 54 | 59
| | | | Tot | 56 | 65 | 121
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 91.1% | 83.6% | 98.5%
| | | | Sp | 83.1% | 74.0% | 92.2%
| | | | PPV | 82.3% | 72.7% | 91.8%
| | | | NPV | 91.5% | 84.4% | 98.6%
| | | | 4) CA-125 > 65 U/ml - postmenopause
| | | | | Dis+ | Dis- | Tot
| | | | T+ | 35 | 0 | 35
| | | | T- | 9 | 20 | 29
| | | | Tot | 44 | 20 | 64
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 79.5% | 67.6% | 91.4%
| | | | Sp | 100.0% | 85.0% | 100.0%
| | | | PPV | 100.0% | 91.4% | 100.0%
| | | | NPV | 69.0% | 52.1% | 85.8%
| | | | 5) CA-125 > 65 U/ml - all ages
| | | | | Dis+ | Dis- | Tot
| | | | T+ | 43 | 4 | 47
| | | | T- | 13 | 61 | 74
| | | | Tot | 56 | 65 | 121
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 76.8% | 65.7% | 87.8%
| | | | Sp | 93.8% | 88.0% | 99.7%
| | | | PPV | 91.5% | 83.5% | 99.5%
| | | | NPV | 82.4% | 73.8% | 91.1%
| | | | 6) D-Dimer -postmenopause
| | | | | Dis+ | Dis- | Tot
| | | | T+ | 39 | 7 | 46
| | | | T- | 5 | 13 | 18
| | | | Tot | 44 | 20 | 64
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 88.6% | 79.2% | 98.0%
| | | | Sp | 65.0% | 44.1% | 85.9%
| | | | PPV | 84.8% | 74.4% | 95.2%
| | | | NPV | 72.2% | 51.5% | 92.9%
Gadducci, Capriello, Bartolini, et al., 1988 | Geographical location: | Age: | Symptomatic (n [%]): | 1) CA-125 ≥ 35 U/ml | | | | Comments:
#6650 | Pisa Italy | NR | NR | | Dis+ | Dis- | Tot | —US scoring system described but not grounded - appears to be a unique (hospital specific? operator specific?) scoring system - also unclear how cutoff of ≥ 10 was fixed
| University Hospital | Menopausal status (n [%]): | Detected by exam (n [%]): | T+ | 31 | 20 | 51 | —CA-125 cutoff ≥ 65 U/ml preferred by authors, but 2×2 table reported only for ≥ 35 U/ml as that is what is in common clinical practice.
| Dates: NR | NR | NR | T- | 5 | 63 | 68 | —Patient data overlaps with article Gadducci et al., 1996 (#6230)
| Size of population: | Race/ethnicity (n [%]): | Detected by imaging (n [%]): | Tot | 36 | 83 | 119 | —Referral criteria etc. not described
| 119 women | NR | NR | | | Lower | Upper | Quality assessment:
| Other | Risk factors (n [%]): | Combination (n [%]): | | Value | 95% CI | 95% CI | Reference standard: +
| Patients undergoing surgery for mass | NR | NR | Se | 86.1% | 74.8% | 97.4% | Verification bias: +
| Reference standard: | Inclusion criteria: | Additional data used for diagnosis: | Sp | 75.9% | 66.7% | 85.1% | Test reliability/variability: - especially given the novel US scoring system
| Histopathology | Patients undergoing surgery for mass | NR | PPV | 60.8% | 47.4% | 74.2% | Sample size: -
| Reference standard applied to all test negatives?: | Exclusion criteria: | | NPV | 92.6% | 86.4% | 98.9% | Statistical tests: +
| Yes | NR | | 2) US | | | | Blinding: ?
| Test reliability established?: | | | | Dis+ | Dis- | Tot | Definition of +/- on screening test: +
| For CA-125 - yes | | | T+ | 26 | 2 | 28
| For US - no | | | T- | 10 | 81 | 91
| Statistical tests used: | | | Tot | 36 | 83 | 119
| Sensitivity, specificity | | | | | Lower | Upper
| Blinding: | | | | Value | 95% CI | 95% CI
| No - probably prospective | | | Se | 72.2% | 57.6% | 86.8%
| Definition of positive and negative on screening test: | | | Sp | 97.9% | 94.8% | 100.0%
| US scoring system ≥ 10 (of 16 with 4 points for shape, ascites, outline, and structure) | | | PPV | 92.9% | 83.3% | 100.0%
| | | | NPV | 89.0% | 82.6% | 95.4%
Gadducci, Ferdeghini, Prontera, et al., 1992 | Geographical location: | Age: | Symptomatic (n [%]): | 1) CA-125 ≥ 65 U/ml (Age < 50 years) | | | | Comments:
#6850 | Italy | NR | NR | | Dis+ | Dis- | Tot | —Data stratified by age/menopausal status for CA-125 using lower cutpoint not presented.
| Dates: NR | Menopausal status (n [%]): | Detected by exam (n [%]): | T+ | 8 | 146 | 154 | —Appears that borderline tumors grouped with malignant
| Size of population: | NR | NR | T- | 8 | 51 | 59 | —Unclear how patients chosen; no definition of menopause
| 344 | Race/ethnicity (n [%]): | Detected by imaging (n [%]): | Tot | 16 | 197 | 213 | Quality assessment:
| Other | Italian | NR | | | Lower | Upper | Reference standard: +
| Consecutive case series | Risk factors (n [%]): | Combination (n [%]): | | Value | 95% CI | 95% CI | Verification bias: +
| Reference standard: | NR | NR | Se | 50.0% | 25.5% | 74.5% | Test reliability/variability: -
| Pathology | Inclusion criteria: | Additional data used for diagnosis: | Sp | 26.0% | 19.9% | 32.1% | Sample size: +
| Reference standard applied to all test negatives?: | Patients undergoing laparotomyfor ovarian masses | NR | PPV | 5.2% | 1.7% | 8.7% | Statistical tests: +
| Yes | Exclusion criteria: | | NPV | 86.4% | 77.7% | 95.2% | Blinding: -
| Test reliability established?: | NR | | 2) CA-125 ≥ 65U/ml (Age ≥ 50) | | | | Definition of +/- on screening test: +
| Yes for CA-125 | | | | Dis+ | Dis- | Tot
| Statistical tests used: | | | T+ | 60 | 8 | 68
| Chi-square | | | T- | 14 | 49 | 63
| Blinding: | | | Tot | 74 | 57 | 131
| NR | | | | | Lower | Upper
| Definition of positive and negative on screening test: | | | | Value | 95% CI | 95% CI
| CA-125 35 and 65 U/ml | | | Se | 81.1% | 72.2% | 90.0%
| | | | Sp | 86.0% | 77.0% | 95.0%
| | | | PPV | 88.2% | 80.6% | 95.9%
| | | | NPV | 77.8% | 67.5% | 88.0%
| | | | 3) CA-125 ≥ 35 (for all ages)
| | | | | Dis+ | Dis- | Tot
| | | | T+ | 74 | 83 | 157
| | | | T- | 16 | 171 | 187
| | | | Tot | 90 | 254 | 344
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 82.3% | 74.4% | 90.2%
| | | | Sp | 67.3% | 61.5% | 73.1%
| | | | PPV | 47.1% | 39.3% | 54.9%
| | | | NPV | 91.4% | 87.4% | 95.5%
| | | | 4) CA-125 ≥ 65 (for all ages)
| | | | | Dis+ | Dis- | Tot
| | | | T+ | 68 | 154 | 222
| | | | T- | 22 | 100 | 122
| | | | Tot | 90 | 254 | 344
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 75.6% | 66.7% | 84.4%
| | | | Sp | 39.4% | 33.4% | 45.4%
| | | | PPV | 30.6% | 24.6% | 36.7%
| | | | NPV | 82.0% | 75.1% | 88.8%
Gadducci, Ferdeghini, Rispoli, et al., 1991 | Geographical location: | Age: | Symptomatic (n [%]): | 1) CA-125 > 35 U/ml | | | | Comments:
#6490 | Pisa, Italy | NR | NR | | Dis+ | Dis- | Tot | —No description on inclusion etc.
| University Hospital | Menopausal status (n [%]): | Detected by exam (n [%]): | T+ | 49 | 66 | 115 | —Hospital based study
| Dates: NR | NR | NR | T- | 8 | 97 | 105 | —Although info in article on TATI, this was excluded from 2×2 table because it's not common test
| Size of population: | Race/ethnicity (n [%]): | Detected by imaging (n [%]): | Tot | 57 | 163 | 220 | Quality assessment:
| 220 women | NR | NR | | | Lower | Upper | Reference standard: +
| Other | Risk factors (n [%]): | Combination (n [%]): | | Value | 95% CI | 95% CI | Verification bias: +
| Preop patients at university hospital | NR | NR | Se | 86.0% | 77.0% | 95.0% | Test reliability/variability: +
| Reference standard: | Inclusion criteria: | Additional data used for diagnosis: | Sp | 59.5% | 52.0% | 67.0% | Sample size: - not discussed
| Histopathology | NR aside from undergoing gynecological surgery (presumably for mass) | None | PPV | 42.6% | 33.6% | 51.6% | Statistical tests: +
| Reference standard applied to all test negatives?: | Exclusion criteria: | | NPV | 92.4% | 87.3% | 97.5% | Blinding: +/- not discussed but prospective?
| Yes | NR | | | | | | Definition of +/- on screening test: +
| Test reliability established?:
| Yes
| Statistical tests used:
| Se, Sp
| Blinding:
| NR but serum drawn prior to surgery
| Definition of positive and negative on screening test:
| CA-125 > 35 (or 65) U/ml
Grab, Flock, Stohr, et al., 2000 | Geographical location: | Age: | Symptomatic (n [%]): | 1) Ultrasound - combination morphology and Doppler | | | | Comments:
#2720 | Germany | Median: 45 | NR - but assume 0% since excluded | | Dis+ | Dis- | Tot | —No description of who refused surgery
| Dates: NR | Range: 18–82 | Detected by exam (n [%]): | T+ | 11 | 36 | 47 | —Unclear how patients came to have diagnosis of mass
| Size of population: | Menopausal status (n [%]): | NR | T- | 1 | 53 | 54 | —Descriptive analysis of MRI and CT; no scoring system used
| 101 | NR | Detected by imaging (n [%]): | Tot | 12 | 89 | 101 | —RI cut point (0.45) not described why chosen
| Other | Race/ethnicity (n [%]): | NR | | | Lower | Upper | —No discussion of inter/intra observer variability
| Case series | NR | Combination (n [%]): | | Value | 95% CI | 95% CI | —Unclear if combination morphology and Doppler used in series or parallel
| Reference standard: | Risk factors (n [%]): | NR | Se | 92.0% | 76.7% | 100.0% | —One of few studies to explicitly state presence or absence of symptoms
| Yes | NR | Additional data used for diagnosis: | Sp | 60.0% | 49.8% | 70.2% | Quality assessment:
| Reference standard applied to all test negatives?: | Inclusion criteria: | NR | PPV | 23.4% | 11.3% | 35.5% | Reference standard:
| Yes | Asymptomatic adnexal mass | | NPV | 98.1% | 94.6% | 100.0% | Verification bias: +
| Test reliability established?: | Prospective consecutive patients scheduled for laproscopy offered entry | | 2) MRI | | | | Test reliability/variability: +
| NR | Exclusion criteria: | | | Dis+ | Dis- | Tot | Sample size: +
| Statistical tests used: | Pregnant women, age < 18 and patients with clinical symptoms of malignancy | | T+ | 10 | 14 | 24 | Statistical tests: -
| None | | | T- | 2 | 75 | 77 | Blinding: +
| Blinding: | | | Tot | 12 | 89 | 101 | Definition of +/- on screening test:
| Yes | | | | | Lower | Upper | +, but how all 3 modalities used not described
| Definition of positive and negative on screening test: | | | | Value | 95% CI | 95% CI
| Sonography: | | | Se | 83.0% | 61.7% | 100.0%
| Adnexal masses with suspicious patterns according to Sawai's classification, DePriest score ≥ 5 or RI < 0.45 assumed to be malignant | | | Sp | 84.0% | 76.4% | 91.6%
| MRI | | | PPV | 41.7% | 21.9% | 61.4%
| Lesions considered benign if one or more of the following were met: cystic structures without any solid areas, diameter 4 cm or less wall thickness < 3 mm and presence of typical characteristics of dermoid cyst or endometrioma. If one of these not fulfilled then considered malignant. | | | NPV | 97.4% | 93.8% | 100.0%
| PET | | | 3) PET
| If uptake of F-FDG equaled or exceeded that of the liver and they were not localized within structures with physiologic uptake. | | | | Dis+ | Dis- | Tot
| COMBINATION | | | T+ | 7 | 18 | 25
| All 3 used in conference, but criteria not described | | | T- | 5 | 71 | 76
| | | | Tot | 12 | 89 | 101
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 58.0% | 30.1% | 85.9%
| | | | Sp | 80.0% | 71.7% | 88.3%
| | | | PPV | 28.0% | 10.4% | 45.6%
| | | | NPV | 93.4% | 87.8% | 99.0%
| | | | 4) All 3 (definition of positive/negative not given)
| | | | | Dis+ | Dis- | Tot
| | | | T+ | 11 | 13 | 24
| | | | T- | 1 | 76 | 77
| | | | Tot | 12 | 89 | 101
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 92.0% | 76.7% | 100.0%
| | | | Sp | 85.0% | 77.6% | 92.4%
| | | | PPV | 45.8% | 25.9% | 65.8%
| | | | NPV | 98.7% | 96.2% | 100.0%
Granberg, Norstrom, and Wikland, 1990 | Geographical location: | Age: | Symptomatic (n [%]): | 1) Vaginal ultrasound (data not presented by menopausal status) | | | | Comments:
#5320 | Sweden | Range: < 20 to > 70 | 71% had symptoms | | Dis+ | Dis- | Tot | —No US scoring system used - descriptive only
| Dates: 1987-1988 | Menopausal status (n [%]): | Detected by exam (n [%]): | T+ | 32 | 11 | 43 | —Unclear how patients selected (if consecutive)
| Size of population: | Pre (< 45): 86 (48%) | 100% found at a gyn exam performed 1 week to 1 month prior to surgery, but unclear whether symptoms present | T- | 7 | 130 | 137 | Quality assessment:
| 180 | Post (> 55): 94 (52%) | Detected by imaging (n [%]): | Tot | 39 | 141 | 180 | Reference standard: +
| Other | Race/ethnicity (n [%]): | NR | | | Lower | Upper | Verification bias: +
| Prospective series | Swedish | Combination (n [%]): | | Value | 95% CI | 95% CI | Test reliability/variability: -
| Reference standard: | Risk factors (n [%]): | NR | Se | 82.1% | 70.0% | 94.1% | Sample size: +
| Pathology | NR | Additional data used for diagnosis: | Sp | 92.2% | 87.8% | 96.6% | Statistical tests: -
| Reference standard applied to all test negatives?: | Inclusion criteria: | NR | PPV | 74.4% | 61.4% | 87.5% | Blinding: -
| Yes | Women scheduled for elective surgery due to adnexal masses | | NPV | 94.9% | 91.2% | 98.6% | Definition of +/- on screening test: -
| Test reliability established?: | Exclusion criteria:
| Used the same MD for all exams | NR
| Statistical tests used:
| None
| Blinding:
| NR
| Definition of positive and negative on screening test:
| “Classified as malignant the more complex it looked on ultrasound”
Granberg, Norstrom, and Wikland, 1991 | Geographical location: | Age: | Symptomatic (n [%]): | 1) US - all patients | | | | Comments:
#10920 | Sweden | Mean: 53.8 | NR | | Dis+ | Dis- | Tot | —No scoring system used for US morphology - descriptive and not reproducible
| Dates: May 1988 - Dec 1988 | Range: 21–92 | Detected by exam (n [%]): | T+ | 16 | 6 | 22 | —Clinical pathway not described in patients
| Size of population: | Menopausal status (n [%]): | NR | T- | 0 | 28 | 28 | —TVUS only
| 50 | NR | Detected by imaging (n [%]): | Tot | 16 | 34 | 50 | Quality assessment:
| Case series | Race/ethnicity (n [%]): | NR | | | Lower | Upper | Reference standard: +
| Reference standard: | NR | Combination (n [%]): | | Value | 95% CI | 95% CI | Verification bias: +
| Histopathology | Risk factors (n [%]): | NR | Se | 100.0% | 81.3% | 100.0% | Test reliability/variability: -
| Reference standard applied to all test negatives?: | NR | Additional data used for diagnosis: | Sp | 82.0% | 69.1% | 94.9% | Sample size: -
| Yes | Inclusion criteria: | NR | PPV | 72.7% | 54.1% | 91.3% | Statistical tests: +
| Test reliability established?: | Surgical series | | NPV | 100.0% | 89.3% | 100.0% | Blinding: -
| Not really | Exclusion criteria: | | | | | | Definition of +/- on screening test: +
| Statistical tests used: | NR
| Student's T test
| Linear regression
| Se, Sp
| Blinding:
| NR
| Definition of positive and negative on screening test:
| US - at least one of the following criteria fulfilled:
| 1) tumor > 10 cm in diameter (excluding simple completely unilocular cysts), 2) unilocular with echogenic areas inside the cyst, 3) multilocular with more than one thick (> 1 mm) septation and internal echoes, 4) multilocular-solid.
Guerriero, Ajossa, Garau, et al., 2005 | Geographical location: | Age: | Symptomatic (n [%]): | 1) US morphology | | | | Comments:
#7470 | Cagliari, Italy | Mean (SD): 39 (15) | NR | | Dis+ | Dis- | Tot | —Definition of positive morphology scan or Doppler very unclear (used some subjective description) - no score or calculation used
| Dates: NR | Range: 14–79 | Detected by exam (n [%]): | T+ | 95 | 64 | 159 | —Kappa statistic calculated
| Size of population: | Menopausal status (n [%]): | NR | T- | 0 | 294 | 294 | —TVUS only
| 424 women | Pre (< 45): 323 (76%) | Detected by imaging (n [%]): | Tot | 95 | 358 | 453 | Quality assessment:
| 453 masses | Post (> 55): 101 (24%) | NR | | | Lower | Upper | Reference standard: +
| Case series | Race/ethnicity (n [%]): | Combination (n [%]): | | Value | 95% CI | 95% CI | Verification bias: +
| Reference standard: | NR | NR | Se | 100.0% | 96.8% | 100.0% | Test reliability/variability: +
| Histopathology | Risk factors (n [%]): | Additional data used for diagnosis: | Sp | 82.0% | 78.0% | 86.0% | Sample size: -
| Reference standard applied to all test negatives?: | NR | NR | PPV | 59.7% | 52.1% | 67.4% | Statistical tests: +
| Yes | Inclusion criteria: | | NPV | 100.0% | 99.0% | 100.0% | Blinding: -
| Test reliability established?: | NR | | 2) Doppler | | | | Definition of +/- on screening test: -
| Not really | Exclusion criteria: | | | Dis+ | Dis- | Tot
| Statistical tests used: | NR | | T+ | 95 | 32 | 127
| Se, Sp | | | T- | 0 | 326 | 326
| Kappa statistic, | | | Tot | 95 | 358 | 453
| Blinding: | | | | | Lower | Upper
| NR | | | | Value | 95% CI | 95% CI
| Definition of positive and negative on screening test: | | | Se | 100.0% | 96.8% | 100.0%
| US morphology: benign was anything that resembled an endometrioma, or a cystic teratoma, or with appearance of non-malignant(not defined) | | | Sp | 91.0% | 88.0% | 94.0%
| Doppler - not clearly stated but appears to be simple presence or absence of flow visualized in “echogenic structure” | | | PPV | 74.8% | 67.3% | 82.4%
| | | | NPV | 100.0% | 99.1% | 100.0%
Guerriero, Ajossa, Risalvato, et al., 1998 | Geographical location: | Age: | Symptomatic (n [%]): | Estimates are for masses not women
#3400 | Italy | Mean (SD): 41 (15) | NR | 1) Post menopause PI ≤ 1 | | | | Comments:
| Dates: Jan 1996-May 1997 | Range: 14–77 | Detected by exam (n [%]): | | Dis+ | Dis- | Tot | —2×2 analysis of masses not women
| Size of population: | Menopausal status (n [%]): | NR | T+ | 23 | 12 | 35 | US - descriptive no scoring system used
| 240 | Pre (< 45): 127 (71%) | Detected by imaging (n [%]): | T- | 3 | 13 | 16 | —Unclear why different PI cut points used
| 178 women with 192 masses | Post (> 55): 51 (29%) | NR | Tot | 26 | 25 | 51 | —No explanation for why RI cut point chosen
| Other | Race/ethnicity (n [%]): | Combination (n [%]): | | | Lower | Upper | —Good use of kappa
| Prospective series | NR | NR | | Value | 95% CI | 95% CI | Quality assessment:
| Reference standard: | Risk factors (n [%]): | Additional data used for diagnosis: | Se | 88.0% | 75.5% | 100.0% | Reference standard: +
| Pathology | NR | NR | Sp | 52.0% | 32.4% | 71.6% | Verification bias: +
| Reference standard applied to all test negatives?: | Inclusion criteria: | | PPV | 65.7% | 50.0% | 81.4% | Test reliability/variability: +/-
| Yes | Women under observation for presence of adnexal mass | | NPV | 81.3% | 62.1% | 100.0% | Sample size: -
| Test reliability established?: | Exclusion criteria: | | 2) Total for PI ≤ 1 | | | | Statistical tests: +
| Yes | Pregnant | | | Dis+ | Dis- | Tot | Blinding: +/
| Statistical tests used: | | | T+ | 29 | 84 | 113 | Definition of +/- on screening test: +
| Kappa for reliability | | | T- | 4 | 75 | 79
| Blinding: | | | Tot | 33 | 159 | 192
| NR | | | | | Lower | Upper
| Definition of positive and negative on screening test: | | | | Value | 95% CI | 95% CI
| B-mode: Malignant when echogenic structure situated adjacent to wall of cyst is present, when a large > 3 mm irregular homogeneous or heterogeneous echogenic structure present or when an irregular thickened > 3 mm wall or septum present. | | | Se | 88.0% | 76.9% | 99.1%
| Color Doppler imaging | | | Sp | 47.0% | 39.2% | 54.8%
| RI < 0.4, PI ≤ 1 or a PI ≤ 0.8 | | | PPV | 25.7% | 17.6% | 33.7%
| CA-125: 35 and 65U/ml | | | NPV | 94.9% | 90.1% | 99.8%
Guerriero, Alcazar, Coccia, et al., 2002 | Geographical location: | Age: | Symptomatic (n [%]): | 1) Transvaginal sonography: Premenopausal | | | | Comments:
#2130 | Italy | Mean (SD): 40 (14) | NR | | Dis+ | Dis- | Tot | —CA-125 used but data not presented separately
| Dates: Apr 1997 to Jul 2000 | Range: 14–81 | Detected by exam (n [%]): | T+ | 48 | 62 | 110 | —Estimates are for masses, not individuals - difficult to determine denominator being used
| Size of population: | Menopausal status (n [%]): | NR | T- | 1 | 506 | 507 | Quality assessment:
| 789 women with 826 masses | Pre (< 45): 617 (78%) | Detected by imaging (n [%]): | Tot | 49 | 568 | 617 | Reference standard: +
| Other | Post (> 55): 172 (22%) | NR | | | Lower | Upper | Verification bias: +
| Case series | Race/ethnicity (n [%]): | Combination (n [%]): | | Value | 95% CI | 95% CI | Test reliability/variability: +
| Reference standard: | NR | NR | Se | 98.0% | 94.1% | 100.0% | Sample size: +
| Pathology | Risk factors (n [%]): | Additional data used for diagnosis: | Sp | 89.0% | 86.4% | 91.6% | Statistical tests: +
| Reference standard applied to all test negatives?: | NR | NR | PPV | 43.6% | 34.4% | 52.9% | Blinding: -
| Yes | Inclusion criteria: | | NPV | 99.8% | 99.4% | 100.0% | Definition of +/- on screening test: -; not detailed enough to reproduce
| Test reliability established?: | All women scheduled for surgery in the presence of a persistent adnexal mass | | 2) Transvaginal sonography: Postmenopausal
| Yes | Exclusion criteria: | | | Dis+ | Dis- | Tot
| Statistical tests used: | Women with an anechoic unilocular or bilocular cystic mass with a thin regular wall without endocystic vegetation | | T+ | 91 | 84 | 175
| Z statistic | | | T- | 0 | 88 | 88
| K statistic for agreement | | | Tot | 91 | 172 | 263
| Blinding: | | | | | Lower | Upper
| NR | | | | Value | 95% CI | 95% CI
| Definition of positive and negative on screening test: | | | Se | 100.0% | 96.7% | 100.0%
| TV sonography: | | | Sp | 51.0% | 43.5% | 58.5%
| multiloculated, complex or solid mass in which the echo architecture was not highly indicative of a benign histologic type was categorized as malignant. | | | PPV | 52.0% | 44.6% | 59.4%
| Color Doppler: | | | NPV | 100.0% | 96.6% | 100.0%
| malignancy was assumed if arterial flow was visualized in an echogenic structure or in an irregular solid portion defined as malignant on B-mode imaging. | | | 3) Color Doppler - Premenopausal
| | | | | Dis+ | Dis- | Tot
| | | | T+ | 46 | 23 | 69
| | | | T- | 3 | 545 | 548
| | | | Tot | 49 | 568 | 617
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 94.0% | 87.4% | 100.0%
| | | | Sp | 96.0% | 94.4% | 97.6%
| | | | PPV | 66.7% | 55.5% | 77.8%
| | | | NPV | 99.5% | 98.8% | 100.0%
| | | | 4) Color Doppler: Postmenopausal
| | | | | Dis+ | Dis- | Tot
| | | | T+ | 87 | 40 | 127
| | | | T- | 4 | 132 | 136
| | | | Tot | 91 | 172 | 263
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 96.0% | 92.0% | 100.0%
| | | | Sp | 77.0% | 70.7% | 83.3%
| | | | PPV | 68.5% | 60.4% | 76.6%
| | | | NPV | 97.1% | 94.2% | 99.9%
| | | | 5) Color Doppler: combined ages
| | | | | Dis+ | Dis- | Tot
| | | | T+ | 133 | 63 | 196
| | | | T- | 7 | 677 | 684
| | | | Tot | 140 | 740 | 880
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 95.0% | 91.4% | 98.6%
| | | | Sp | 91.5% | 89.5% | 93.5%
| | | | PPV | 67.9% | 61.3% | 74.4%
| | | | NPV | 99.0% | 98.2% | 99.7%
| | | | 6) US morphology - combined ages
| | | | | Dis+ | Dis- | Tot
| | | | T+ | 139 | 146 | 285
| | | | T- | 1 | 594 | 595
| | | | Tot | 140 | 740 | 880
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 99.3% | 97.9% | 100.0%
| | | | Sp | 80.3% | 77.4% | 83.1%
| | | | PPV | 48.8% | 43.0% | 54.6%
| | | | NPV | 99.8% | 99.5% | 100.0%
Hata, Hata, and Kitao, 1995 | Geographical location: | Age: | Symptomatic (n [%]): | 1) Peak systolic velocity > 16 cm/sec | | | | Comments:
#10960 | Japan | Mean: 46.1 | NR | | Dis+ | Dis- | Tot | —US morphology descriptive - no scoring system used,
| Dates: NR | Range: 20–78 | Detected by exam (n [%]): | T+ | 25 | 6 | 31 | —Unclear why RI of 0.72 was used or PSV of 16cm/sec
| Size of population: | Menopausal status (n [%]): | NR | T- | 5 | 66 | 71 | —LMP tumors grouped in with malignant
| 102 | NR | Detected by imaging (n [%]): | Tot | 30 | 72 | 102 | —TVUS only
| Case series | Race/ethnicity (n [%]): | NR | | | Lower | Upper | Quality assessment:
| Reference standard: | Japanese | Combination (n [%]): | | Value | 95% CI | 95% CI | Reference standard: +
| Histopathology | Risk factors (n [%]): | NR | Se | 83.3% | 70.0% | 96.6% | Verification bias: +
| Reference standard applied to all test negatives?: | NR | Additional data used for diagnosis: | Sp | 91.7% | 85.3% | 98.1% | Test reliability/variability: -
| Yes | Inclusion criteria: | NR | PPV | 80.6% | 66.7% | 94.6% | Sample size: -
| Test reliability established?: | Referred to hospital with mass who had US prior to surgical evaluation | | NPV | 93.0% | 87.0% | 98.9% | Statistical tests: +
| Not really | Exclusion criteria: | | 2) RI <0.72 | | | | Blinding: -
| Statistical tests used: | NR | | | Dis+ | Dis- | Tot | Definition of +/- on screening test: +
| Se, Sp, | | | T+ | 28 | 23 | 51
| Kappa statistic | | | T- | 2 | 49 | 51
| Chi square | | | Tot | 30 | 72 | 102
| Blinding: | | | | | Lower | Upper
| NR | | | | Value | 95% CI | 95% CI
| Definition of positive and negative on screening test: | | | Se | 93.3% | 84.4% | 100.0%
| US morphology: “features that suggested the possibility of malignancy” such as dense irregular septa, multilocular cysts, papillary formation, poorly defined borders, solid focus, echogenic core | | | Sp | 68.1% | 57.3% | 78.9%
| R< 0.72 | | | PPV | 54.9% | 41.2% | 68.6%
| PSV > 16 cm/sec | | | NPV | 96.1% | 90.8% | 100.0%
| | | | 3) US morphology
| | | | | Dis+ | Dis- | Tot
| | | | T+ | 26 | 22 | 48
| | | | T- | 4 | 50 | 54
| | | | Tot | 30 | 72 | 102
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 86.7% | 74.5% | 98.9%
| | | | Sp | 69.4% | 58.8% | 80.0%
| | | | PPV | 54.2% | 40.1% | 68.3%
| | | | NPV | 92.6% | 85.6% | 99.6%
Hata, Hata, Manabe, et al., 1992 | Geographical location: | Age: | Symptomatic (n [%]): | 1) RI < 0.72 | | | | Comments:
#5010 | Japan | Mean: 47.4 | NR | | Dis+ | Dis- | Tot | —Unclear how patients selected
| Dates: NR | Range: 20–78 | Detected by exam (n [%]): | T+ | 25 | 17 | 42 | —Borderline tumors grouped in with malignant
| Size of population: | Menopausal status (n [%]): | NR | T- | 2 | 19 | 21 | —No US scoring system used (and means of diagnosis not well described)
| 63 | Pre (< 45): 35 (56%) | Detected by imaging (n [%]): | Tot | 27 | 36 | 63 | —MRI almost scoring system
| Other | Post (> 55): 28 (44%) | NR | | | Lower | Upper | —RI cut point determined from analysis of this data
| Prospective series | Race/ethnicity (n [%]): Japanese | Combination (n [%]): | | Value | 95% CI | 95% CI | —Unable to stratify by age
| Reference standard: | Risk factors (n [%]): | NR | Se | 92.6% | 82.7% | 100.0% | Quality assessment:
| Histopathology | NR | Additional data used for diagnosis: | Sp | 52.8% | 36.5% | 69.1% | Reference standard: +
| Reference standard applied to all test negatives?: | Inclusion criteria: | NR | PPV | 59.5% | 44.7% | 74.4% | Verification bias: +
| Yes | Suspected pelvic tumors | | NPV | 90.5% | 77.9% | 100.0% | Test reliability/variability: -
| Test reliability established?: | Exclusion criteria: | | 2) US | | | | Sample size: -
| CA-125 - yes | NR | | | Dis+ | Dis- | Tot | Statistical tests: +
| RI - no | | | T+ | 23 | 11 | 34 | Blinding: -
| Statistical tests used: | | | T- | 4 | 25 | 29 | Definition of +/- on screening test: +/-
| ROC curves | | | Tot | 27 | 36 | 63
| T tests, Chi-square | | | | | Lower | Upper
| Blinding: | | | | Value | 95% CI | 95% CI
| NR | | | Se | 85.2% | 71.8% | 98.6%
| Definition of positive and negative on screening test: | | | Sp | 69.4% | 54.3% | 84.5%
| CA-125 > 35 U/ml | | | PPV | 67.6% | 51.9% | 83.4%
| RI - calculated from own analysis of data < 0.72 | | | NPV | 86.2% | 73.7% | 98.8%
| US - not described | | | 3) MRI
| MRI - malignant = size > 4 cm and (any of the following): 1) cystic, wall > 3 mm +/- nodularity | | | | Dis+ | Dis- | Tot
| 2) predom solid lesion | | | T+ | 18 | 1 | 19
| 3) involvement of other organs or sidewalls or omental dz or ascites or adenopathy | | | T- | 9 | 35 | 44
| | | | Tot | 27 | 36 | 63
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 66.7% | 48.9% | 84.5%
| | | | Sp | 97.1% | 91.6% | 100.0%
| | | | PPV | 94.7% | 84.7% | 100.0%
| | | | NPV | 79.5% | 67.6% | 91.5%
| | | | 4) CA-125 > 35
| | | | | Dis+ | Dis- | Tot
| | | | T+ | 16 | 3 | 19
| | | | T- | 11 | 33 | 44
| | | | Tot | 27 | 36 | 63
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 59.3% | 40.8% | 77.8%
| | | | Sp | 91.7% | 82.7% | 100.0%
| | | | PPV | 84.2% | 67.8% | 100.0%
| | | | NPV | 75.0% | 62.2% | 87.8%
Herrmann Jr., Locher, and Goldhirsch, 1987 | Geographical location: | Age: | Symptomatic (n [%]): | 1) US (borderline tumors excluded) | | | | Comments:
#6840 | Germany | NR | NR | | Dis+ | Dis- | Tot | —Excluded 92 patients who did not get operated on within 3 weeks of sonography - delay may be related to test result
| Dates: 1981-1985 | Menopausal status (n [%]): | Detected by exam (n [%]): | T+ | 38 | 8 | 46 | —Borderline tumors were excluded from authors calculations, but reported separately
| Size of population: | NR | NR | T- | 14 | 177 | 191 | —Data reported separately for pelvic versus adnexal masses, except for benign tumors, which were reported together (Table 1). This may raise numbers in Dis- column of 2×2 table with corresponding error for PPV and NPV.
| 312/404 | Race/ethnicity (n [%]): | Detected by imaging (n [%]): | Tot | 52 | 185 | 237 | —Data presented on page 779 re: prevalence of disease by age, but need additional information to fill in 2×2.
| Screening study | NR | NR | | | Lower | Upper | —Very unclear how patients selected
| Retrospective series | Risk factors (n [%]): | Combination (n [%]): | | Value | 95% CI | 95% CI | US scoring system from Fleischer et al (not well used criteria) - and not described in text
| Reference standard: | NR | NR | Se | 73.1% | 61.0% | 85.1% | Quality assessment:
| Pathology | Inclusion criteria: | Additional data used for diagnosis: | Sp | 95.7% | 92.7% | 98.6% | Reference standard: -
| Reference standard applied to all test negatives?: | NR | NR | PPV | 82.6% | 71.7% | 93.6% | Verification bias: -
| Yes | Exclusion criteria: | | NPV | 92.7% | 89.0% | 96.4% | Test reliability/variability: -
| Test reliability established?: | Very young age | | 2) US (borderline tumors considered benign) | | | | Sample size: +
| No | Pregnancy | | | Dis+ | Dis- | Tot | Statistical tests: +
| Statistical tests used: | Endocrinologic disorder | | T+ | 38 | 11 | 49 | Blinding: -
| Chi-square | Recurrent tumors | | T- | 14 | 178 | 192 | Definition of +/- on screening test: +
| Blinding: | No pathology diagnosis | | Tot | 52 | 189 | 241
| NR | | | | | Lower | Upper
| Definition of positive and negative on screening test: | | | | Value | 95% CI | 95% CI
| Ultrasound: | | | Se | 73.1% | 61.0% | 85.1%
| Thick septae, irregular solid parts within a mass, indefinite margins, and the presence of ascites and matted bowel loops regarded as malignant. | | | Sp | 94.2% | 90.8% | 97.5%
| | | | PPV | 77.6% | 65.9% | 89.2%
| | | | NPV | 92.7% | 89.0% | 96.4%
Hillaby, Aslam, Salim, et al., 2004 | Geographical location: | Age: | Symptomatic (n [%]): | 1) US - ovarian crescent sign (T+ = negative) | | | | Quality assessment:
#1620 | London, UK | Mean: 43 | NR | | Dis+ | Dis- | Tot | Reference standard: +
| Dates: Apr 2000 - Jun 2003 | Range: 15–81 | Detected by exam (n [%]): | T+ | 23 | 18 | 41 | Verification bias: +
| Size of population: | Menopausal status (n [%]): | NR | T- | 1 | 58 | 59 | Test reliability/variability: ±, crescent sign evaluated for reliability, but only in 15 cases and 2 observers.
| 119 women | Pre: 70 (70%) | Detected by imaging (n [%]): | Tot | 24 | 76 | 100 | Sample size: -
| Case series | Post: 30 (30%) | NR | | | Lower | Upper | Statistical tests: +
| Reference standard: | Race/ethnicity (n [%]): | Combination (n [%]): | | Value | 95% CI | 95% CI | Blinding: +
| Histopathology | NR | NR | Se | 96.0% | 88.2% | 100.0% | Definition of +/- on screening test: +
| Reference standard applied to all test negatives?: | Risk factors (n [%]): | Additional data used for diagnosis: | Sp | 76.0% | 66.4% | 85.6%
| Yes | NR | NR | PPV | 56.1% | 40.9% | 71.3%
| Test reliability established?: | Inclusion criteria: | | NPV | 98.3% | 95.0% | 100.0%
| Interobserver reliability for 2 examiners on 15 cases showed agreement for crescent sign | Scheduled to undergo surgery for adnexal pathology, referred to tertiary referral gyn scanning unit | | 2) PI < 1.0
| Statistical tests used: | Exclusion criteria: | | | Dis+ | Dis- | Tot
| Se, Sp | None | | T+ | 14 | 8 | 22
| Blinding: | | | T- | 10 | 68 | 78
| Yes (prospective study) | | | Tot | 24 | 76 | 100
| Definition of positive and negative on screening test: | | | | | Lower | Upper
| Yes | | | | Value | 95% CI | 95% CI
| Ovarian crescent sign - presence of normal ovarian tissue on TVUS: Criteria to identify normal ovarian tissues were: | | | Se | 58.0% | 38.3% | 77.7%
| Hypoechogenic tissue with or without ovarian follicles located adjacent to the cyst wall, which could not be separated from the cyst by applying a moderate amount of pressure and which was enclosed within the ovarian capsule encircling the tumor. | | | Sp | 89.0% | 82.0% | 96.0%
| Also | | | PPV | 63.6% | 43.5% | 83.7%
| CA-125 ≥ 35 U/ml | | | NPV | 87.2% | 79.8% | 94.6%
| PI < 1.0 | | | 3) CA-125 ≥ 35 U/ml
| | | | | Dis+ | Dis- | Tot
| | | | T+ | 21 | 26 | 47
| | | | T- | 3 | 50 | 53
| | | | Tot | 24 | 76 | 100
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 88.0% | 75.0% | 100.0%
| | | | Sp | 66.0% | 55.3% | 76.7%
| | | | PPV | 44.7% | 30.5% | 58.9%
| | | | NPV | 94.3% | 88.1% | 100.0%
| | | | 4) Tumor volume ≥ 180 mL
| | | | | Dis+ | Dis- | Tot
| | | | T+ | 19 | 35 | 54
| | | | T- | 5 | 41 | 46
| | | | Tot | 24 | 76 | 100
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 79.0% | 62.7% | 95.3%
| | | | Sp | 54.0% | 42.8% | 65.2%
| | | | PPV | 35.2% | 22.4% | 47.9%
| | | | NPV | 89.1% | 80.1% | 98.1%
| | | | 5) Papillary proliferations
| | | | | Dis+ | Dis- | Tot
| | | | T+ | 10 | 10 | 20
| | | | T- | 14 | 66 | 80
| | | | Tot | 24 | 76 | 100
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 41.0% | 21.3% | 60.7%
| | | | Sp | 87.0% | 79.4% | 94.6%
| | | | PPV | 50.0% | 28.1% | 71.9%
| | | | NPV | 82.5% | 74.2% | 90.8%
| | | | 6) Time-averaged maximum velocity (TAMXV ≥ 12 cm/s)
| | | | | Dis+ | Dis- | Tot
| | | | T+ | 15 | 7 | 22
| | | | T- | 9 | 69 | 78
| | | | Tot | 24 | 76 | 100
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 63.0% | 43.7% | 82.3%
| | | | Sp | 91.0% | 84.6% | 97.4%
| | | | PPV | 68.2% | 48.7% | 87.6%
| | | | NPV | 88.5% | 81.4% | 95.6%
Hogdall, Hogdall, Tingulstad, et al., 2000 | Geographical location: | Age: | Symptomatic (n [%]): | 1) Overall sensitivity for CA-125 using a cutpoint of 35U/ml | | | | Comments:
#2610 | Denmark | Benign | NR | | Dis+ | Dis- | Tot | —Data are presented in Table 4 by age 50, but total N seems to indicate that this is based on only the women with ovarian cancer; determination of specificity doesn't seem valid.
| Dates: Sep 1994 to Apr 1996 | Median: 48 | Detected by exam (n [%]): | T+ | 34 | 28 | 62 | Quality assessment:
| Size of population: | Range: 19–86 | NR | T- | 10 | 96 | 106 | Reference standard: +
| 168 | Non-ovarian cancer | Detected by imaging (n [%]): | Tot | 44 | 124 | 168 | Verification bias: +
| Screening study | Median: 69 | NR | | | Lower | Upper | Test reliability/variability: -
| Prospective series | Range: 42–79 | Combination (n [%]): | | Value | 95% CI | 95% CI | Sample size: +
| Reference standard: | Ovarian cancer | NR | Se | 77.3% | 64.9% | 89.7% | Statistical tests: +
| Pathology | Median: 61.5 | Additional data used for diagnosis: | Sp | 77.4% | 70.0% | 84.8% | Blinding: -
| Reference standard applied to all test negatives?: | Range: 31–82 | NR | PPV | 54.8% | 42.5% | 67.2% | Definition of +/- on screening test: -
| Yes | Menopausal status (n [%]): | | NPV | 90.6% | 85.0% | 96.1%
| Test reliability established?: | NR
| ? Interassay coefficient? | Race/ethnicity (n [%]):
| Statistical tests used: | Danish?
| ROC curves | Risk factors (n [%]):
| Mann-Witney | NR
| Spearman-Rank | Inclusion criteria:
| Blinding: | Presence of a pelvic mass and a decision taken to proceed with surgical exploration
| NR | Exclusion criteria:
| Definition of positive and negative on screening test: | NR
| Not pre-specified
| but present Table 3 with“generally accepted cutpoints”
Hricak, Chen, Coakley, et al., 2000 | Geographical location: | Age: | Symptomatic (n [%]): | 1) Non-enhanced MRI | | | | Comments:
#2800 | San Francisco, CA | Mean: 53 | NR | | Dis+ | Dis- | Tot | —LMP tumors grouped into malignant
| University Hospital | Range: 18–83 | Detected by exam (n [%]): | T+ | 83 | 23 | 106 | —Referral population from gynecological clinic- (probability of malignancy before imaging 51%); sicker population, not representative
| Dates: Apr 1993 - May 1996 | Menopausal status (n [%]): | NR | T- | 13 | 68 | 81 | —Data collected and analyzed per mass, not per patient
| Size of population: | NR | Detected by imaging (n [%]): | Tot | 96 | 91 | 187 | Quality assessment:
| 128 women | Race/ethnicity (n [%]): | NR | | | Lower | Upper | Reference standard: +
| (187 masses) | NR | Combination (n [%]): | | Value | 95% CI | 95% CI | Verification bias: +
| Other | Risk factors (n [%]): | NR | Se | 86.5% | 79.6% | 93.3% | Test reliability/variability: +
| Consecutive patients referred for MRI from gynecologist who had surgery | NR | Additional data used for diagnosis: | Sp | 74.7% | 65.8% | 83.7% | Sample size: - not discussed
| Reference standard: | Inclusion criteria: | Compared gadolinium enhanced MRI versus not enhanced | PPV | 78.3% | 70.5% | 86.1% | Statistical tests: +
| Histopathology | Women with diagnosis of adnexal mass referred for MR from Gynoncol clinic who subsequently underwent surgery | | NPV | 84.0% | 76.0% | 91.9% | Blinding: +
| Reference standard applied to all test negatives?: | Exclusion criteria: | | 2) Gadolinium-enhanced MRI | | | | Definition of +/- on screening test: +
| Yes | NR | | | Dis+ | Dis- | Tot
| Test reliability established?: | | | T+ | 91 | 19 | 110
| Yes; inter- and intraobserver variability explicitly measured | | | T- | 5 | 72 | 77
| Statistical tests used: | | | Tot | 96 | 91 | 187
| Logistic regression | | | | | Lower | Upper
| ROC curves | | | | Value | 95% CI | 95% CI
| Se, Sp | | | Se | 94.8% | 90.3% | 99.2%
| Kappa | | | Sp | 79.1% | 70.8% | 87.5%
| Blinding: | | | PPV | 82.7% | 75.7% | 89.8%
| Yes | | | NPV | 93.5% | 88.0% | 99.0%
| Definition of positive and negative on screening test:
| [From ref 19]
| Malignant = at least one of the following primary criteria present: > 4 cm, bilateral, predominantly solid, cystic with wall or septum > 3 mm or papillary projections. OR at least 2 of the following secondary criteria present: ascites, peritoneal metastasis, adenopathy.
Huber, Medl, Baumann, et al., 2002 | Geographical location: | Age: | Symptomatic (n [%]): | 1) US morphology | | | | Comments:
#5700 | Austria | NR | NR | | Dis+ | Dis- | Tot | —Patients all referred with suspicion of ovarian cancer (hence high incidence of cancer in this group)
| Dates: May 1995 - Jan 2001 | Menopausal status (n [%]): | Detected by exam (n [%]): | T+ | 54 | 8 | 62 | —Unclear and not reproducible criteria for + or - US and MRI - no scoring system used
| Size of population: | NR | NR | T- | 9 | 22 | 31 | —Combination TVUS and abdominal US (unable to stratify, no N stated for each)
| 93 | Race/ethnicity (n [%]): | Detected by imaging (n [%]): | Tot | 63 | 30 | 93 | Quality assessment:
| Reference standard: | NR | NR | | | Lower | Upper | Reference standard: +
| Histopathology | Risk factors (n [%]): | Combination (n [%]): | | Value | 95% CI | 95% CI | Verification bias: +
| Reference standard applied to all test negatives?: | NR | NR | Se | 85.0% | 76.2% | 93.8% | Test reliability/variability: -
| Yes | Inclusion criteria: | Additional data used for diagnosis: | Sp | 73.0% | 57.1% | 88.9% | Sample size: -
| Test reliability established?: | Patients suspected of having ovarian cancer in time frame referred for surgery and had imaging done | NR | PPV | 87.1% | 78.8% | 95.4% | Statistical tests: +
| No | Exclusion criteria: | | NPV | 71.0% | 55.0% | 86.9% | Blinding: +
| Statistical tests used: | NR | | 2) MRI | | | | Definition of +/- on screening test: -
| Chi square | | | | Dis+ | Dis- | Tot
| Fisher exact test | | | T+ | 56 | 4 | 60
| Blinding: | | | T- | 7 | 26 | 33
| Yes | | | Tot | 63 | 30 | 93
| Definition of positive and negative on screening test: | | | | | Lower | Upper
| US - “detection of complex (noncystic) and/or solid mass, which was ≥ 5 cm in premenopausal woman or any size in postmenopausal woman. | | | | Value | 95% CI | 95% CI
| MRI - descriptive | | | Se | 89.0% | 81.3% | 96.7%
| | | | Sp | 86.0% | 73.6% | 98.4%
| | | | PPV | 93.3% | 87.0% | 99.6%
| | | | NPV | 78.8% | 64.8% | 92.7%
Hurteau, Woolas, Jacobs, et al., 1995 | Geographical location: | Age: | Symptomatic (n [%]): | 1) CA-125 > 35 | | | | Comments:
#4060 | Patients from London, UK | NR | NR | | Dis+ | Dis- | Tot | —Very unclear patient selection, inclusion and exclusion criteria (numbers don't match up - no explanation of how went from 100 to 92)
| Dates: NR | Menopausal status (n [%]): | Detected by exam (n [%]): | T+ | 32 | 31 | 63 | —Data on IL 2 alpha not included in 2×2 table as this is not a common test
| Size of population: | NR | NR | T- | 7 | 30 | 37 | —Inclusion of healthy subjects not necessarily appropriate for diagnostic (as opposed to screening) test
| Unclear - article mentions 100 patients preop evaluation as well as 88 “healthy subjects”, but analysis done on 92 | Race/ethnicity (n [%]): | Detected by imaging (n [%]): | Tot | 39 | 61 | 100 | Quality assessment:
| Other | NR | NR | | | Lower | Upper | Reference standard: +
| Series in single center | Risk factors (n [%]): | Combination (n [%]): | | Value | 95% CI | 95% CI | Verification bias: +
| Reference standard: | NR | NR | Se | 82.1% | 70.0% | 94.1% | Test reliability/variability: + - not discussed in article but well established test
| Histopathology | Inclusion criteria: | Additional data used for diagnosis: | Sp | 49.2% | 36.6% | 61.7% | Sample size: -
| Reference standard applied to all test negatives?: | Unclear - preop with diagnosis of adnexal mass | NR | PPV | 50.8% | 38.4% | 63.1% | Statistical tests: +/-
| Yes | Exclusion criteria: | | NPV | 81.1% | 68.5% | 93.7% | Blinding: +
| Test reliability established?: | NR | | | | | | Definition of +/- on screening test: +
| Yes
| Statistical tests used:
| Sen, Sp
| Student's t test
| Blinding:
| NR - prospective sampling
| Definition of positive and negative on screening test:
| CA-125 > 35 U/mL
Inoue, Fujita, Nakazawa, et al., 1992 | Geographical location: | Age: | Symptomatic (n [%]): | 1) CA-125 (> 65 U/mL) | | | | Comments:
#5120 | Osaka, Japan | NR | NR | | Dis+ | Dis- | Tot | —CA-125 limit 65U/mL
| University Hospital | Menopausal status (n [%]): | Detected by exam (n [%]): | T+ | 25 | 44 | 69 | —No description of patient population at all
| Dates: Sep 1989 - May 1991 | NR | NR | T- | 40 | 273 | 313 | —5 surface epithelial tumors of LMP were grouped into malignant category
| Size of population: | Race/ethnicity (n [%]): | Detected by imaging (n [%]): | Tot | 65 | 317 | 382 | Quality assessment:
| 382 women | NR | NR | | | Lower | Upper | Reference standard: +
| Other | Risk factors (n [%]): | Combination (n [%]): | | Value | 95% CI | 95% CI | Verification bias: +
| Patents who underwent surgery for adnexal mass | NR | NR | Se | 38.0% | 26.2% | 49.8% | Test reliability/variability: + (COV discussed in serum samples between labs)
| Reference standard: | Inclusion criteria: | Additional data used for diagnosis: | Sp | 86.0% | 82.2% | 89.8% | Sample size: -(not discussed)
| Histopathology | Women undergoing surgery for (presumed) adnexal mass at one of the University hospitals in time frame | None | PPV | 36.2% | 24.9% | 47.6% | Statistical tests: +
| Reference standard applied to all test negatives?: | Exclusion criteria: | | NPV | 87.2% | 83.5% | 90.9% | Blinding: +
| Yes | LMP tumors other than those of surface epithelial-stromal type and non-gynecological tumors. | | 2) CEA | | | | Definition of +/- on screening test: +
| Test reliability established?: | | | | Dis+ | Dis- | Tot
| Yes | | | T+ | 14 | 10 | 24
| Statistical tests used: | | | T- | 51 | 307 | 358
| ROC curves | | | Tot | 65 | 317 | 382
| Se, Sp | | | | | Lower | Upper
| Blinding: | | | | Value | 95% CI | 95% CI
| No | | | Se | 22.0% | 11.9% | 32.1%
| Definition of positive and negative on screening test: | | | Sp | 97.0% | 95.1% | 98.9%
| CA-125 > 65 U/mL | | | PPV | 58.3% | 38.6% | 78.1%
| CEA > 2.4 ng/mL | | | NPV | 85.8% | 82.1% | 89.4%
| | | | Additional data reported for other markers, Sialyl-Tn (STN), sialys-Lewis Xi (SLX), CA 19-9, Tissue polypeptide antigen
Itakura, Kikkawa, Kajiyama, et al., 2003 | Geographical location: | Age: | Symptomatic (n [%]): | 1) Morphological index of De Priest (> 7) | | | | Comments:
#1690 | Japan | Mean (SD): 49.1 | NR | | Dis+ | Dis- | Tot | —Se and Sp reported unclear if for patient or for tumor (most likely for tumor)
| University Hospital | Menopausal status (n [%]): | Detected by exam (n [%]): | T+ | 24 | 15 | 39 | —CA-125 cutoff 65 U/mL
| Dates: Jun 1998 - Jul 2000 | Pre: 41 (48.8%) | NR | T- | 3 | 42 | 45 | —Borderline tumors lumped into malignant
| Size of population: | Post: 43 (51.2%) | Detected by imaging (n [%]): | Tot | 27 | 57 | 84 | Quality assessment:
| 84 women (95 tumors) | Race/ethnicity (n [%]): | NR | | | Lower | Upper | Reference standard: +
| Other | NR | Combination (n [%]): | | Value | 95% CI | 95% CI | Verification bias: +
| Hospital referral for surgery secondary to mass | Risk factors (n [%]): | NR | Se | 90.3% | 79.1% | 100.0% | Test reliability/variability: +
| Reference standard: | NR | Additional data used for diagnosis: | Sp | 73.4% | 61.9% | 84.9% | Sample size: - not discussed
| Histopathology | Inclusion criteria: | NR | PPV | 61.5% | 46.3% | 76.8% | Statistical tests: +/-
| Reference standard applied to all test negatives?: | Patients who underwent surgery at university hospital for mass | | NPV | 93.3% | 86.0% | 100.0% | Blinding: -
| Yes | (not clearly described) | | 2) PI (min < 1.0) | | | | Definition of +/- on screening test: +
| Test reliability established?: | Exclusion criteria: | | | Dis+ | Dis- | Tot
| CA-125 - yes | NR | | T+ | 22 | 8 | 30
| DePriest - yes | | | T- | 5 | 49 | 54
| PI - yes | | | Tot | 27 | 57 | 84
| Statistical tests used: | | | | | Lower | Upper
| Se, Sp | | | | Value | 95% CI | 95% CI
| Blinding: | | | Se | 80.6% | 65.7% | 95.5%
| Prospective study - blinding not discussed | | | Sp | 85.9% | 76.9% | 94.9%
| Definition of positive and negative on screening test: | | | PPV | 73.3% | 57.5% | 89.2%
| CA-125 > 65 U/mL | | | NPV | 90.7% | 83.0% | 98.5%
| Morphological index of DePriest score > 7 | | | 3) CA-125 (> 65 U/ml)
| PI < 1.0 | | | | Dis+ | Dis- | Tot
| | | | T+ | 19 | 7 | 26
| | | | T- | 8 | 50 | 58
| | | | Tot | 27 | 57 | 84
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 70.4% | 53.2% | 87.6%
| | | | Sp | 87.7% | 79.2% | 96.2%
| | | | PPV | 73.1% | 56.0% | 90.1%
| | | | NPV | 86.2% | 77.3% | 95.1%
Jacobs, Oram, Fairbanks, et al., 1990 | Geographical location: | Age: | Symptomatic (n [%]): | 1) CA-125 > 30 | | | | Comments:
#6820 | London | Mean (SD): | NR | | Dis+ | Dis- | Tot | —CA-125 cutoff of 30U/mL used
| Dates: NR | Benign 48.8 (14.3) | Detected by exam (n [%]): | T+ | 34 | 25 | 59 | Quality assessment:
| Size of population: | Malignant 59.0 (11.8) | NR | T- | 8 | 76 | 84 | Reference standard: +
| 143 | Menopausal status (n [%]): | Detected by imaging (n [%]): | Tot | 42 | 101 | 143 | Verification bias: +
| Other | NR | NR | | | Lower | Upper | Test reliability/variability: +
| Consecutive series | Race/ethnicity (n [%]): | Combination (n [%]): | | Value | 95% CI | 95% CI | Sample size: -
| Reference standard: | NR | NR | Se | 81.0% | 69.1% | 92.9% | Statistical tests: +
| Histopathology | Risk factors (n [%]): | Additional data used for diagnosis: | Sp | 75.0% | 66.6% | 83.4% | Blinding: +
| Reference standard applied to all test negatives?: | NR | NR | PPV | 57.6% | 45.0% | 70.2% | Definition of +/- on screening test: + (but didn't explain why 30 U/mL used as cutoff for CA-125)
| Yes | Inclusion criteria: | | NPV | 90.5% | 84.2% | 96.8%
| Test reliability established?: | Consecutive admissions for elective surgical investigation of pelvic mass in hospital in time frame | | 2) US score ≥ 1
| CA-125 - yes | Exclusion criteria: | | | Dis+ | Dis- | Tot
| Statistical tests used: | NR | | T+ | 41 | 52 | 93
| Stepwise logistic regression | | | T- | 0 | 46 | 46
| Se, Sp | | | Tot | 41 | 98 | 139
| RMI | | | | | Lower | Upper
| Blinding: | | | | Value | 95% CI | 95% CI
| NR - but prospective | | | Se | 100.0% | 92.7% | 100.0%
| Definition of positive and negative on screening test: | | | Sp | 46.9% | 37.0% | 56.8%
| CA-125 > 30U/mL | | | PPV | 44.1% | 34.0% | 54.2%
| US: 1 point assigned for each of the following: | | | NPV | 100.0% | 93.5% | 100.0%
| —multilocular cyst | | | 3) US score ≥ 2
| —solid areas | | | | Dis+ | Dis- | Tot
| —metastases | | | T+ | 29 | 17 | 46
| —ascites | | | T- | 12 | 81 | 93
| —bilateral lesion | | | Tot | 41 | 98 | 139
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 70.7% | 56.8% | 84.6%
| | | | Sp | 82.7% | 75.2% | 90.2%
| | | | PPV | 63.0% | 49.1% | 77.0%
| | | | NPV | 87.1% | 80.3% | 93.9%
Jacobs, Stabile, Bridges, et al., 1988 | Geographical location: | Age: | Symptomatic (n [%]): | 1) CA-125 > 30 U/ml (assuming all test negatives truly negative) | | | | Comments:
#6830 | London, UK | Mean: 54 | 0 (0%) | | Dis+ | Dis- | Tot | —Unclear where definition of ovarian volume as abnormal (> 8.8ml) came from
| Dates: NR | Range: 45–83 | Detected by exam (n [%]): | T+ | 1 | 30 | 31 | —Vague criteria for BME
| Size of population: | Menopausal status (n [%]): | NR | T- | 0 | 979 | 979 | —Low incidence of cancer in this screening study
| 1010 screened with BME and CA-125 | Post (> 55): 1010 (100%) | Detected by imaging (n [%]): | Tot | 1 | 1009 | 1010 | —Abdominal US only
| 58 US done secondary to abnormal BME or CA-125 | Race/ethnicity (n [%]): | NR | | | Lower | Upper | Quality assessment:
| 9 went to surgery | NR | Combination (n [%]): | | Value | 95% CI | 95% CI | Reference standard: -
| Screening study | Risk factors (n [%]): | NR | Se | 100.0% | -200.0% | 100.0% | Verification bias: -
| Reference standard: | NR | Additional data used for diagnosis: | Sp | 97.0% | 96.0% | 98.1% | Test reliability/variability: -
| Surgery for 9 repeat US and BME at 3 month intervals for one year for initial abnormals (by CA-125 or BME) | Inclusion criteria: | NR | PPV | 3.2% | 0.0% | 9.4% | Sample size: -
| Reference standard applied to all test negatives?: | NR | | NPV | 100.0% | 99.7% | 100.0% | Statistical tests: +
| No | Exclusion criteria: | | 2) CA-125 > 30U/ml not assuming test negatives true negative (including only those which had US) | | | | Blinding: -
| Test reliability established?: | NR | | | Dis+ | Dis- | Tot | Definition of +/- on screening test: +
| Yes | | | T+ | 1 | 30 | 31
| Statistical tests used: | | | T- | 0 | 27 | 27
| Se, Sp | | | Tot | 1 | 57 | 58
| Blinding: NR | | | | | Lower | Upper
| Definition of positive and negative on screening test: | | | | Value | 95% CI | 95% CI
| BME - “palpable mass of any size ... separate from uterus or GI tract” | | | Se | 100.0% | -200.0% | 100.0%
| CA-125 ≥ 30 U/ml | | | Sp | 47.4% | 34.4% | 60.3%
| US ovarian volume > 8.8ml | | | PPV | 3.2% | 0.0% | 9.4%
| | | | NPV | 100.0% | 88.9% | 100.0%
| | | | 3) BME (assuming all negatives true negative)
| | | | | Dis+ | Dis- | Tot
| | | | T+ | 1 | 27 | 28
| | | | T- | 0 | 982 | 982
| | | | Tot | 1 | 1009 | 1010
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 100.0% | -200.0% | 100.0%
| | | | Sp | 97.3% | 96.3% | 98.3%
| | | | PPV | 3.6% | 0.0% | 10.4%
| | | | NPV | 100.0% | 99.7% | 100.0%
| | | | 4) BME not assuming test negatives true negative
| | | | | Dis+ | Dis- | Tot
| | | | T+ | 1 | 27 | 28
| | | | T- | 0 | 30 | 30
| | | | Tot | 1 | 57 | 58
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 100.0% | -200.0% | 100.0%
| | | | Sp | 52.6% | 39.7% | 65.6%
| | | | PPV | 3.6% | 0.0% | 10.4%
| | | | NPV | 100.0% | 90.0% | 100.0%
| | | | 4) US alone (ovarian volume > 8.8ml)
| | | | | Dis+ | Dis- | Tot
| | | | T+ | 1 | 12 | 13
| | | | T- | 0 | 45 | 45
| | | | Tot | 1 | 57 | 58
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 100.0% | -200.0% | 100.0%
| | | | Sp | 78.9% | 68.4% | 89.5%
| | | | PPV | 7.7% | 0.0% | 22.2%
| | | | NPV | 100.0% | 93.3% | 100.0%
Jain, 1994 | Geographical location: | Age: | Symptomatic (n [%]): | 1) RI < 0.4 of MASSES | | | | Comments:
#4620 | Stanford, CA | Mean: 43 | NR | | Dis+ | Dis- | Tot | —Data presented such that LMP could be easily excluded from analysis
| Dates: NR | Range: 33–55 | Detected by exam (n [%]): | T+ | 7 | 7 | 14 | —Unclear if anyone other than author did US examinations
| Size of population: | Menopausal status (n [%]): | NR | T- | 2 | 33 | 35 | —No discussion of inter/intra operator variability
| 42 women (50 masses) | NR | Detected by imaging (n [%]): | Tot | 9 | 40 | 49 | —Data presented with N = masses not patients
| Other | Race/ethnicity (n [%]): | NR | | | Lower | Upper | Quality assessment:
| Prospective series of surgical cases with US | NR | Combination (n [%]): | | Value | 95% CI | 95% CI | Reference standard: +
| Reference standard: | Risk factors (n [%]): | NR | Se | 77.8% | 50.6% | 100.0% | Verification bias: +
| Histopathology | NR | Additional data used for diagnosis: | Sp | 82.5% | 70.7% | 94.3% | Test reliability/variability: -
| Reference standard applied to all test negatives?: | Inclusion criteria: | NR | PPV | 50.0% | 23.8% | 76.2% | Sample size: -
| Yes | 42 women with clinically suspected adnexal masses undergoing surgery - US performed 1–5 days prior | | NPV | 94.3% | 86.6% | 100.0% | Statistical tests: -
| Test reliability established?: | Exclusion criteria: | | 2) US (MASSES) | | | | Blinding: +/-
| RI - yes | Obstetrical cases | | | Dis+ | Dis- | Tot | Definition of +/- on screening test: -
| US - not really (references his own article the next in this batch #4950) | | | T+ | 9 | 2 | 11
| Statistical tests used: | | | T- | 0 | 38 | 38
| NR | | | Tot | 9 | 40 | 49
| Blinding: | | | | | Lower | Upper
| NR - but prospective | | | | Value | 95% CI | 95% CI
| Definition of positive and negative on screening test: | | | Se | 100.0% | 66.7% | 100.0%
| RI < 0.4 | | | Sp | 95.0% | 88.2% | 100.0%
| Grey scale US - | | | PPV | 81.8% | 59.0% | 100.0%
| Presence of any of the following: | | | NPV | 100.0% | 92.1% | 100.0%
| Irregular solid portion, irregular wall, thick irregular septa, mural notdule; Doppler done, but neovascularization not required for diagnosis of malignancy
Jain, Friedman, Pettinger, et al., 1993 | Geographical location: | Age: | Symptomatic (n [%]): | 1) US: Cancer vs. benign | | | | Comments:
#4950 | Davis and Palo Alto, CA | Mean: 41.5 | NR | | Dis+ | Dis- | Tot | —Kappa calculated
| Dates: NR | Range: 29–54 | Detected by exam (n [%]): | T+ | 3 | 14 | 17 | —Unclear how individuals chosen for study (if not consecutive)
| Size of population: | Menopausal status (n [%]): | NR | T- | 0 | 20 | 20 | —US score consisted of diagnosis as did MRI - ?reproducible
| 32 | NR | Detected by imaging (n [%]): | Tot | 3 | 34 | 37 | —Pathology not available for all, laproscopy patients had FNA with examination of ovaries
| Other | Race/ethnicity (n [%]): | NR | | | Lower | Upper | —Se/Sp based on masses, not patients
| Prospective series | NR | Combination (n [%]): | | Value | 95% CI | 95% CI | Quality assessment:
| Reference standard: | Risk factors (n [%]): | NR | Se | 100.0% | 0.0% | 100.0% | Reference standard: +
| Histopathology or FNA at time of laparoscopy | NR | Additional data used for diagnosis: | Sp | 60.0% | 43.5% | 76.5% | Verification bias: +/-
| Reference standard applied to all test negatives?: | Inclusion criteria: | NR | PPV | 17.6% | 0.0% | 35.8% | Test reliability/variability: +
| Yes | Prospective women with suspected masses at hospital scheduled for surgery | | NPV | 100.0% | 85.0% | 100.0% | Sample size: -
| Test reliability established?: | Exclusion criteria: | | 2) MRI: Cancer vs. benign | | | | Statistical tests: +/-
| MRI - | NR | | | Dis+ | Dis- | Tot | Blinding: +
| Statistical tests used: | | | T+ | 2 | 0 | 2 | Definition of +/- on screening test: -
| Kappa, Se, Sp | | | T- | 1 | 34 | 35
| Blinding: | | | Tot | 3 | 34 | 37
| NR - but prospective | | | | | Lower | Upper
| Definition of positive and negative on screening test: | | | | Value | 95% CI | 95% CI
| Descriptive diagnostic criteria for both MRI and US - “simple cyst, hem cyst, endometrioma, dermoid, pedunc fibroid, ovarian carcinoma, ovarian torsion” | | | Se | 67.0% | 13.8% | 100.0%
| | | | Sp | 100.0% | 91.2% | 100.0%
| | | | PPV | 100.0% | 0% | 100.0%
| | | | NPV | 97.1% | 91.6% | 100.0%
Juhasz, Kurjak, Lampe, et al., 1990 | Geographical location: | Age: | Symptomatic (n [%]): | 1) Color flow present or absent | | | | Comments:
#10860 | Yugoslavia and Hungary | NR | NR | | Dis+ | Dis- | Tot | —Unclear exactly what was meant by present flow on Doppler
| Dates: NR | Menopausal status (n [%]): | Detected by exam (n [%]): | T+ | 21 | 17 | 38 | —No description of patient characteristics
| Size of population: | NR | NR | T- | 1 | 108 | 109 | —TVUS only
| 147 | Race/ethnicity (n [%]): | Detected by imaging (n [%]): | Tot | 22 | 125 | 147 | Quality assessment:
| Case series | NR | NR | | | Lower | Upper | Reference standard: +
| Reference standard: | Risk factors (n [%]): | Combination (n [%]): | | Value | 95% CI | 95% CI | Verification bias: +
| Histopathology | NR | NR | Se | 95.5% | 86.8% | 100.0% | Test reliability/variability: -
| Reference standard applied to all test negatives?: | Inclusion criteria: | Additional data used for diagnosis: | Sp | 86.4% | 80.4% | 92.4% | Sample size: -
| Yes | NR | NR | PPV | 55.3% | 39.5% | 71.1% | Statistical tests: -
| Test reliability established?: | Exclusion criteria: | | NPV | 99.1% | 97.3% | 100.0% | Blinding: -
| Yes | NR | | | | | | Definition of +/- on screening test: -
| Statistical tests used:
| Se, Sp
| Blinding:
| NR
| Definition of positive and negative on screening test:
| Presence or absence of color flow within adnexal mass on Doppler
Kawahara, Yoshida, Kurokawa, et al., 2004 | Geographical location: | Age: | Symptomatic (n [%]): | 1) MRI | | | | Comments:
#10 | Fukui, Japan | NR | NR | | Dis+ | Dis- | Tot | —LMP tumors grouped in with malignant
| Dates: Sept 2001 - Aug 2003 | Menopausal status (n [%]): | Detected by exam (n [%]): | T+ | 21 | 2 | 23 | —Patient referral from onc clinic, not representative, sicker
| Size of population: | NR | NR | T- | 2 | 13 | 15 | —MRI scoring system vague and not reproducible
| 38 | Race/ethnicity (n [%]): | Detected by imaging (n [%]): | Tot | 23 | 15 | 38 | —No discussion of inter/intra observer variability
| Other | NR | NR | | | Lower | Upper | —In reporting PET results authors state “the benign tumors were correctly identified as negative for malignancy in all 13 patients with benign lesion”however there were 15 patients with benign lesions
| Series of suspected ovarian cancer cases who went to surgery | Risk factors (n [%]): | Combination (n [%]): | | Value | 95% CI | 95% CI | Quality assessment:
| Reference standard: | NR | NR | Se | 91.3% | 79.8% | 100.0% | Reference standard: +
| Histopathology | Inclusion criteria: | Additional data used for diagnosis: | Sp | 86.7% | 69.5% | 100.0% | Verification bias: +
| Reference standard applied to all test negatives?: | Patients who had been screened in gynecological oncology clinic with BME and US and considered to have masses suspicious for malignancy | NR | PPV | 91.3% | 79.8% | 100.0% | Test reliability/variability: -
| Yes | Exclusion criteria: | | NPV | 86.7% | 69.5% | 100.0% | Sample size: -
| Test reliability established?: | NR | | 2) FDG-PET | | | | Statistical tests: -
| MRI - yes | | | | Dis+ | Dis- | Tot | Blinding: +/-
| PET scan - ? | | | T+ | 18 | 0 | 18 | Definition of +/- on screening test: -
| Statistical tests used: | | | T- | 5 | 15 | 20
| Se, Sp | | | Tot | 23 | 15 | 38
| Blinding: | | | | | Lower | Upper
| NR - prospective study | | | | Value | 95% CI | 95% CI
| Definition of positive and negative on screening test: | | | Se | 78.3% | 61.4% | 95.1%
| MRI - if any of these features was met, mass considered suspicious for malignancy: “cystic without solid areas, diameter of 4cm or less, wall thickness < 0.3 cm, the presence of typical characteristics of dermoid cyst or endometrioma” | | | Sp | 100.0% | 80.0% | 100.0%
| For PET scan with 18-Flourodeoxyglucose - “hypermetabolic lesions that were more intense than the liver and not attributable to bladder etc. were considered positive for malignancy” | | | PPV | 100.0% | 83.3% | 100.0%
| | | | NPV | 75.0% | 56.0% | 94.0%
Kawai, Kikkawa, Ishikawa, et al., 1994 | Geographical location: | Age: | Symptomatic (n [%]): | 1) Doppler | | | | Comments:
#10940 | Japan | NR | NR | | Dis+ | Dis- | Tot | —Means of evaluating Doppler (1/PI) is unusual and not justified in text
| Dates: Apr 1990 - Aug 1993 | Menopausal status (n [%]): | Detected by exam (n [%]): | T+ | 30 | 14 | 44 | —Cut point for PI of 1.25 is also unusual
| Size of population: | NR | NR | T- | 10 | 55 | 65 | —LMP tumors grouped in with malignant
| 109 | Race/ethnicity (n [%]): | Detected by imaging (n [%]): | Tot | 40 | 69 | 109 | —Calculated PPV and NPV differ slightly from text
| Case series | NR | NR | | | Lower | Upper | —TVUS only
| Reference standard: | Risk factors (n [%]): | Combination (n [%]): | | Value | 95% CI | 95% CI | Quality assessment:
| Histopathology | NR | NR | Se | 75.0% | 61.6% | 88.4% | Reference standard: +
| Reference standard applied to all test negatives?: | Inclusion criteria: | Additional data used for diagnosis: | Sp | 79.2% | 69.6% | 88.8% | Verification bias: +
| Yes | NR | NR | PPV | 68.2% | 54.4% | 81.9% | Test reliability/variability: -
| Test reliability established?: | Exclusion criteria: | | NPV | 84.6% | 75.8% | 93.4% | Sample size: -
| Yes | NR | | 2) CA-125 > 35U/ml | | | | Statistical tests: -
| Statistical tests used: | | | | Dis+ | Dis- | Tot | Blinding: -
| Student's t test | | | T+ | 29 | 37 | 66 | Definition of +/- on screening test: -
| Chi square analysis | | | T- | 11 | 32 | 43
| Blinding: | | | Tot | 40 | 69 | 109
| NR | | | | | Lower | Upper
| Definition of positive and negative on screening test: | | | | Value | 95% CI | 95% CI
| Doppler: 1/PI with cutoff 0.8 (which equals a cutoff for PI of 1.25) | | | Se | 72.2% | 58.3% | 86.1%
| CA-125 > 35 U/ml | | | Sp | 45.8% | 34.0% | 57.6%
| CA-72–4 > 4U/ml | | | PPV | 43.9% | 32.0% | 55.9%
| CA-19-9 > 37U/ml | | | NPV | 74.4% | 61.4% | 87.5%
| | | | 3) CA-72-4
| | | | | Dis+ | Dis- | Tot
| | | | T+ | 17 | 12 | 29
| | | | T- | 23 | 57 | 80
| | | | Tot | 40 | 69 | 109
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 41.7% | 26.4% | 57.0%
| | | | Sp | 83.3% | 74.5% | 92.1%
| | | | PPV | 58.6% | 40.7% | 76.5%
| | | | NPV | 71.3% | 61.3% | 81.2%
| | | | 4) CA-19-9
| | | | | Dis+ | Dis- | Tot
| | | | T+ | 14 | 12 | 26
| | | | T- | 26 | 57 | 83
| | | | Tot | 40 | 69 | 109
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 36.1% | 21.2% | 51.0%
| | | | Sp | 83.3% | 74.5% | 92.1%
| | | | PPV | 53.8% | 34.7% | 73.0%
| | | | NPV | 68.7% | 58.7% | 78.7%
Komatsu, Konishi, Mandai, et al., 1996 | Geographical location: | Age: | Symptomatic (n [%]): | 1) US: benign vs. malignant (US class 0 or 1a benign, all other malignant); borderline counted as malignancy | | | | Comments:
#4050 | Kyoto, Japan | Mean: 45.9 | NR | | Dis+ | Dis- | Tot | —Unclear how patients chosen for study (consecutive? ...)
| Dates: May 1989 - May 1993 | Rang: 17–89 | Detected by exam (n [%]): | T+ | 34 | 26 | 60 | —Clinical presentation not described
| Size of population: | Menopausal status (n [%]): | NR | T- | 0 | 22 | 22 | —Outcome of 73 patients who did not undergo surgery not described
| 82 | Pre (≤ 45): 54 (65.9%) | Detected by imaging (n [%]): | Tot | 34 | 48 | 82 | —Over half of masses were malignant
| Other | Post (≥ 55): 28 (34.1%) | NR | | | Lower | Upper | —Results not stratified by age/menopausal status
| Retrospective case series comparing US and MR | Race/ethnicity (n [%]): | Combination (n [%]): | | Value | 95% CI | 95% CI | Quality assessment:
| Reference standard: | NR | NR | Se | 100.0% | 91.2% | 100.0% | Reference standard: +; pathology
| Histopathology | Risk factors (n [%]): | Additional data used for diagnosis: | Sp | 45.8% | 31.7% | 59.9% | Verification bias: -; large portion did not undergo surgery
| Reference standard applied to all test negatives?: | NR | NR | PPV | 56.7% | 44.1% | 69.2% | Test reliability/variability: -; not described
| Yes | Inclusion criteria: | | NPV | 100.0% | 86.4% | 100.0% | Sample size: -; wide Cls
| Test reliability established?: | NR | | 2) MRI: benign vs. malignant (MRI class 1b malignant, all others benign); borderline counted as malignancy | | | | Statistical tests: -; 2×2 tables not presented
| Statistical tests used: | Exclusion criteria: | | | Dis+ | Dis- | Tot | Blinding: +
| Blinding: | NR | | T+ | 31 | 3 | 34 | Definition of +/- on screening test:
| Yes | | | T- | 3 | 22 | 25
| Definition of positive and negative on screening test: | | | Tot | 34 | 25 | 59
| US classification: | | | | | Lower | Upper
| 0 = cyst with well-defined, thin wall | | | | Value | 95% CI | 95% CI
| 1a = septation | | | Se | 91.2% | 81.6% | 100.0%
| 1b = solid tissueCA-125 > 35 U/ml | | | Sp | 88.0% | 75.3% | 100.0%
| 2a = complex mass with internal structure with diffuse low-level echoes, no distinct findings of cyst | | | PPV | 91.2% | 81.6% | 100.0%
| 2b = complex mass with internal structure with excrescences with lowlevel echoes and blurred margin | | | NPV | 88.0% | 75.3% | 100.0%
| 1b, 2a, 2b considered possibly malignant
| MRI:
| 0 = cyst with well-defined wall, no internal enhancement, homogenous low intensity on T-1 weighted images, high intensity on T2
| 1a = neoplasm with septation
| 1b = solid
| 2a = cystic mass with complex fluid such as blood, proteinaceous fluid, or fat
| 2b = cystic mass with unenhanced excrescences
| 1b considered possibly malignant
Kurjak and Kupesic, 1999 | Geographical location: | Age: | Symptomatic (n [%]): | 1) 2D US combined | | | | Comments:
#2920 | Zagreb, Croatia | Mean (SD): | NR | | Dis+ | Dis- | Tot | —TVUS and 3D/Doppler scoring systems invented by authors (?) and no reference of use given (no reliability calculation etc.) - reproducibility?
| University Hospital | Pre 34 | Detected by exam (n [%]): | T+ | 10 | 3 | 13 | —Same group of patients as #2820
| Dates: Jan 1997 - Jun 1998 | Peri 49 | NR | T- | 1 | 106 | 107 | Quality assessment:
| Size of population: | Post 61 | Detected by imaging (n [%]): | Tot | 11 | 109 | 120 | Reference standard: +
| 120 women | Range: 18–77 | NR | | | Lower | Upper | Verification bias: +
| Other | Menopausal status (n [%]): | Combination (n [%]): | | Value | 95% CI | 95% CI | Test reliability/variability: -
| Patients scheduled for surgery at university hospital | Pre: 76 (63.3%) | NR | Se | 90.9% | 73.9% | 100.0% | Sample size: -
| Reference standard: | Peri: 7 (5.8%) | Additional data used for diagnosis: | Sp | 97.3% | 94.2% | 100.0% | Statistical tests: +
| Histopathology | Post: 37 (30.8%) | NR | PPV | 76.9% | 54.0% | 99.8% | Blinding: +
| Reference standard applied to all test negatives?: | Race/ethnicity (n [%]): | | NPV | 99.1% | 97.2% | 100.0% | Definition of +/- on screening test: +
| Yes | NR | | 2) 3D US combined
| Test reliability established?: | Risk factors (n [%]): | | | Dis+ | Dis- | Tot
| No | NR | | T+ | 11 | 1 | 12
| Statistical tests used: | Inclusion criteria: | | T- | 0 | 108 | 108
| Se, Sp | Not clearly stated - women with masses to undergo surgery in hospital | | Tot | 11 | 109 | 120
| Blinding: | Premenopausal women had US during early proliferative phase only | | | | Lower | Upper
| No - but prospective | Exclusion criteria: | | | Value | 95% CI | 95% CI
| Definition of positive and negative on screening test: | NR | | Se | 100.0% | 72.7% | 100.0%
| TVUS score ≥ 5 (where +2 for papillarities > 3 mm, +1 for shadowing present, +1 for septa > 3 mm, +2 for solid parts present, +2 for mixed or high echogenicity, +1 for peritoneal fluid, +2 for RI ≤ 0.42 | | | Sp | 99.1% | 97.3% | 100.0%
| 3D US score > 7 (where +2 for papilarities, +1 for present shadowing, +1 for septa >3 mm, +2 for solid parts present, +2 for mixed or high echogenicity, +1 for peritoneal fluid present, +2 for irregular surface, +2 for relation with surrounding structures disturbed, +2 for chaotic vessel arrangement, +2 for complex branching pattern) | | | PPV | 91.7% | 76.0% | 100.0%
| | | | NPV | 100.0% | 97.2% | 100.0%
Kurjak, Kupesic, Sparac, et al., 2000 | Geographical location: | Age: | Symptomatic (n [%]): | 1) 2D alone (B-mode) | | | | Comments:
#2560 | Zagreb, Croatia | Mean (SD): | NR | | Dis+ | Dis- | Tot | —The scale used for scoring invented by authors - not independently verified, not part of the literature (used also in #2920)
| University Hospital | Pre - 34 | Detected by exam (n [%]): | T+ | 6 | 5 | 11 | —Differentiation of US from Doppler assessment in terms of scale not clear
| Dates: Jan 1998 - Jun 1999 | Peri - 49 | NR | T- | 3 | 76 | 79 | Quality assessment:
| Size of population: | Post - NR | Detected by imaging (n [%]): | Tot | 9 | 81 | 90 | Reference standard: +
| 90 women | Median: | NR | | | Lower | Upper | Verification bias: +
| Other | Range: 18–77 | Combination (n [%]): | | Value | 95% CI | 95% CI | Test reliability/variability: -
| Prospective patients with masses for surgery in university hospital | Menopausal status (n [%]): | NR | Se | 66.7% | 35.9% | 97.5% | Sample size: -
| Reference standard: | Pre: 58 (64.4%) | Additional data used for diagnosis: | Sp | 93.8% | 88.6% | 99.1% | Statistical tests: +/-
| Histopathology | Peri: 4 (4.4%) | NR | PPV | 54.5% | 25.1% | 84.0% | Blinding: +
| Reference standard applied to all test negatives?: | Post: 28 (31.1%) | | NPV | 96.2% | 92.0% | 100.0% | Definition of +/- on screening test: +/-
| Yes | Race/ethnicity (n [%]): | | 2) 2D Doppler alone RI ≤ 0.42
| Test reliability established?: | NR | | | Dis+ | Dis- | Tot
| No (although same scale used in articles #2820 or #2920) | Risk factors (n [%]): | | T+ | 8 | 4 | 12
| Statistical tests used: | NR | | T- | 1 | 77 | 78
| Se, Sp | Inclusion criteria: | | Tot | 9 | 81 | 90
| Blinding: | Prospective patients with ovarian mass scheduled to Have surgery in hospital | | | | Lower | Upper
| Yes | Exclusion criteria: | | | Value | 95% CI | 95% CI
| Definition of positive and negative on screening test: | NR | | Se | 88.9% | 68.4% | 100.0%
| 2D US | | | Sp | 95.1% | 90.3% | 99.8%
| for 2D alone score ≥ 3 is positive | | | PPV | 66.7% | 40.0% | 93.3%
| for Doppler alone score ≥ 2 is positive | | | NPV | 98.7% | 96.2% | 100.0%
| for combined 2D score ≥ 5 score is positive where +2 for papillarities, +1 for shadowing present, +1 for septa > 3 mm thick, +2 for solid parts present, +2 for mixed of high level echogenicity, +1 for peritoneal fluid present, +2 for RI ≤ 0.42 | | | 3) Combined 2D US and Doppler
| 3D US score ≥ 5 is+ | | | | Dis+ | Dis- | Tot
| for Doppler alone score ≥ 2+ for combined score ≥ 7 where +2 for papillarities, +1 for shadowing present, +1 for septa > 3 mm thick, +2 for solid parts present, +2 for mixed of high level echogenicity, +1 for peritoneal fluid present, +2 for irregular surface, +2 for disturbed relation with surrounding structures, +2 for chaotic vessel arrangement, +2 for complex branching pattern | | | T+ | 8 | 2 | 10
| | | | T- | 1 | 79 | 80
| | | | Tot | 9 | 81 | 90
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 88.9% | 68.4% | 100.0%
| | | | Sp | 97.5% | 94.1% | 100.0%
| | | | PPV | 80.0% | 55.2% | 100.0%
| | | | NPV | 98.8% | 96.3% | 100.0%
| | | | 4) 3D TVUS
| | | | | Dis+ | Dis- | Tot
| | | | T+ | 7 | 2 | 9
| | | | T- | 2 | 79 | 81
| | | | Tot | 9 | 81 | 90
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 77.8% | 50.6% | 100.0%
| | | | Sp | 97.5% | 94.1% | 100.0%
| | | | PPV | 77.8% | 50.6% | 100.0%
| | | | NPV | 97.5% | 94.2% | 100.0%
| | | | 5) 3D Doppler
| | | | | Dis+ | Dis- | Tot
| | | | T+ | 8 | 2 | 10
| | | | T- | 1 | 79 | 80
| | | | Tot | 9 | 81 | 90
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 88.9% | 68.4% | 100.0%
| | | | Sp | 97.5% | 94.1% | 100.0%
| | | | PPV | 80.0% | 55.2% | 100.0%
| | | | NPV | 98.8% | 96.3% | 100.0%
| | | | 6) Combined 3D
| | | | | Dis+ | Dis- | Tot
| | | | T+ | 9 | 1 | 10
| | | | T- | 0 | 80 | 80
| | | | Tot | 9 | 81 | 90
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 100.0% | 66.7% | 100.0%
| | | | Sp | 98.8% | 96.4% | 100.0%
| | | | PPV | 90.0% | 71.4% | 100.0%
| | | | NPV | 100.0% | 96.3% | 100.0%
Kurjak and Predanic, 1992 | Geographical location: | Age: | Symptomatic (n [%]): | 1) Morphologic scoring system | | | | Comments:
#4990 | Zagreb Croatia | Mean (SD): 48 | NR | | Dis+ | Dis- | Tot | —Article attempts to verify scoring system these authors developed and used previously (in #2820 and #2560) (modification of Sassone criteria)
| University Hospital | Range: 19–76 | Detected by exam (n [%]): | T+ | 35 | 7 | 42 | —Data analyzed in terms of masses not individuals
| Dates: Sep 1990 - Sep 1991 | Menopausal status (n [%]): | Presumably 100% | T- | 3 | 129 | 132 | Quality assessment:
| Size of population: | Pre: 111 (72%) | Detected by imaging (n [%]): | Tot | 38 | 136 | 174 | Reference standard: +
| 812 women screened with US in whom 174 masses detected in 154 women | Post: 43 (28%) | Not applicable | | | Lower | Upper | Verification bias: +
| Other | Race/ethnicity (n [%]): | Combination (n [%]): | | Value | 95% CI | 95% CI | Test reliability/variability: -
| Combination - initially screening of women with “clinical suspicion of mass” then analysis of subset who went to surgery (n = 154) | NR | NR | Se | 92.1% | 83.5% | 100.0% | Sample size: -
| Reference standard: | Risk factors (n [%]): | Additional data used for diagnosis: | Sp | 94.8% | 91.1% | 98.5% | Statistical tests: - (no discussion in any of their papers of kappa etc.)
| For subset - Histopathology | NR | NR | PPV | 83.3% | 72.1% | 94.6% | Blinding: +/-
| Reference standard applied to all test negatives?: | Inclusion criteria: | | NPV | 97.7% | 95.2% | 100.0% | Definition of +/- on screening test: +
| Yes for subset | Initially, all women referred to hospital in time frame with clinical suspicion of adnexal mass. Then those who had mass on US and went to surgery | | 2) Color Doppler scoring system
| Test reliability established?: | Exclusion criteria: | | | Dis+ | Dis- | Tot
| No | NR | | T+ | 37 | 0 | 37
| Statistical tests used: | | | T- | 1 | 136 | 137
| Se, Sp | | | Tot | 38 | 136 | 174
| Blinding: | | | | | Lower | Upper
| NR but prospective | | | | Value | 95% CI | 95% CI
| Definition of positive and negative on screening test: | | | Se | 97.3% | 92.1% | 100.0%
| TVUS | | | Sp | 100.0% | 97.8% | 100.0%
| for 2D alone score ≥ 3 is positive | | | PPV | 100.0% | 91.9% | 100.0%
| for Doppler alone score ≥ 2 is positive | | | NPV | 99.3% | 97.8% | 100.0%
| for combined 2D score ≥ 5 score is positive where +2 for papillarities, +1 for shadowing present, +1 for septa > 3 mm thick, +2 for solid parts present, +2 for mixed of high level echogenicity, +1 for peritoneal fluid present, +2 for RI ≤ 0.42 | | | 3) Combined Doppler and morphology
| | | | | Dis+ | Dis- | Tot
| | | | T+ | 37 | 0 | 37
| | | | T- | 1 | 136 | 137
| | | | Tot | 38 | 136 | 174
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 97.3% | 92.1% | 100.0%
| | | | Sp | 100.0% | 97.8% | 100.0%
| | | | PPV | 100.0% | 91.9% | 100.0%
| | | | NPV | 99.3% | 97.8% | 100.0%
Kurjak, Schulman, Sosic, et al., 1992 | Geographical location: | Age: | Symptomatic (n [%]): | 1) For RI < 0.41 | | | | Comments:
#5020 | Zagreb, Croatia | NR | For N = 1000, 257 (25.7%) were symptomatic | | Dis+ | Dis- | Tot | —US scoring system although illustrated in figure 1, was not described in text - unclear where and how scoring system derived, if tested/verified ...
| Dates: 1989-1990 | Menopausal status (n [%]): | For N = 83 of the 29 with malignant tumors, 25 were symptomatics | T+ | 28 | 3 | 31 | —RI cutoff of < 0.41 used based upon distribution of RI data points in from this study itself - also similar to prior retrospective cutpoint by study authors
| Size of population: | Post (> 55): 83 (100%) | Detected by exam (n [%]): | T- | 1 | 51 | 52 | —Doppler Index - although descriptive in nature, appears in data to be identical to the RI results, with the exception that the RI “unable to measure” are included in results as 0 leading to a drop in sensitivity of results
| 1000 screened | Race/ethnicity (n [%]): | NR | Tot | 29 | 54 | 83 | —No discussion of inter/intra observer variability
| 83 operated on | NR | Detected by imaging (n [%]): | | | Lower | Upper | —Numbers in Table 4 inconsistent
| Screening study | Risk factors (n [%]): | For N = 1000, 83 had US that lead to surgery (8.3%) | | Value | 95% CI | 95% CI | —Followup of initial test negatives not reported
| For N = 83, operative series | NR | Combination (n [%]): | Se | 96.0% | 88.9% | 100.0% | Quality assessment:
| Reference standard: | Inclusion criteria: | NR | Sp | 95.0% | 89.2% | 100.0% | Reference standard: +
| Histopathology (for N = 83) | Age > 40 | Additional data used for diagnosis: | PPV | 90.3% | 79.9% | 100.0% | Verification bias: + for surgical series, - for screening series
| Reference standard applied to all test negatives?: | At least 12 months since LMP | NR | NPV | 98.1% | 94.3% | 101.0% | Test reliability/variability: -
| Yes for N = 83 | Criteria for surgery included: | | 2) US morphology | | | | Sample size: -
| Test reliability established?: | Mass 5 cm or greater on at least 2 exams | | | Dis+ | Dis- | Tot | Statistical tests: +
| Yes | Cyst associated with persistent or acute pain | | T+ | 14 | 1 | 15 | Blinding: - - but prospective
| Statistical tests used: | Enlarged ovary or cyst with RI “near” 0.4 on 2 separate | | T- | 15 | 53 | 68 | Definition of +/- on screening test: + for RI, +/- for US
| Chi-square | Exclusion criteria: | | Tot | 29 | 54 | 83
| Fisher exact | NR | | | | Lower | Upper
| Student t test | | | | Value | 95% CI | 95% CI
| Se, Sp | | | Se | 48.0% | 29.8% | 66.2%
| Blinding: | | | Sp | 98.0% | 94.3% | 100.0%
| NR - but prospective | | | PPV | 93.3% | 80.7% | 100.0%
| Definition of positive and negative on screening test: | | | NPV | 77.9% | 68.1% | 87.8%
| RI < 0.41 | | | 3) For Doppler score (> 2)
| US morphology score > 4 | | | | Dis+ | Dis- | Tot
| (figure 1): | | | T+ | 26 | 1 | 27
| Color Doppler score - 0 for vessels not seen, 1 for regular separate vessels, 2 for randomly dispersed vessels | | | T- | 3 | 53 | 56
| | | | Tot | 29 | 54 | 83
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 89.7% | 78.6% | 100.0%
| | | | Sp | 98.1% | 94.6% | 100.0%
| | | | PPV | 96.3% | 89.2% | 100.0%
| | | | NPV | 94.6% | 88.7% | 100.0%
| | | | 4) For combined US and Doppler (< 6)
| | | | | Dis+ | Dis- | Tot
| | | | T+ | 26 | 3 | 29
| | | | T- | 3 | 51 | 54
| | | | Tot | 29 | 54 | 83
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 89.7% | 78.6% | 100.0%
| | | | Sp | 94.4% | 88.3% | 100.0%
| | | | PPV | 89.7% | 78.6% | 100.0%
| | | | NPV | 94.4% | 88.3% | 100.0%
Kurjak, Shalan, Kupesic, et al., 1994 | Geographical location: | Age: | Symptomatic (n [%]): | 1) US - persistent mass; only those with surgical confirmation | | | | Comments:
#4470 | Zagreb, Croatia | Mean (SD): | 0 (0%) | | Dis+ | Dis- | Tot | —Decision to operate not described
| Dates: Jan 1988 to Dec 1992 | Pre 45.1 (3.5) | Detected by exam (n [%]): | T+ | 4 | 1 | 5 | —Screening series not complete - 316 women undergoing followup US still (from total of 404 needing it!) - this is confusing
| Size of population: | Post 56.2 (5.2) | 0 (0%) | T- | 0 | 27 | 27 | —Unclear what was used in US diagnosis (assume from title combination of doppler and US morphology, but nothing in article)
| 5013 screened | Range: 4–71 | Detected by imaging (n [%]): | Tot | 4 | 28 | 32 | —US followup after 6 months, but span of time not mentioned
| 38 operated on | Menopausal status (n [%]): | NR | | | Lower | Upper | —Assume 100% followup? - no discussion of drop out etc.
| Screening study | Pre (< 45): 2214 (44%) | Combination (n [%]): | | Value | 95% CI | 95% CI | —No discussion of inter/intra observer variability
| Reference standard: | Post (> 55): 2799 (56%) | NR | Se | 100.0% | 25.0% | 100.0% | —Results not stratified by age/menopausal status
| Histopathology for few who went to surgery | Race/ethnicity (n [%]): | Additional data used for diagnosis: | Sp | 96.4% | 89.6% | 100.0% | Quality assessment:
| Otherwise repeat US | NR | Premenopausal women scanned during day 3–8 of cycle | PPV | 80.0% | 44.9% | 100.0% | Reference standard: +/-
| Reference standard applied to all test negatives?: | Risk factors (n [%]): | STUDY FLOW - | NPV | 100.0% | 88.9% | 100.0% | Verification bias: —
| No | NR | 5013 screened | 2) US, assuming all test negative true negatives, excluding 316 with results not reported | | | | Test reliability/variability: -
| But US repeated in initial abnormals (cycstic structures less than 5cm) followed up after 6 months | Inclusion criteria: | 424 abnormal ovaries, of whom 20 went to surgery, leaving | | Dis+ | Dis- | Tot | Sample size: -
| Test reliability established?: | Age ≥ 40 | 404 repeat US (316 still pending), of whom 70 resolved spontaneously | T+ | 4 | 1 | 5 | Statistical tests: - (no significance testing done)
| Yes | No “pelvic symptoms” | 18 persistent went to surgery | T- | 0 | 97 | 97 | Blinding: +
| Statistical tests used: | Exclusion criteria: | | Tot | 4 | 98 | 102 | Definition of +/- on screening test: -
| NR - proportions | Women on hormonal therapy | | | | Lower | Upper
| Blinding: | | | | Value | 95% CI | 95% CI
| NR - prospective | | | Se | 100.0% | 25.0% | 100.0%
| Definition of positive and negative on screening test: | | | Sp | 99.0% | 97.0% | 100.0%
| “a persistently enlarged ovary” - 2.5 cm or greater in two separate scans | | | PPV | 80.0% | 44.9% | 100.0%
| RI < 0.41 | | | NPV | 100.0% | 96.9% | 100.0%
| US morphology score > 4
Kurjak, Zalud, and Alfirevic, 1991 | Geographical location: | Age: | Symptomatic (n [%]): | 1) RI < 0.4 | | | | Comments:
#5190 | Zagreb, Croatia | Mean: | Unclear | | Dis+ | Dis- | Tot | —No mention of inclusion criteria for this study
| Dates: NR | Pre 42 | Detected by exam (n [%]): | T+ | 54 | 1 | 55 | —8620 were asymptomatic screening, 5697 were referral from gyn clinic for “suspicion” of mass (not stated how this diagnosis made), however, both grouped into analysis together
| Size of population: | Post 56 | ?5697/14,317: | T- | 2 | 623 | 625 | —Proportion cited pre and post menopausal don't add up to total N, rather to “clinic referral” group
| 14317 total | Range: 18–72 | Detected by imaging (n [%]): | Tot | 56 | 624 | 680 | —No mention of how many RI they were unable to measure
| 8,620 asymptomatic for screening | Menopausal status (n [%]): | NR | | | Lower | Upper | —No mention of followup
| 5697 with “suspected adnexal mass” | Pre (< 45): 7495 | Combination (n [%]): | | Value | 95% CI | 95% CI | —Very problematic study with large numbers ...
| 680 operated on | Post (> 55): 1125 | NR | Se | 96.4% | 91.6% | 100.0% | —RI mean calculated from 5 separate readings (not the lowest measured as in other studies)
| Screening study | This is of the 8620 women referred from clinic | Additional data used for diagnosis: | Sp | 99.8% | 99.5% | 100.0% | —Inter observer variability WAS discussed
| Reference standard: | Race/ethnicity (n [%]): | NR | PPV | 98.2% | 94.7% | 100.0% | —RI < 0.4 used here, same authors use 0.41 elsewhere
| Histopathology in 680 operated on | NR | | NPV | 99.7% | 99.2% | 100.0% | —Unclear how much overlap in study sample between the authors different papers there is
| Reference standard applied to all test negatives?: | Risk factors (n [%]): | | | | | | —16/55 malignancies Stage I
| Only to surgical cases | NR | | | | | | Quality assessment:
| Test reliability established?: | Inclusion criteria: | | | | | | Reference standard: +/-
| Yes | NR | | | | | | Verification bias: -
| Statistical tests used: | Exclusion criteria: | | | | | | Test reliability/variability: +
| Not described - proportions | NR | | | | | | Sample size: -
| Blinding: | | | | | | | Statistical tests: -
| Not mentioned (prospective) | | | | | | | Blinding: +/-
| Definition of positive and negative on screening test: | | | | | | | Definition of +/- on screening test: +
| RI < 0.4
Kurtz, Tsimikas, Tempany, et al., 1999 | Geographical location: | Age: | Symptomatic (n [%]): | 1) Doppler and Conventional US | | | | Comments:
#2940 | Ann Arbor, MI | Mean: 52 | NR | | Dis+ | Dis- | Tot | —Data in 2×2 tables derived from ROC curves, estimated based on total N's for each test; numbers agree with Table 6 in manuscript.
| Baltimore, MD | Median: 51.5 | Detected by exam (n [%]): | T+ | 82 | 6 | 88 | —Referral base for study from oncology clinic - sicker pop
| Boston, MA | Range 19–82 | NR | T- | 27 | 149 | 176 | Quality assessment:
| Philadelphia, PA | Menopausal status (n [%]): | Detected by imaging (n [%]): | Tot | 109 | 155 | 264 | Reference standard: +
| University Hospitals | NR | NR | | | Lower | Upper | Verification bias: +, few women were excluded
| Dates: May 1993 - Apr 1996 | Race/ethnicity (n [%]): | Combination (n [%]): | | Value | 95% CI | 95% CI | Test reliability/variability: -
| Size of population: | NR | NR | Se | 75.2% | 67.1% | 83.3% | Sample size: -
| 280 women | Risk factors (n [%]): | Additional data used for diagnosis: | Sp | 96.1% | 93.1% | 99.2% | Statistical tests: +
| Other | NR | NR | PPV | 93.2% | 87.9% | 98.4% | Blinding: +
| All eligible patients referred by Gyn Onc to University hospital for surgery | Inclusion criteria: | | NPV | 84.7% | 79.3% | 90.0% | Definition of +/- on screening test: +
| Reference standard: | Over 18, suspected of having ovarian cancer based on physical exam or pelvic US | | 2) CT
| Histopathology | Exclusion criteria: | | | Dis+ | Dis- | Tot
| Reference standard applied to all test negatives?: | Unable to provide consent, not a surgical candidate, pregnancy, prior surgery within 6 months of entry into study | | T+ | 58 | 16 | 74
| Yes | | | T- | 5 | 134 | 139
| Test reliability established?: | | | Tot | 63 | 150 | 213
| No | | | | | Lower | Upper
| Statistical tests used: | | | | Value | 95% CI | 95% CI
| Se, Sp, ROC | | | Se | 92.1% | 85.4% | 98.7%
| Blinding: | | | Sp | 89.3% | 84.4% | 94.3%
| Yes to outcome (prospective) radiologists not blinded to diagnosis | | | PPV | 78.4% | 69.0% | 87.8%
| Definition of positive and negative on screening test: | | | NPV | 96.4% | 93.3% | 99.5%
| | | | 3) MRI
| | | | | Dis+ | Dis- | Tot
| | | | T+ | 47 | 16 | 63
| | | | T- | 1 | 115 | 116
| | | | Tot | 48 | 131 | 179
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 97.9% | 93.9% | 100.0%
| | | | Sp | 87.8% | 82.2% | 93.4%
| | | | PPV | 74.6% | 63.9% | 85.4%
| | | | NPV | 99.1% | 97.5% | 100.0%
Leeners, Schild, Funk, et al., 1996 | Geographical location: | Age: | Symptomatic (n [%]): | 1) Sassone score | | | | Comments:
#3940 | Aachen, Germany | Mean: 48.4 | 52 (51.5%) | | Dis+ | Dis- | Tot | —Borderline tumors grouped in with malignant
| Academic | Range: 16–84 | Detected by exam (n [%]): | T+ | 16 | 13 | 29 | —2×2 tables calculated in terms of masses not patients
| Dates: Jan 1993 - Sep 1994 | Menopausal status (n [%]): | NR | T- | 7 | 73 | 80 | —Patients had been referred from gynecologic clinic where had often times already had US
| Size of population: | Pre (< 45): 67 (66.3%) | Detected by imaging (n [%]): | Tot | 23 | 86 | 109 | —No discussion of followup of 6 initial who didn't get surgery
| 101 patients (109 tumors) | Post (> 55): 34(33.7%) | NR | | | Lower | Upper | —RI and PI cutoff calculated from data itself - not using prior cutoffs
| 95 women got surgery | Race/ethnicity (n [%]): | Combination (n [%]): | | Value | 95% CI | 95% CI | —Clinical presentation not described
| Other | NR | NR | Se | 69.8% | 51.0% | 88.5% | Quality assessment:
| Consecutive series in single center | Risk factors (n [%]): | Additional data used for diagnosis: | Sp | 85.0% | 77.5% | 92.5% | Reference standard: +/-
| Reference standard: | Family history: 16 (15.8%) | NR | PPV | 55.2% | 37.1% | 73.3% | Verification bias: +/-
| Histopathology for 95 | Inclusion criteria: | | NPV | 91.3% | 85.1% | 97.4% | Test reliability/variability: -
| Unclear what for the other 6 | Consecutive patients referred to US for “clinical suspicion of an adnexal mass” | | 2) Doppler (RI - lowest from a series of measurements) | | | | Sample size: -
| Reference standard applied to all test negatives?: | Exclusion criteria: | | | Dis+ | Dis- | Tot | Statistical tests: +
| No - see above | NR | | T+ | 16 | 34 | 50 | Blinding: -
| Test reliability established?: | | | T- | 7 | 52 | 59 | Definition of +/- on screening test: -
| Yes | | | Tot | 23 | 86 | 109
| Statistical tests used: | | | | | Lower | Upper
| Fisher exact | | | | Value | 95% CI | 95% CI
| Wilcoxon 2 sample test | | | Se | 70.9% | 52.3% | 89.5%
| Blinding: | | | Sp | 60.9% | 50.6% | 71.2%
| NR but prospective | | | PPV | 32.0% | 19.1% | 44.9%
| Definition of positive and negative on screening test: | | | NPV | 88.1% | 79.9% | 96.4%
| Sassone's score > 9 | | | 3) Combined Doppler and Sassone score
| PI < 0.65 | | | | Dis+ | Dis- | Tot
| RI < 0.45 | | | T+ | 17 | 23 | 40
| | | | T- | 6 | 63 | 69
| | | | Tot | 23 | 86 | 109
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 74.0% | 56.1% | 91.9%
| | | | Sp | 73.7% | 64.4% | 83.0%
| | | | PPV | 42.5% | 27.2% | 57.8%
| | | | NPV | 91.3% | 84.7% | 98.0%
Lerner, Timor-Tritsch, Federman, et al., 1994 | Geographical location: | Age: | Symptomatic (n [%]): | 1) US scoring system of Sassone (cutoff ≥ 3 for T+) | | | | Comments:
#6360 | New York, NY | Mean: 44.5 | NR | | Dis+ | Dis- | Tot | —The article uses data from its institution to fit a linear model from which they modify Sassonne's criteria — their criteria actually performs worse that the original from Sassone (Se 100, Sp 83) which isn't discussed fully
| University Hospital | Range: 12–85 | Detected by exam (n [%]): | T+ | 30 | 72 | 102 | —Denominator in 2×2 tables is masses not individuals
| Dates: May 1990 - Mar 1993 | Menopausal status (n [%]): | NR | T- | 1 | 247 | 248 | —LMP tumors included as benign
| Size of population: | Pre (< 45): 228 (73%) | Detected by imaging (n [%]): | Tot | 31 | 319 | 350 | Quality assessment:
| 312 patients with | Post (> 55): 84 (27%) | NR | | | Lower | Upper | Reference standard: +
| 350 ovarian masses | Race/ethnicity (n [%]): | Combination (n [%]): | | Value | 95% CI | 95% CI | Verification bias: +
| Other | NR | NR | Se | 96.8% | 90.6% | 100.0% | Test reliability/variability: -, cutoff may have been selected a posteriori
| Retrospective analysis of US of women who had gone to surgery for adnexal mass | Risk factors (n [%]): | Additional data used for diagnosis: | Sp | 77.4% | 72.8% | 82.0% | Sample size: -
| Reference standard: | NR | NR | PPV | 29.4% | 20.6% | 38.3% | Statistical tests: -, analysis based on tumors not patients.
| Histopathology | Inclusion criteria: | | NPV | 99.6% | 98.8% | 100.0% | Blinding: +
| Reference standard applied to all test negatives?: | Women who had surgery in time frame for whom images were available | | | | | | Definition of +/- on screening test: +
| Yes | Exclusion criteria:
| Test reliability established?: | Attempts made to not perform US in luteal phase
| Yes for Sasonne, no for modified criteria used here
| Statistical tests used:
| Se, Sp
| Blinding:
| Yes
| Definition of positive and negative on screening test:
| Modified Sasonne where + was ≥ 3 and +1 for shadowing present, +1 for ≥ 3 mm walls, +2 for solid wall structure, +3 for papillarities ≥ 3 mm, +3 for mixed or high echogenicity
Lin, Angel, DuBeshter, et al., 1993 | Geographical location: | Age: | Symptomatic (n [%]): | 1) US | | | | Comments:
#4890 | Rochester, NY, USA | Median: 56 | Pain - 37(46.3%) | | Dis+ | Dis- | Tot | —Patients referred from gynecological onconlogy clinic
| Dates: Jul 1989 - Jun 1990 | Range: 19–88 | Asymptomatic - 70(87.5%) | T+ | 15 | 11 | 26 | —No scoring system for US or CT used
| Size of population: | Menopausal status (n [%]): | Detected by exam (n [%]): | T- | 3 | 11 | 14 | —Retrospective with subjective means of judging “suspicious for malignancy” and no mention of blinding or how this assessment of prior radiology studies was made
| 80 women | Pre (< 45): 18 (22.5%) | NR | Tot | 18 | 22 | 40 | —Borderline tumors grouped in with malignant
| Other | Post (> 55): 62 (77.5) | Detected by imaging (n [%]): | | | Lower | Upper | —Not all tests available for all patients - hence difference in N for each 2×2 table
| Case series | Race/ethnicity (n [%]): | NR | | Value | 95% CI | 95% CI | —The PPV and NPV of CT 2×2 table differ significantly in my calculation than that reported in the article (PPV-75%, NPV-71%)
| Retrospective | Caucasian 72 (90%) | Combination (n [%]): | Se | 83.3% | 66.1% | 100.0% | Quality assessment:
| Reference standard: | Black 8 (10%) | NR | Sp | 50.0% | 29.1% | 70.9% | Reference standard: +
| Histopathology | Risk factors (n [%]): | Additional data used for diagnosis: | PPV | 57.7% | 38.7% | 76.7% | Verification bias: +
| Reference standard applied to all test negatives?: | Family history: 11 (13.8%) | NR | NPV | 78.6% | 57.1% | 100.0% | Test reliability/variability: -
| Yes | Inclusion criteria: | | 2) CT | | | | Sample size: -
| Test reliability established?: | “Mass in the pelvic area” who underwent surgery in time frame | | | Dis+ | Dis- | Tot | Statistical tests: +
| No for US and CT (no scoring system used) | Exclusion criteria: | | T+ | 25 | 9 | 34 | Blinding: -
| Statistical tests used: | NR | | T- | 4 | 5 | 9 | Definition of +/- on screening test: -
| P value calculated by NR | | | Tot | 29 | 14 | 43
| Blinding: | | | | | Lower | Upper
| No; retrospective | | | | Value | 95% CI | 95% CI
| Definition of positive and negative on screening test: | | | Se | 86.2% | 73.7% | 98.8%
| US and CT - “presence of a complex or heterogenous mass, ascites, omental tumor or other evidence of metastatic tumor in the pelvic area or abdomen” | | | Sp | 35.7% | 10.6% | 60.8%
| | | | PPV | 73.5% | 58.7% | 88.4%
| | | | NPV | 55.6% | 23.1% | 88.0%
Lin, Wu, Lee, et al., 1993 | Geographical location: | Age: | Symptomatic (n [%]): | 1) RI ≤ 0.4 | | | | Comments:
#6990 | Taiwan | Mean: 40.5 | NR | | Dis+ | Dis- | Tot | —Borderline tumors grouped in malignant category
| University Hospital | Range: 11–81 | Detected by exam (n [%]): | T+ | 62 | 8 | 70 | —“Satisfactory arterial waveforms” only in 111(40.7%) of benign masses (and in 87(96.7%) of malignant) - however, all were included in the 2×2 table (assume 60% non-satisfactory wave forms used in benign lesions?)
| Dates: Jul 1990 - Oct 1993 | Menopausal status (n [%]): | NR | T- | 28 | 272 | 300 | —Report treats no satisfactory wave form as “test negative.”
| Size of population: | NR | Detected by imaging (n [%]): | Tot | 90 | 280 | 370 | Quality assessment:
| 370 women | Race/ethnicity (n [%]): | 370 (100%) | | | Lower | Upper | Reference standard: +
| Other | NR | Combination (n [%]): | | Value | 95% CI | 95% CI | Verification bias: +
| Hospital referrals for adnexal masses | Risk factors (n [%]): | NR | Se | 68.9% | 59.3% | 78.5% | Test reliability/variability: - (not discussed or calculated for operators in study)
| Reference standard: | NR | Additional data used for diagnosis: | Sp | 97.1% | 95.1% | 99.1% | Sample size: -
| Histopathology | Inclusion criteria: | NR | PPV | 88.6% | 81.1% | 96.0% | Statistical tests: +
| Reference standard applied to all test negatives?: | Suspected ovarian mass on US referred to hospital for surgery | | NPV | 90.7% | 87.4% | 94.0% | Blinding: +/-
| Yes | Exclusion criteria: | | 2) RI ≤ 0.5 | | | | Definition of +/- on screening test: +
| Test reliability established?: | Study US in luteal phase | | | Dis+ | Dis- | Tot
| RI - yes (usually with 0.4 cutoff) | | | T+ | 71 | 22 | 93
| Statistical tests used: | | | T- | 19 | 258 | 277
| Se, Sp | | | Tot | 90 | 280 | 370
| Blinding: | | | | | Lower | Upper
| NR but study prospective | | | | Value | 95% CI | 95% CI
| Definition of positive and negative on screening test: | | | Se | 78.9% | 70.5% | 87.3%
| RI ≤ 0.4 or 0.5 or 0.6 | | | Sp | 92.1% | 88.9% | 95.3%
| | | | PPV | 76.3% | 67.7% | 85.0%
| | | | NPV | 93.1% | 90.2% | 96.1%
| | | | 3) RI ≤ 0.6
| | | | | Dis+ | Dis- | Tot
| | | | T+ | 82 | 38 | 120
| | | | T- | 8 | 242 | 250
| | | | Tot | 90 | 280 | 370
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 91.1% | 85.2% | 97.0%
| | | | Sp | 86.4% | 82.4% | 90.4%
| | | | PPV | 68.3% | 60.0% | 76.7%
| | | | NPV | 96.8% | 94.6% | 99.0%
Luxman, Bergman, Sagi, et al., 1991 | Geographical location: | Age: | Symptomatic (n [%]): | 1) US—Size > 5 cm and/or complex/solid = malignant | | | | Comments:
#6530 | Tel Aviv, Israel | Mean: 62 | NR | | Dis+ | Dis- | Tot | —All postmenopausal but age range 42–90
| Dates: NR | Range: 42–90 | Detected by exam (n [%]): | T+ | 27 | 42 | 69 | —Very unclear how tests were graded + or - (more than “simple” vs. “complex”?)
| Size of population: | Menopausal status (n [%]): | NR | T- | 2 | 31 | 33 | Quality assessment:
| 102 | Post (> 55): 102 (100%) | Detected by imaging (n [%]): | Tot | 29 | 73 | 102 | Reference standard: +
| Other | Race/ethnicity (n [%]): | NR | | | Lower | Upper | Verification bias: +
| Case series | NR | Combination (n [%]): | | Value | 95% CI | 95% CI | Test reliability/variability:-
| Reference standard: | Risk factors (n [%]): | NR | Se | 93.0% | 83.7% | 100.0% | Sample size: -
| Histopathology | NR | Additional data used for diagnosis: | Sp | 42.0% | 30.7% | 53.3% | Statistical tests: +/-
| Reference standard applied to all test negatives?: | Inclusion criteria: | NR | PPV | 39.1% | 27.6% | 50.6% | Blinding: +
| Yes | NR - presumable, presence of mass scheduled for surgery during time frame | | NPV | 93.9% | 85.8% | 100.0% | Definition of +/- on screening test: -
| Test reliability established?: | Exclusion criteria: | | 2) US—size > 5 cm alone = malignant
| No | NR | | | Dis+ | Dis- | Tot
| Statistical tests used: | | | T+ | 24 | 12 | 36
| Se, Sp | | | T- | 5 | 61 | 66
| Blinding: | | | Tot | 29 | 73 | 102
| No | | | | | Lower | Upper
| Definition of positive and negative on screening test: | | | | Value | 95% CI | 95% CI
| US - unclear | | | Se | 82.8% | 69.0% | 96.5%
| “simple” if lesion unilocular and lacking septa | | | Sp | 83.6% | 75.1% | 92.1%
| “complex” if solid area, papillae, septa, enhanced echogenicity | | | PPV | 66.7% | 51.3% | 82.1%
| | | | NPV | 92.4% | 86.0% | 98.8%
| | | | 3) US—complex or solid = malignant
| | | | | Dis+ | Dis- | Tot
| | | | T+ | 27 | 33 | 60
| | | | T- | 2 | 40 | 42
| | | | Tot | 29 | 73 | 102
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 93.1% | 83.9% | 100.0%
| | | | Sp | 54.8% | 43.4% | 66.2%
| | | | PPV | 45.0% | 32.4% | 57.6%
| | | | NPV | 95.2% | 88.8% | 100.0%
Ma, Shen, and Lang, 2003 | Geographical location: | Age: | Symptomatic (n [%]): | 1) CA-125 ≥ 30 U/ml | | | | Comments:
#1900 | Peking, China | Range: 30 - NR | NR | | Dis+ | Dis- | Tot | —Menopause defined
| University | Menopausal status (n [%]): | Detected by exam (n [%]): | T+ | 56 | 27 | 83 | —Unclear where US scoring system comes from and how calculated.
| Dates: Jan 1998 - June 1999 | Pre: 89 (64%) | NR | T- | 7 | 50 | 57 | —Unclear if US score done at time of imaging study or when looking back.
| Size of population: | Post: 51 (36%) | Detected by imaging (n [%]): | Tot | 63 | 77 | 140 | —CA-125 cutoff (30, 50) not what used in States now
| 140 women | > 1 year of amenorrhea or if s/p hysterectomy, age > 50 years | NR | | | Lower | Upper | Quality assessment:
| Other | Race/ethnicity (n [%]): | Combination (n [%]): | | Value | 95% CI | 95% CI | Reference standard: +
| Retrospective analysis of surgical patients with CA-125 and US in single academic center | NR | NR | Se | 88.9% | 81.1% | 96.7% | Verification bias: +
| Reference standard: | Risk factors (n [%]): | Additional data used for diagnosis: | Sp | 64.9% | 54.2% | 75.6% | Test reliability/variability:
| Histopathology | NR | NR | PPV | 67.5% | 57.4% | 77.5% | + for CA-125
| Reference standard applied to all test negatives?: | Inclusion criteria: | | NPV | 87.7% | 79.2% | 96.2% | - for US
| Yes | “Ovarian neoplasm” patients over 30 years admitted to a single institution | | 2) CA-125 ≥ 50 | | | | Sample size: -
| Test reliability established?: | Exclusion criteria: | | | Dis+ | Dis- | Tot | Statistical tests: +
| CA-125 - yes | NR | | T+ | 53 | 21 | 74 | Blinding: -
| US - unclear what scoring system used - reliability probably not established | | | T- | 10 | 56 | 66 | Definition of +/- on screening test: +
| Statistical tests used: | | | Tot | 63 | 77 | 140
| Se, Sp, PPV | | | | | Lower | Upper
| Blinding: | | | | Value | 95% CI | 95% CI
| NR (retrospective analysis of already collected data) | | | Se | 84.1% | 75.1% | 93.1%
| Definition of positive and negative on screening test: | | | Sp | 72.7% | 62.7% | 82.7%
| CA-125 > (various cutoffs analyzed 30, 50, 100) | | | PPV | 71.6% | 61.3% | 81.9%
| US score 0 or 1 point given for: multi-focal lesion, nature of focal lesion, unilateral or bilateral lesion, ascites, metastasis Max = 5 | | | NPV | 84.8% | 76.2% | 93.5%
| | | | 3) US score ≥ 2
| | | | | Dis+ | Dis- | Tot
| | | | T+ | 59 | 13 | 72
| | | | T- | 4 | 64 | 68
| | | | Tot | 63 | 77 | 140
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 93.7% | 87.7% | 99.7%
| | | | Sp | 83.1% | 74.7% | 91.5%
| | | | PPV | 81.9% | 73.1% | 90.8%
| | | | NPV | 94.1% | 88.5% | 99.7%
Maggino, Gadducci, D'Addario, et al., 1994 | Geographical location: | Age: | Symptomatic (n [%]): | 1) CA-125, threshold >35, EXCLUDING 45 patients not operated on because of US and CA-125 | | | | Comments:
#4500 | Padua, Pisa, Bari, Brescia, and Milan, Italy | Range: 40–91 | 209 (72.1%) | | Dis+ | Dis- | Tot | —Reference standard not applied to all test negatives
| Dates: Mar 1991-Mar 1992 | Overall mean not reported | Detected by exam (n [%]): | T+ | 83 | 24 | 107 | -2×2 tables are limited to patients with adnexal masses (excluding other non-ovarian pelvic masses)
| Size of population: | Menopausal status (n [%]): | NR | T- | 23 | 110 | 133 | Quality assessment:
| 383; 48 excluded based on criteria, 45 not reported because ultrasound and CA-125 did not lead to surgery | 100% post menopausal | Detected by imaging (n [%]): | Tot | 106 | 134 | 240 | Reference standard: +
| Other | Race/ethnicity (n [%]): | NR | | | Lower | Upper | Verification bias: -
| Multicenter series | NR | Combination (n [%]): | | Value | 95% CI | 95% CI | Test reliability/variability: -
| Reference standard: | Risk factors (n [%]): | NR | Se | 78.3% | 70.5% | 86.1% | Sample size: -
| Surgery | NR | Additional data used for diagnosis: | Sp | 82.1% | 75.6% | 88.6% | Statistical tests: +
| Reference standard applied to all test negatives?: | Inclusion criteria: | NR | PPV | 77.6% | 69.7% | 85.5% | Blinding: -
| No | Clinical diagnosis of pelvic mass | | NPV | 82.7% | 76.3% | 89.1% | Definition of +/- on screening test: +
| Test reliability established?: | Postmenopausal at least 1 year | | 2) CA-125, threshold > 65, EXCLUDING 45 patients not operated on because of US and CA-125
| Not referenced or discussed (ultrasound) | Exclusion criteria: | | | Dis+ | Dis- | Tot
| Statistical tests used: | Premenopausal, Previous malignancy, except breast ca | | T+ | 76 | 10 | 86
| Se, Sp | Previous bilateral adnexectomy | | T- | 30 | 124 | 154
| Blinding: | Previous hysterectomy if < 55 years | | Tot | 106 | 134 | 240
| No | | | | | Lower | Upper
| Definition of positive and negative on screening test: | | | | Value | 95% CI | 95% CI
| Probably benign: | | | Se | 71.7% | 63.1% | 80.3%
| - < 5 cm; - thin, clear wall; - hypoechogenic; - no septae, or no more than 3 thin septae; - No fluid in cul de sac | | | Sp | 92.5% | 88.1% | 97.0%
| Equivocal: | | | PPV | 88.4% | 81.6% | 95.1%
| - Between 5 and 10 cm; - Thick, clear, smooth wall; - Hypoechogenic liquid or solid homogeneous content; - > 3 thin septae; - Thick, regular septae; - No vegetations; - No free peritoneal fluid | | | NPV | 80.5% | 74.3% | 86.8%
| Malignant: none of the above | | | 3) Ultrasound, equivocal or higher as positive, EXCLUDING patients not operated on because of findings
| | | | | Dis+ | Dis- | Tot
| | | | T+ | 105 | 72 | 177
| | | | T- | 1 | 62 | 63
| | | | Tot | 106 | 134 | 240
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 99.1% | 97.2% | 100.0%
| | | | Sp | 46.3% | 37.8% | 54.7%
| | | | PPV | 59.3% | 52.1% | 66.6%
| | | | NPV | 98.4% | 95.3% | 100.0%
| | | | 4) Ultrasound, malignant as positive, EXCLUDING patients not operated on because of findings
| | | | | Dis+ | Dis- | Tot
| | | | T+ | 90 | 30 | 120
| | | | T- | 16 | 104 | 120
| | | | Tot | 106 | 134 | 240
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 84.9% | 78.1% | 91.7%
| | | | Sp | 77.6% | 70.6% | 84.7%
| | | | PPV | 75.0% | 67.3% | 82.7%
| | | | NPV | 86.7% | 80.6% | 92.7%
Malkasian Jr., Knapp, Lavin, et al., 1988 | Geographical location: | Age: | Symptomatic (n [%]): | 1) All patients, CA-125 > 35 as positive | | | | Comments:
#6810 | Rochester, MN; Boston, MA; Hershey, PA; Los Angeles, CA | Benign | Clinical presentation not described | | Dis+ | Dis- | Tot | —Unclear how subjects selected
| Dates: NR | Mean: 43.5 | Detected by exam (n [%]): | T+ | 53 | 18 | 71 | —Spectrum of disease described
| Size of population: | Range: 15–88 | NR | T- | 15 | 72 | 87 | —Tests all drawn within 1 week of surgery; unclear if results would have been different if drawn prior to decision for surgery
| 172; 14 excluded for total of 158 | Malignant | Detected by imaging (n [%]): | Tot | 68 | 90 | 158 | — Borderline tumors included with malignant
| Other | Mean: 63.5 | NR | | | Lower | Upper | Quality assessment:
| Multicenter, case series | Range: 16–96 | Combination (n [%]): | | Value | 95% CI | 95% CI | Reference standard: +
| Reference standard: | Menopausal status (n [%]): | NR | Se | 77.9% | 68.1% | 87.8% | Verification bias: +
| Surgery/pathology | Benign | Additional data used for diagnosis: | Sp | 80.0% | 71.7% | 88.3% | Test reliability/variability:+
| Reference standard applied to all test negatives?: | Pre (< 45): 56 (62.2%) | Stage | PPV | 74.6% | 64.5% | 84.8% | Sample size: + (confidence intervals given)
| Yes | Post (> 55): 34 (37.8%) | I 23.3% | NPV | 82.8% | 74.8% | 90.7% | Statistical tests: +
| Test reliability established?: | Malignant: | II 10.0% | 2) All patients, CA-125 > 100 as threshold | | | | Blinding: +
| Yes | Pre 10 (14.7%) | III 61.5% | | Dis+ | Dis- | Tot | Definition of +/- on screening test: +
| Statistical tests used: | Post: 58 (85.3%) | IV 5.0% | T+ | 50 | 4 | 54
| Se/Sp | Race/ethnicity (n [%]): | | T- | 18 | 86 | 104
| Blinding: | NR | | Tot | 68 | 90 | 158
| Yes | Risk factors (n [%]): | | | | Lower | Upper
| Definition of positive and negative on screening test: | NR | | | Value | 95% CI | 95% CI
| CA-15 at various thresholds | Inclusion criteria: | | Se | 73.5% | 63.0% | 84.0%
| | Palpable mass | | Sp | 95.6% | 91.3% | 99.8%
| | Scheduled for surgery | | PPV | 92.6% | 85.6% | 99.6%
| | Blood drawn within 1 week of surgery | | NPV | 82.7% | 75.4% | 90.0%
| | Exclusion criteria: | | 3) Premenopausal patients, CA-125 > 35 as threshold
| | Preop definitive diagnosis of ovarian cancer (n = 11) | | | Dis+ | Dis- | Tot
| | Blood > 1 week (n = 3) | | T+ | 6 | 15 | 21
| | | | T- | 4 | 41 | 45
| | | | Tot | 10 | 56 | 66
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 60.0% | 29.6% | 90.4%
| | | | Sp | 73.2% | 61.6% | 84.8%
| | | | PPV | 28.6% | 9.2% | 47.9%
| | | | NPV | 91.1% | 82.8% | 99.4%
| | | | 4) Premenopausal patients, CA-125 > 100 as threshold
| | | | | Dis+ | Dis- | Tot
| | | | T+ | 6 | 3 | 9
| | | | T- | 4 | 53 | 57
| | | | Tot | 10 | 56 | 66
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 60.0% | 29.6% | 90.4%
| | | | Sp | 94.6% | 88.7% | 100.0%
| | | | PPV | 66.7% | 35.9% | 97.5%
| | | | NPV | 93.0% | 86.4% | 99.6%
| | | | 5) Postmenopausal patients, CA-125 > 35 as threshold
| | | | | Dis+ | Dis- | Tot
| | | | T+ | 47 | 3 | 50
| | | | T- | 11 | 31 | 42
| | | | Tot | 58 | 34 | 92
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 81.0% | 70.9% | 91.1%
| | | | Sp | 91.2% | 81.6% | 100.0%
| | | | PPV | 94.0% | 87.4% | 100.0%
| | | | NPV | 73.8% | 60.5% | 87.1%
| | | | 6) Postmenopausal patients, CA-125 > 100 as threshold
| | | | | Dis+ | Dis- | Tot
| | | | T+ | 44 | 1 | 45
| | | | T- | 13 | 33 | 46
| | | | Tot | 57 | 34 | 91
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 77.2% | 66.3% | 88.1%
| | | | Sp | 97.1% | 91.4% | 100.0%
| | | | PPV | 97.8% | 93.5% | 100.0%
| | | | NPV | 71.7% | 58.7% | 84.8%
Maly, Riss, and Deutinger, 1995 | Geographical location: | Age: | Symptomatic (n [%]): | 1) Diastolic notch absent | | | | Comments:
#6800 | Vienna, Austria | Range: 28–75 | Clinical presentation not described | | Dis+ | Dis- | Tot | —Unclear how patient pop chosen, if consecutive, if any excluded
| Dates: NR | Menopausal status (n [%]): | Detected by exam (n [%]): | T+ | 37 | 5 | 42 | Quality assessment:
| Size of population: | Pre (< 45): 55 (53.9%) | NR | T- | 0 | 39 | 39 | Reference standard: +
| 102 women | Post (> 55): 47 (46.1%) | Detected by imaging (n [%]): | Tot | 37 | 44 | 81 | Verification bias: -
| Other | Race/ethnicity (n [%]): | NR | | | Lower | Upper | Test reliability/variability: -
| Case series | NR | Combination (n [%]): | | Value | 95% CI | 95% CI | Sample size: -
| Reference standard: | Risk factors (n [%]): | NR | Se | 100.0% | 91.9% | 100.0% | Statistical tests: +
| Pathology | NR | Additional data used for diagnosis: | Sp | 88.6% | 79.3% | 98.0% | Blinding: -
| Reference standard applied to all test negatives?: | Inclusion criteria: | Premenopausal US in secretory phase | PPV | 88.1% | 78.3% | 97.9% | Definition of +/- on screening test: - (not clearly defined)
| Yes | NR | | NPV | 100.0% | 92.3% | 100.0%
| Test reliability established?: | Exclusion criteria: | | 2) Demonstrable blood vessels
| Not referenced or discussed | NR | | | Dis+ | Dis- | Tot
| Statistical tests used: | | | T+ | 37 | 44 | 81
| Chi-square, t-test | | | T- | 2 | 19 | 21
| Blinding: | | | Tot | 39 | 63 | 102
| NR | | | | | Lower | Upper
| Definition of positive and negative on screening test: | | | | Value | 95% CI | 95% CI
| Diastolic notch: “short drop of flow curve at beginning of diastole” | | | Se | 94.9% | 87.9% | 100.0%
| | | | Sp | 30.2% | 18.8% | 41.5%
| | | | PPV | 45.7% | 34.8% | 56.5%
| | | | NPV | 90.5% | 77.9% | 100.0%
Mancuso, De Vivo, Triolo, et al., 2004 | Geographical location: | Age: | Symptomatic (n [%]): | 1) US | | | | Comments:
#1610 | Italy | Mean (SD): 42.2 | 68 (54.4%) symptomatic | | Dis+ | Dis- | Tot | —Menopause versus fertile not defined
| University Hospital | Range: 18 - 82 | 5 (4%) had urinary or intestinal symptoms | T+ | 14 | 24 | 38 | —Even though data on menopausal status collected, analysis used age > or < 50 as
| Dates: NR | Menopausal status (n [%]): | only 30 (24%) described as asymptomatic | T- | 0 | 87 | 87 | —US scoring system not described (?Sasonne or modified) - positive or negative US not defined
| Size of population: | Pre 76 (61%) | Detected by exam (n [%]): | Tot | 14 | 111 | 125 | Quality assessment:
| 125 women | Post 49 (39%) | NR | | | Lower | Upper | Reference standard: +
| Other | Race/ethnicity (n [%]): | Detected by imaging (n [%]): | | Value | 95% CI | 95% CI | Verification bias: +
| Patients referred to hospital with mass who had surgery | NR | NR | Se | 100.0% | 78.6% | 100.0% | Test reliability/variability: -
| Reference standard: | Risk factors (n [%]): | Combination (n [%]): | Sp | 78.6% | 71.0% | 86.2% | Sample size: -
| Histopathology | NR | NR | PPV | 36.8% | 21.5% | 52.2% | Statistical tests: +
| Reference standard applied to all test negatives?: | Inclusion criteria: | Additional data used for diagnosis: | NPV | 100.0% | 96.6% | 100.0% | Blinding: -
| Yes | Patients referred to hospital with mass who had surgery | 22 (17.6%) reported a menstrual disorder as main symptom | 2) CA-125 ≥ 35 U/ml | | | | Definition of +/- on screening test:
| Test reliability established?: | Exclusion criteria: | | | Dis+ | Dis- | Tot | + for CA-125
| CA-125 - yes | NR | | T+ | 14 | 24 | 38 | - for US
| US - unclear what was used | | | T- | 0 | 87 | 87
| Statistical tests used: | | | Tot | 14 | 111 | 125
| Se, Sp, LR | | | | | Lower | Upper
| Blinding: | | | | Value | 95% CI | 95% CI
| NR (US and serum prior to surgery) | | | Se | 100.0% | 78.6% | 100.0%
| Definition of positive and negative on screening test: | | | Sp | 78.6% | 71.0% | 86.2%
| CA-125 ≥ 35 U/ml | | | PPV | 36.8% | 21.5% | 52.2%
| US - NR what was + or negative or what scoring system used | | | NPV | 100.0% | 96.6% | 100.0%
Manjunath, Pratap-kumar, Sujatha, et al., 2001 | Geographical location: | Age: | Symptomatic (n [%]): | 1) CA-125 ≥ 35 U/ml | | | | Comments:
#2510 | Manipal, India | NR | NR | | Dis+ | Dis- | Tot | —LMP tumors grouped into malignant
| Dates: Jan 1997 - Aug 1999 | Menopausal status (n [%]): | Detected by exam (n [%]): | T+ | 77 | 10 | 87 | —Although menopausal status was reported, results were not stratified by menopausal status (or age)
| Size of population: | Pre (< 45): 84(55.2%) | NR | T- | 16 | 45 | 61 | —Unclear US scoring system
| 152 women | Post (> 55): 64(42.1%) | Detected by imaging (n [%]): | Tot | 93 | 55 | 148 | Quality assessment:
| Other | Race/ethnicity (n [%]): | NR | | | Lower | Upper | Reference standard: +
| Retrospective analysis of women admitted to academic hospital with pelvic mass who had surgery | NR | Combination (n [%]): | | Value | 95% CI | 95% CI | Verification bias: +
| Reference standard: | Risk factors (n [%]): | NR | Se | 83.0% | 75.4% | 90.6% | Test reliability/variability: + for CA-125
| Histopathology | NR | Additional data used for diagnosis: | Sp | 82.0% | 71.8% | 92.2% | ?/- for US
| Reference standard applied to all test negatives?: | Inclusion criteria: | NR | PPV | 88.5% | 81.8% | 95.2% | Sample size: -
| Yes | Patients who had surgery for pelvic masses | | NPV | 73.8% | 62.7% | 84.8% | Statistical tests: +
| Test reliability established?: | Exclusion criteria: | | 2) US score ≥ 2 | | | | Blinding: -
| CA-125 - yes | NR | | | Dis+ | Dis- | Tot | Definition of +/- on screening test: +/-
| US - ? | | | T+ | 40 | 6 | 46
| Statistical tests used: | | | T- | 53 | 49 | 102
| Se, Sp, ROC curves | | | Tot | 93 | 55 | 148
| Blinding: | | | | | Lower | Upper
| NR | | | | Value | 95% CI | 95% CI
| Definition of positive and negative on screening test: | | | Se | 43.0% | 32.9% | 53.1%
| CA-125 (multiple cutoffs) | | | Sp | 89.0% | 80.7% | 97.3%
| US score 1 point given for presence of multi-locular systic lesion, solid area, bilateral, ascites, intraabdominal mets. | | | PPV | 87.0% | 77.2% | 96.7%
| | | | NPV | 48.0% | 38.3% | 57.7%
Marchetti, Zambon, Lamaina, et al., 2002 | Geographical location: | Age: | Symptomatic (n [%]): | 1) All patients with positive ultrasound, borderline classified as malignant, assuming negative ultrasound truly negative | | | | Comments:
#2230 | Padua, Italy | Mean: 49 | 518 (11.9%) | | Dis+ | Dis- | Tot | —Variable reference standard
| Dates: Sep 1996-Oct 2001 | Menopausal status (n [%]): | Detected by exam (n [%]): | T+ | 2 | 174 | 176 | —Length of followup, loss to followup not clearly described
| Size of population: 176 positives/4,350 exams | NR | NR | T- | 0 | 4174 | 4174 | —Results not stratified by age, menopausal status
| Screening study | Race/ethnicity (n [%]): | Detected by imaging (n [%]): | Tot | 2 | 4348 | 4350 | Quality assessment:
| Reference standard: | NR | NR | | | Lower | Upper | Reference standard:-
| Surgery, followup | Risk factors (n [%]): | Combination (n [%]): | | Value | 95% CI | 95% CI | Verification bias: -
| Reference standard applied to all test negatives?: | NR | NR | Se | 100.0% | 0.0% | 100.0% | Test reliability/variability: -
| No | Inclusion criteria: | Additional data used for diagnosis: | Sp | 96.0% | 95.4% | 96.6% | Sample size: +
| Test reliability established?: | Borderline classified as malignant | Screening frequency not described | PPV | 1.1% | 0.0% | 2.7% | Statistical tests:-
| Not referenced or discussed | Exclusion criteria: | | NPV | 100.0% | 99.9% | 100.0% | Blinding: +
| Statistical tests used: | NR | | 2) Patients undergoing surgery only (not clear from paper, but 29 had “ultrasound findings indicative of malignant lesions”, and 45 total underwent surgery | | | | Definition of +/- on screening test: -
| Chi-square, Se/Sp | | | | Dis+ | Dis- | Tot
| Blinding: | | | T+ | 2 | 27 | 29
| Yes | | | T- | 0 | 16 | 16
| Definition of positive and negative on screening test: | | | Tot | 2 | 43 | 45
| Criteria for referral or positive test not described | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 100.0% | 0.0% | 100.0%
| | | | Sp | 37.2% | 22.8% | 51.7%
| | | | PPV | 6.9% | 0.0% | 16.1%
| | | | NPV | 100.0% | 81.3% | 100.0%
Marret, Sauget, Giraudeau, et al., 2004 | Geographical location: | Age: | Symptomatic (n [%]): | 1) RI < 0.53 | | | | Comments:
#7680 | France | Mean: 46.2 | NR | | Dis+ | Dis- | Tot | —Analysis done for masses not women
| Dates: Feb 2002 - Mar 2003 | Range: 19–72 | Detected by exam (n [%]): | T+ | 18 | 13 | 31 | —Study looks specifically at the use of IV contrast at the time of US (as this is a novel method, data from that outcome is not included in this evidence table)
| Size of population: | Menopausal status (n [%]): | NR | T- | 5 | 65 | 70 | —Unable to stratify by menopausal status
| 99 women | Pre (< 45): 58 (58.6%) | Detected by imaging (n [%]): | Tot | 23 | 78 | 101 | —Interobserver correlation coefficient 0.92
| 101 masses | Post (> 55): 41 (41.4%) | NR | | | Lower | Upper | —US modality (TVUS vs. abdominal) not specified - assume TV?
| Prospective series (“pilot” per authors) | Race/ethnicity (n [%]): | Combination (n [%]): | | Value | 95% CI | 95% CI | Quality assessment:
| Reference standard: | NR | NR | Se | 78.0% | 61.1% | 94.9% | Reference standard: +
| Histopathology | Risk factors (n [%]): | Additional data used for diagnosis: | Sp | 83.0% | 74.7% | 91.3% | Verification bias: +
| Reference standard applied to all test negatives?: | NR | NR | PPV | 58.1% | 40.7% | 75.4% | Test reliability/variability:+
| Yes | Inclusion criteria: | | NPV | 92.9% | 86.8% | 98.9% | Sample size: -
| Test reliability established?: | Woman with diagnosis of adnexal mass admitted to hospital in time frame | | 2) CA-125 ≥ 25 | | | | Statistical tests: +
| Yes | Exclusion criteria: | | | Dis+ | Dis- | Tot | Blinding: +
| Statistical tests used: | NR | | T+ | 19 | 12 | 31 | Definition of +/- on screening test: +
| Kappa statistics | | | T- | 4 | 66 | 70
| AUC | | | Tot | 23 | 78 | 101
| Se, Sp | | | | | Lower | Upper
| Chi square - Fisher exact | | | | Value | 95% CI | 95% CI
| Blinding: | | | Se | 83.0% | 67.6% | 98.4%
| NR | | | Sp | 85.0% | 77.1% | 92.9%
| Definition of positive and negative on screening test: | | | PPV | 61.3% | 44.1% | 78.4%
| RI < 0.53 | | | NPV | 94.3% | 88.8% | 99.7%
| CA-125 > 25 U/ml
Matthes, Moreira de Andrade, and Bighetti, 1996 | Geographical location: | Age: | Symptomatic (n [%]): | 1) US (Kurjak morphology) | | | | Comments:
#11020 | Brazil | Mean: 45.75 | NR | | Dis+ | Dis- | Tot | —8 patients dropped from analysis - not mentioned why
| Dates: Feb 1992 - Feb 1994 | Median: 46 | Detected by exam (n [%]): | T+ | 8 | 7 | 15 | —Kurjak criteria for morphologic classification (without Doppler), and cutpoint not described for this study
| Size of population: | Range: 15–83 | NR | T- | 2 | 26 | 28 | —LMP included with malignant
| 51, however results only available for 43 | Menopausal status (n [%]): | Detected by imaging (n [%]): | Tot | 10 | 33 | 43 | —Unclear if TVUS or abdominal US or combination used
| Reference standard: | NR | NR | | | Lower | Upper | Quality assessment:
| Reference standard applied to all test negatives?: | Race/ethnicity (n [%]): | Combination (n [%]): | | Value | 95% CI | 95% CI | Reference standard: +
| Test reliability established?: | NR | NR | Se | 80.0% | 55.2% | 100.0% | Verification bias: +
| Statistical tests used: | Risk factors (n [%]): | Additional data used for diagnosis: | Sp | 78.8% | 64.8% | 92.7% | Test reliability/variability: -
| Blinding: | NR | NR | PPV | 53.3% | 28.1% | 78.6% | Sample size: -
| Definition of positive and negative on screening test: | Inclusion criteria: | | NPV | 92.9% | 83.3% | 100.0% | Statistical tests: +
| | Unclear | | | | | | Blinding: -
| | Exclusion criteria: | | | | | | Definition of +/- on screening test: +/-
| | NR
McIntosh, Drescher, Karlan, et al., 2004 | Geographical location: | Age: | Symptomatic (n [%]): | 1) CA-125 (cutoff not specified; sensitivity calculated corresponding to 98% specificity on ROC curve based on LR model) | | | | Quality assessment:
#6700 | Seattle, WA | NR | NR | | Dis+ | Dis- | Tot | Reference standard: +
| Dates: NR | Menopausal status (n [%]): | Detected by exam (n [%]): | T+ | 19 | 1 | 20 | Verification bias: +
| Size of population: | Pre: 90 (29%) | NR | T- | 33 | 42 | 75 | Test reliability/variability: +
| 95/315 total including healthy controls (no mass) | Post: 225 (71%) | Detected by imaging (n [%]): | Tot | 52 | 43 | 95 | Sample size: +
| 52 ovarian cancer | Race/ethnicity (n [%]): | NR | | | Lower | Upper | Statistical tests: +
| 43 benign ovarian tumors | White: 268 (85%) | Combination (n [%]): | | Value | 95% CI | 95% CI | Blinding: -
| = 95 used for calculations here | Hispanic: 4 (1%%) | NR | Se | 37.2% | 24.1% | 50.3% | Definition of +/- on screening test: -
| Other | Black: 1 (< 1%) | Additional data used for diagnosis: | Sp | 98.0% | 93.8% | 100.0%
| Case-control | Asian: 8 (3%) | NR | PPV | 95.0% | 85.4% | 100.0%
| Reference standard: | Native American: 3 (< 1%) | | NPV | 56.0% | 44.8% | 67.2%
| Histopathology | Risk factors (n [%]): | | Also reported for soluble mesothelin related (SMR) marker; not reported here.
| Reference standard applied to all test negatives?: | NR
| Yes | Inclusion criteria:
| Test reliability established?: | Cases and controls - randomly selected from repository
| Yes | Exclusion criteria:
| Statistical tests used: | NR
| ROC, LR models
| Blinding:
| NR
| Definition of positive and negative on screening test:
| SA 125 - cutoffs not selected a priori
Medl, Kulen-kampff, Stiskal, et al., 1995 | Geographical location: | Age: | Symptomatic (n [%]): | 1) Ultrasound | | | | Comments::
#6300 | Vienna, Austria | NR | NR | | Dis+ | Dis- | Tot | —Unclear how cases selected
| Dates: NR | Menopausal status (n [%]): | Detected by exam (n [%]): | T+ | 30 | 8 | 38 | —Clinical presentation not described
| Size of population: | NR | NR | T- | 7 | 22 | 29 | —No scoring system for US - unclear if descriptive analysis required all or any of the findings to be considered malignant - MRI more clearly described
| 73 women | Race/ethnicity (n [%]): | Detected by imaging (n [%]): | Tot | 37 | 30 | 67 | Quality assessment:
| Other | NR | NR | | | Lower | Upper | Reference standard: +
| Case series | Risk factors (n [%]): | Combination (n [%]): | | Value | 95% CI | 95% CI | Verification bias: +
| Reference standard: | NR | NR | Se | 81.0% | 68.4% | 93.6% | Test reliability/variability: -
| Surgery | Inclusion criteria: | Additional data used for diagnosis: | Sp | 73.0% | 57.1% | 88.9% | Sample size: -
| Reference standard applied to all test negatives?: | NR | Stage | PPV | 78.9% | 66.0% | 91.9% | Statistical tests: +
| Yes | Exclusion criteria: | I: n=11 (29.7%) | NPV | 75.9% | 60.3% | 91.4% | Blinding: -
| Test reliability established?: | NR | II: n=1 (2.7%) | 2) MRI | | | | Definition of +/- on screening test: +
| Not described or discussed | | III: n=24 (64.9%) | | Dis+ | Dis- | Tot
| Statistical tests used: | | IV: n=1 (2.7%) | T+ | 36 | 5 | 41
| Se/Sp | | | T- | 1 | 25 | 26
| Blinding: | | | Tot | 37 | 30 | 67
| Not described | | | | | Lower | Upper
| Definition of positive and negative on screening test: | | | | Value | 95% CI | 95% CI
| Ultrasound: | | | Se | 97.3% | 92.1% | 100.0%
| - Cyst with irregular wall; - Wall thickness > 3 cm; - Papillary wall structures; - Solid components; - Presence of ascites | | | Sp | 83.3% | 70.0% | 96.7%
| MRI: | | | PPV | 87.8% | 77.8% | 97.8%
| - > 4cm; - Wall thickness > 3 mm or nodular or other solid components; - Entirely solid; - Involvement of adjacent organs; - Ascites; - Lymph node > 1 cm; - Peritoneal, mesenteric, or omental disease | | | NPV | 96.2% | 88.8% | 100.0%
Menon, Talaat, Rosenthal, et al., 2000 | Geographical location: | Age: | Symptomatic (n [%]): | All results given using number of scans as denominator (n = 1219), disease defined as incident cancer within 1 year of scan | | | | Comments:
#2780 | London, UK | NR | NR | 1) Abnormal volume as threshold | | | | —Authors state no significant differences in sensitivity, but underpowered to detect differences
| Dates: 1986-1989 | Menopausal status (n [%]): | Detected by exam (n [%]): | | Dis+ | Dis- | Tot | Quality assessment:
| Size of population: | 100% postmenopausal, > 45 | NR | T+ | 17 | 63 | 80 | Reference standard: +
| 22,000 in prevalence screen, 10,958 randomized to 3 annual incidence screens. Results based on 741women | Race/ethnicity (n [%]): | Detected by imaging (n [%]): | T- | 2 | 945 | 947 | Verification bias: +
| Screening study | NR | NR | Tot | 19 | 1008 | 1027 | Test reliability/variability: -
| Reference standard: | Risk factors (n [%]): | Combination (n [%]): | | | Lower | Upper | Sample size: - (large study, but small number of cancers)
| Surgery, registry diagnosis of cancer, followup questionnaire | All with elevated CA-125 | NR | | Value | 95% CI | 95% CI | Statistical tests: -
| Reference standard applied to all test negatives?: | Inclusion criteria: | Additional data used for diagnosis: | Se | 89.5% | 75.7% | 100.0% | Blinding: +
| Yes | NR | All with CA-125 > 30 | Sp | 93.8% | 92.3% | 95.2% | Definition of +/- on screening test: +
| Test reliability established?: | Exclusion criteria: | 75.3% of scans transabdominal, 8.4% transvaginal, 16.2% both | PPV | 21.3% | 12.3% | 30.2%
| Not referenced or discussed | NR | | NPV | 99.8% | 99.5% | 100.0%
| Statistical tests used: | | | 2) Abnormal morphology as threshold
| Se/Sp | | | | Dis+ | Dis- | Tot
| Blinding: | | | T+ | 19 | 61 | 80
| Yes | | | T- | 0 | 947 | 947
| Definition of positive and negative on screening test: | | | Tot | 19 | 1008 | 1027
| If CA-125 > 30 U/ml, ultrasound | | | | | Lower | Upper
| If ultrasound normal: | | | | Value | 95% CI | 95% CI
| < 8.8 ml volume, uniform hypoechogenicity, smooth outlines, or not visualized but no abnormality | | | Se | 100.0% | 84.2% | 100.0%
| repeated CA-125 q 3 months × 1 year, then annual screening: | | | Sp | 93.9% | 92.5% | 95.4%
| Equivocal: | | | PPV | 23.8% | 14.4% | 33.1%
| Ovarian volume < 8.8 ml with abnormal morphology: repeat scan q 6 weeks until either normal or abnormal scan | | | NPV | 100.0% | 99.7% | 100.0%
| Abnormal: Ovarian volume > 8.8 ml, referred to gynecologist, with management at their discretion | | | 3) Complex morphology as threshold
| | | | | Dis+ | Dis- | Tot
| | | | T+ | 16 | 27 | 43
| | | | T- | 3 | 981 | 984
| | | | Tot | 19 | 1008 | 1027
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 84.2% | 67.8% | 100.0%
| | | | Sp | 97.3% | 96.3% | 98.3%
| | | | PPV | 37.2% | 22.8% | 51.7%
| | | | NPV | 99.7% | 99.4% | 100.0%
Merce, Caballero, Barco, et al., 1998 | Geographical location: | Age: | Symptomatic (n [%]): | 1) US score ≥ 6 | | | | Comments:
#3510 | Spain | Mean: 41 | NR | | Dis+ | Dis- | Tot | —Time interval from original diagnosis of mass to followup US was 2 weeks to 3 months
| Dates: 1990 - 1995 | Range: 15 - 87 | Detected by exam (n [%]): | T+ | 21 | 34 | 55 | —US score developed by authors in different paper [ref 15] and unclear how reliable. Test features of score not described.
| Size of population: | Menopausal status (n [%]): | NR | T- | 1 | 73 | 74 | —2×2 tables based on the 129 who had surgery only
| 213 | NR | Detected by imaging (n [%]): | Tot | 22 | 107 | 129 | Quality assessment:
| 129 had surgery | Race/ethnicity (n [%]): | NR | | | Lower | Upper | Reference standard: +, 2×2 table based only on those who had surgery
| Other | NR | Combination (n [%]): | | Value | 95% CI | 95% CI | Verification bias: -, only US followup in 213-129 patients
| Patients with masses ?referred to hospital | Risk factors (n [%]): | NR | Se | 95.5% | 86.8% | 100.0% | Test reliability/variability: -
| Reference standard: | NR | Additional data used for diagnosis: | Sp | 68.2% | 59.4% | 77.0% | Sample size: -
| Histopathology for those in surgery, repeat US for the others | Inclusion criteria: | NR | PPV | 38.2% | 25.3% | 51.0% | Statistical tests: +
| Reference standard applied to all test negatives?: | Premenopausal women with ovarian mass >28mm in diameter, or >10mm for menopausal women. | | NPV | 98.6% | 96.0% | 100.0% | Blinding: -
| No | Exclusion criteria: | | 2) RI ≤ 0.5 | | | | Definition of +/- on screening test: +
| Test reliability established?: | NR | | | Dis+ | Dis- | Tot
| Unclear for US score | | | T+ | 18 | 36 | 54
| Yes for RI | | | T- | 4 | 71 | 75
| Statistical tests used: | | | Tot | 22 | 107 | 129
| ROC curves | | | | | Lower | Upper
| Blinding: | | | | Value | 95% CI | 95% CI
| NR but US prior to surgery | | | Se | 80.0% | 63.3% | 96.7%
| Definition of positive and negative on screening test: | | | Sp | 66.7% | 57.8% | 75.6%
| RI ≤ 0.5 | | | PPV | 33.3% | 20.8% | 45.9%
| For US sonographic index score ≥ 6 which was volume + morphology score | | | NPV | 94.7% | 89.6% | 99.8%
Morgante, la Marca, Ditto, et al., 1999 | Geographical location: | Age: | Symptomatic (n [%]): | 1) US score of 2 | | | | Comments:
#2900 | Siena, Italy | NR: | NR | | Dis+ | Dis- | Tot | —What constitutes + CA-125 or US score not discussed
| Dates: Jan 1995 - Dec 1997 | Menopausal status (n [%]): | Detected by exam (n [%]): | T+ | 22 | 12 | 34 | —Borderline tumors grouped in with malignant in analysis
| Size of population: | Pre (< 45): 69 (55.6%) | NR | T- | 9 | 81 | 90 | Quality assessment:
| 124 | Post (> 55): 55 (44.3%) | Detected by imaging (n [%]): | Tot | 31 | 93 | 124 | Reference standard: +
| Other | Race/ethnicity (n [%]): | NR | | | Lower | Upper | Verification bias: +
| Case series | NR | Combination (n [%]): | | Value | 95% CI | 95% CI | Test reliability/variability: +/-
| Consecutive admissions for surgery | Risk factors (n [%]): | NR | Se | 71.0% | 55.0% | 87.0% | Sample size: -
| Reference standard: | NR | Additional data used for diagnosis: | Sp | 87.0% | 80.2% | 93.8% | Statistical tests: +
| Histopathology | Inclusion criteria: | NR | PPV | 64.7% | 48.6% | 80.8% | Blinding: +
| Reference standard applied to all test negatives?: | Age >30 | | NPV | 90.0% | 83.8% | 96.2% | Definition of +/- on screening test: -
| Yes | Mass scheduled for surgery in time frame | | 2) CA-125 ≥ 25 U/ml
| Test reliability established?: | Exclusion criteria: | | | Dis+ | Dis- | Tot
| Yes | NR | | T+ | 24 | 15 | 39
| Statistical tests used: | | | T- | 7 | 78 | 85
| Se, Sp, ROC | | | Tot | 31 | 93 | 124
| Chi-square | | | | | Lower | Upper
| Mann-Whitney U test | | | | Value | 95% CI | 95% CI
| Blinding: | | | Se | 78.0% | 63.4% | 92.6%
| NR - prospective | | | Sp | 84.0% | 76.5% | 91.5%
| Definition of positive and negative on screening test: | | | PPV | 61.5% | 46.3% | 76.8%
| CA-125 - range used | | | NPV | 91.8% | 85.9% | 97.6%
| US score: Presence of multilocular cystic lesions (1), solid areas (1), bilateral lesions (1), ascites (1), intraabdominal mets (1) | | | 3) CA-125 ≥ 50 U/ml
| | | | | Dis+ | Dis- | Tot
| | | | T+ | 23 | 5 | 28
| | | | T- | 8 | 88 | 96
| | | | Tot | 31 | 93 | 124
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 74.0% | 58.6% | 89.4%
| | | | Sp | 95.0% | 90.6% | 99.4%
| | | | PPV | 82.1% | 68.0% | 96.3%
| | | | NPV | 91.7% | 86.1% | 97.2%
O'Connell, Ryan, Murphy, et al., 1987 | Geographical location: | Age: | Symptomatic (n [%]): | 1) CA-125 threshold >35 U/ml, ovarian cancer vs. any other diagnosis (including other malignancy) | | | | Comments:
#6690 | Hamilton, Ontario | Mean (SD): 55 | NR | | Dis+ | Dis- | Tot | —Clinical presentation not reported
| Dates: Nov 1984-May 1986 | Range: 13–81 | Detected by exam (n [%]): | T+ | 26 | 17 | 43 | —Very high prevalence of cancer
| Size of population: | Menopausal status (n [%]): | NR | T- | 0 | 13 | 13 | —Borderline masses included in malignant
| 56 women | NR | Detected by imaging (n [%]): | Tot | 26 | 30 | 56 | Quality assessment:
| Other | Race/ethnicity (n [%]): | NR | | | Lower | Upper | Reference standard: +
| Case series | NR | Combination (n [%]): | | Value | 95% CI | 95% CI | Verification bias: +
| Reference standard: | Risk factors (n [%]): | NR | Se | 100.0% | 88.5% | 100.0% | Test reliability/variability: +
| Surgery/pathology | NR | Additional data used for diagnosis: | Sp | 43.3% | 25.6% | 61.1% | Sample size: -
| Reference standard applied to all test negatives?: | Inclusion criteria: | “High clinical suspicion of ovarian cancer” | PPV | 60.5% | 45.9% | 75.1% | Statistical tests: -
| Yes | NR | CA-125 drawn within 3 days of surgery | NPV | 100.0% | 76.9% | 100.0% | Blinding: +
| Test reliability established?: | Exclusion criteria: | | 2) CA-125 threshold > 60 U/ml, ovarian cancer vs. any other diagnosis (including other malignancy) | | | | Definition of +/- on screening test: +
| Yes | NR | | | Dis+ | Dis- | Tot
| Statistical tests used: | | | T+ | 24 | 12 | 36
| Se/Sp/ROC | | | T- | 2 | 18 | 20
| Blinding: | | | Tot | 26 | 30 | 56
| Yes | | | | | Lower | Upper
| Definition of positive and negative on screening test: | | | | Value | 95% CI | 95% CI
| Varied | | | Se | 92.0% | 81.6% | 100.0%
| | | | Sp | 60.0% | 42.5% | 77.5%
| | | | PPV | 66.7% | 51.3% | 82.1%
| | | | NPV | 90.0% | 76.9% | 100.0%
| | | | 3) CA-125 threshold > 35 U/ml, any malignancy vs. benign
| | | | | Dis+ | Dis- | Tot
| | | | T+ | 36 | 7 | 43
| | | | T- | 2 | 11 | 13
| | | | Tot | 38 | 18 | 56
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 95.0% | 88.1% | 100.0%
| | | | Sp | 61.0% | 38.5% | 83.5%
| | | | PPV | 83.7% | 72.7% | 94.8%
| | | | NPV | 84.6% | 65.0% | 100.0%
| | | | 4) CA-125 threshold > 60 U/ml, any malignancy vs. benign
| | | | | Dis+ | Dis- | Tot
| | | | T+ | 33 | 3 | 36
| | | | T- | 5 | 15 | 20
| | | | Tot | 38 | 18 | 56
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 87.0% | 76.3% | 97.7%
| | | | Sp | 83.0% | 65.6% | 100.0%
| | | | PPV | 91.7% | 82.6% | 100.0%
| | | | NPV | 75.0% | 56.0% | 94.0%
Onsrud, Shabana, and Austgulen, 1996 | Geographical location: | Age: | Symptomatic (n [%]): | 1) CA-125 > 20 U/ml | | | | Comments:
#3950 | Trondheim, Norway | Range: 19–80 years | NR | | Dis+ | Dis- | Tot | —Clinical presentation not reported
| Dates: NR | Menopausal status (n [%]): | Detected by exam (n [%]): | T+ | 37 | 4 | 41 | —Spectrum of disease reported
| Size of population: | NR | NR | T- | 8 | 23 | 31 | —Patient selection criteria not described
| 72 women | Race/ethnicity (n [%]): | Detected by imaging (n [%]): | Tot | 45 | 27 | 72 | — CA-125 cutpoint derived from mean +2 SD of the 26 control women
| Other | NR | NR | | | Lower | Upper | Quality assessment:
| Case series | Risk factors (n [%]): | Combination (n [%]): | | Value | 95% CI | 95% CI | Reference standard: +
| Reference standard: | NR | NR | Se | 82.0% | 70.8% | 93.2% | Verification bias: +
| Surgery/pathology | Inclusion criteria: | Additional data used for diagnosis: | Sp | 85.0% | 71.5% | 98.5% | Test reliability/variability: +
| Reference standard applied to all test negatives?: | NR | Stage I: 20/45 (44.4%) | PPV | 90.2% | 81.2% | 99.3% | Sample size: -
| Yes | Exclusion criteria: | Stage II: 1/45 (2.2%) | NPV | 74.2% | 58.8% | 89.6% | Statistical tests: +
| Test reliability established?: | NR | Stage III: 21/45 (46.7%) | 2) TNF p 55 > 2.0 ng/ml | | | | Blinding: +
| Yes | | Stage IV: 1/45 (2.2%) | | Dis+ | Dis- | Tot | Definition of +/- on screening test: +
| Statistical tests used: | | | T+ | 26 | 3 | 29
| Wilcoxon rank sum, Se/Sp | | | T- | 19 | 24 | 43
| Blinding: | | | Tot | 45 | 27 | 72
| Yes | | | | | Lower | Upper
| Definition of positive and negative on screening test: | | | | Value | 95% CI | 95% CI
| Varied | | | Se | 58.0% | 43.6% | 72.4%
| | | | Sp | 89.0% | 77.2% | 100.0%
| | | | PPV | 89.7% | 78.6% | 100.0%
| | | | NPV | 55.8% | 41.0% | 70.7%
| | | | 3) TNF p 75 > 4.3 ng/ml
| | | | | Dis+ | Dis- | Tot
| | | | T+ | 7 | 1 | 8
| | | | T- | 38 | 26 | 64
| | | | Tot | 45 | 27 | 72
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 16.0% | 5.3% | 26.7%
| | | | Sp | 96.0% | 88.6% | 100.0%
| | | | PPV | 87.5% | 64.6% | 100.0%
| | | | NPV | 40.6% | 28.6% | 52.7%
Padungsutt, Thira-pagawong, Senapad, et al., 2000 | Geographical location: | Age: | Symptomatic (n [%]): | 1) Tissue polypeptide specific antigen > 80 U/L | | | | Comments:
#520 | Bangkok, Thailand | Mean (SD): 38.8 (2.8) | NR | | Dis+ | Dis- | Tot | —Clinical presentation not described
| Dates: May 1996-Mar 1997 | Range: 10–69 | Detected by exam (n [%]): | T+ | 36 | 15 | 51 | —Not stratified by age, menopausal status
| Size of population: | Menopausal status (n [%]): | NR | T- | 4 | 37 | 41 | —Patient selection criteria not described
| 92 women | Pre (< 45): 64 (69.6%) | Detected by imaging (n [%]): | Tot | 40 | 52 | 92 | —Borderline tumors grouped with malignant
| Other | Post (> 55): 28 (30.4%) | NR | | | Lower | Upper | —Not a common test modality
| Case series | Race/ethnicity (n [%]): | Combination (n [%]): | | Value | 95% CI | 95% CI | Quality assessment:
| Reference standard: | NR | NR | Se | 90.0% | 80.7% | 99.3% | Reference standard: +
| Surgery | Risk factors (n [%]): | Additional data used for diagnosis: | Sp | 71.2% | 58.8% | 83.5% | Verification bias: +
| Reference standard applied to all test negatives?: | NR | Stage I: 17/40 (42.5%) | PPV | 70.6% | 58.1% | 83.1% | Test reliability/variability:+
| Yes | Inclusion criteria: | Stage II: 3/40 (7.5%) | NPV | 90.2% | 81.2% | 99.3% | Sample size: -
| Test reliability established?: | NR | Stage III: 20/40 (50%) | | | | | Statistical tests:+
| Yes | Exclusion criteria: | | | | | | Blinding: +
| Statistical tests used: | NR | | | | | | Definition of +/- on screening test: +
| Blinding:
| Definition of positive and negative on screening test:
Patsner and Mann, 1988 | Geographical location: | Age: | Symptomatic (n [%]): | 1) CA-125 > 35 U/ml, All patients | | | | Comments:
#5360 | Stony Brook, NY | NR | NR | | Dis+ | Dis- | Tot | —Clinical presentation not described
| Dates: Jul 1985-Jul 1987 | Menopausal status (n [%]): | Detected by exam (n [%]): | T+ | 92 | 25 | 117 | —Borderline tumors grouped with malignant
| Size of population: | Pre (< 45): 125 (50%) | NR | T- | 36 | 97 | 133 | Quality assessment:
| 250 women | Post (> 55): 125 (50%) | Detected by imaging (n [%]): | Tot | 128 | 122 | 250 | Reference standard: +
| Other | Race/ethnicity (n [%]): | NR | | | Lower | Upper | Verification bias: +
| Consecutive case series | NR | Combination (n [%]): | | Value | 95% CI | 95% CI | Test reliability/variability: +
| Reference standard: | Risk factors (n [%]): | NR | Se | 71.9% | 64.1% | 79.7% | Sample size: -
| Surgery/pathology | NR | Additional data used for diagnosis: | Sp | 79.5% | 72.3% | 86.7% | Statistical tests: +
| Reference standard applied to all test negatives?: | Inclusion criteria: | Invasive ovarian cancer | PPV | 78.6% | 71.2% | 86.1% | Blinding: +
| Yes | NR | Stage I: 14/80 (17.5%) | NPV | 72.9% | 65.4% | 80.5% | Definition of +/- on screening test: +
| Test reliability established?: | Exclusion criteria: | Stage II: 3/80 (3.8%) | 2) CA-125 > 35 U/ml, Premenopausal
| Yes | NR | Stage III: 50/80 (62.5%) | | Dis+ | Dis- | Tot
| Statistical tests used: | | Stage IV: 13/80 (16.3%) | T+ | 33 | 16 | 49
| Se/Sp | | | T- | 18 | 58 | 76
| Blinding: | | | Tot | 51 | 74 | 125
| Yes | | | | | Lower | Upper
| Definition of positive and negative on screening test: | | | | Value | 95% CI | 95% CI
| CA-125 > 35 | | | Se | 65.0% | 51.9% | 78.1%
| | | | Sp | 78.0% | 68.6% | 87.4%
| | | | PPV | 67.3% | 54.2% | 80.5%
| | | | NPV | 76.3% | 66.8% | 85.9%
| | | | 3) CA-125 > 35 U/ml, Postmenopausal
| | | | | Dis+ | Dis- | Tot
| | | | T+ | 59 | 9 | 68
| | | | T- | 18 | 39 | 57
| | | | Tot | 77 | 48 | 125
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 77.0% | 67.6% | 86.4%
| | | | Sp | 81.0% | 69.9% | 92.1%
| | | | PPV | 86.8% | 78.7% | 94.8%
| | | | NPV | 68.4% | 56.4% | 80.5%
Prompeler, Madjar, and Sauerbrei, 1996 | Geographical location: | Age: | Symptomatic (n [%]): | Malignant disease includes borderline (n = 9) | | | | Comments:
#3960 | Freiburg, Germany | NR | NR | 1) Total number of arteries > 4, all patients | | | | —Clinical presentation not described
| Dates: Jul 1992-Jul 1994 | Menopausal status (n [%]): | Detected by exam (n [%]): | | Dis+ | Dis- | Tot | —LMP tumors grouped with malignant
| Size of population: | Pre (< 45): 81 (38.2%) | NR | T+ | 56 | 34 | 90 | Quality assessment:
| 212 consecutive cases | Post (> 55): 131 (61.8%) | Detected by imaging (n [%]): | T- | 12 | 110 | 122 | Reference standard: +
| Other | Race/ethnicity (n [%]): | NR | Tot | 68 | 144 | 212 | Verification bias: +
| Case series | NR | Combination (n [%]): | | | Lower | Upper | Test reliability/variability: +
| Reference standard: | Risk factors (n [%]): | NR | | Value | 95% CI | 95% CI | Sample size: + (discussion of power)
| Surgery | NR | Additional data used for diagnosis: | Se | 82.4% | 73.3% | 91.5% | Statistical tests: +
| Reference standard applied to all test negatives?: | Inclusion criteria: | US timed to surgery date - therefore not all premenopausal US done in proliferative phase | Sp | 76.4% | 69.5% | 83.3% | Blinding:
| Yes | NR | | PPV | 62.2% | 52.2% | 72.2% | Definition of +/- on screening test: +
| Test reliability established?: | Exclusion criteria: | | NPV | 90.2% | 84.9% | 95.4%
| Discussed | NR | | 2) Total number of arteries > 4, postmenopausal
| Statistical tests used: | | | | Dis+ | Dis- | Tot
| Spearman's, Mann-Whitney, See/Sp | | | T+ | 45 | 14 | 59
| Blinding: | | | T- | 10 | 62 | 72
| No | | | Tot | 55 | 76 | 131
| Definition of positive and negative on screening test: | | | | | Lower | Upper
| 20 different measures of ovarian vascularity, flow studied. 4 best criteria were | | | | Value | 95% CI | 95% CI
| - Minimum resistive index (difference of peak systolic and maximum end diastolic, divided by peak systolic flow velocity; cutpoint 0.5; - Total number of tumor arteries in color mode; cutpoint 4; - Maximum systolic flow velocity; cutpoint 30 cm/sec; - Sum of all systolic flow velocities; cutpoint 75 cm/sec | | | Se | 81.8% | 71.6% | 92.0%
| | | | Sp | 81.6% | 72.9% | 90.3%
| | | | PPV | 76.3% | 65.4% | 87.1%
| | | | NPV | 86.1% | 78.1% | 94.1%
| | | | 3) Total number of arteries > 4, premenopausal
| | | | | Dis+ | Dis- | Tot
| | | | T+ | 11 | 20 | 31
| | | | T- | 2 | 48 | 50
| | | | Tot | 13 | 68 | 81
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 84.6% | 65.0% | 100.0%
| | | | Sp | 70.6% | 59.8% | 81.4%
| | | | PPV | 35.5% | 18.6% | 52.3%
| | | | NPV | 96.0% | 90.6% | 100.0%
| | | | 4) Min resistive index > 0.5, all patients
| | | | | Dis+ | Dis- | Tot
| | | | T+ | 56 | 59 | 115
| | | | T- | 12 | 85 | 97
| | | | Tot | 68 | 144 | 212
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 82.1% | 73.0% | 91.2%
| | | | Sp | 59.2% | 51.2% | 67.2%
| | | | PPV | 48.7% | 39.6% | 57.8%
| | | | NPV | 87.6% | 81.1% | 94.2%
| | | | 5) Min resistive index, postmenopausal
| | | | | Dis+ | Dis- | Tot
| | | | T+ | 45 | 23 | 68
| | | | T- | 10 | 53 | 63
| | | | Tot | 55 | 76 | 131
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 81.5% | 71.2% | 91.8%
| | | | Sp | 69.2% | 58.8% | 79.6%
| | | | PPV | 66.2% | 54.9% | 77.4%
| | | | NPV | 84.1% | 75.1% | 93.2%
| | | | 6) Min resistive index, premenopausal
| | | | | Dis+ | Dis- | Tot
| | | | T+ | 11 | 36 | 47
| | | | T- | 2 | 32 | 34
| | | | Tot | 13 | 68 | 81
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 84.6% | 65.0% | 100.0%
| | | | Sp | 47.1% | 35.2% | 58.9%
| | | | PPV | 23.4% | 11.3% | 35.5%
| | | | NPV | 94.1% | 86.2% | 100.0%
| | | | 7) Maximum systolic velocity, all patients
| | | | | Dis+ | Dis- | Tot
| | | | T+ | 54 | 33 | 87
| | | | T- | 14 | 111 | 125
| | | | Tot | 68 | 144 | 212
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 79.1% | 69.4% | 88.8%
| | | | Sp | 76.8% | 69.9% | 83.7%
| | | | PPV | 62.1% | 51.9% | 72.3%
| | | | NPV | 88.8% | 83.3% | 94.3%
| | | | 8) Max systolic velocity, postmenopausal
| | | | | Dis+ | Dis- | Tot
| | | | T+ | 42 | 9 | 51
| | | | T- | 13 | 67 | 80
| | | | Tot | 55 | 76 | 131
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 75.9% | 64.6% | 87.2%
| | | | Sp | 87.7% | 80.3% | 95.1%
| | | | PPV | 82.4% | 71.9% | 92.8%
| | | | NPV | 83.8% | 75.7% | 91.8%
| | | | 9) Max systolic velocity, premenopausal
| | | | | Dis+ | Dis- | Tot
| | | | T+ | 21 | 24 | 45
| | | | T- | 1 | 44 | 45
| | | | Tot | 22 | 68 | 90
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 95.5% | 86.8% | 100.0%
| | | | Sp | 64.7% | 53.3% | 76.1%
| | | | PPV | 46.7% | 32.1% | 61.2%
| | | | NPV | 97.8% | 93.5% | 100.0%
| | | | 10) Sum of systolic velocities, all patients
| | | | | Dis+ | Dis- | Tot
| | | | T+ | 61 | 38 | 99
| | | | T- | 7 | 106 | 113
| | | | Tot | 68 | 144 | 212
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 89.6% | 82.3% | 96.9%
| | | | Sp | 73.6% | 66.4% | 80.8%
| | | | PPV | 61.6% | 52.0% | 71.2%
| | | | NPV | 93.8% | 89.4% | 98.2%
| | | | 11) Sum of systolic velocities, postmenopausal
| | | | | Dis+ | Dis- | Tot
| | | | T+ | 50 | 12 | 62
| | | | T- | 5 | 64 | 69
| | | | Tot | 55 | 76 | 131
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 90.7% | 83.0% | 98.4%
| | | | Sp | 84.6% | 76.5% | 92.7%
| | | | PPV | 80.6% | 70.8% | 90.5%
| | | | NPV | 92.8% | 86.6% | 98.9%
Pyrgiotis, Sala-malekis, Loghis, et al., 1993 | Geographical location: | Age: | Symptomatic (n [%]): | 1) All pelvic masses Borderline included as malignant (n = 4) | | | | Comments:
#4790 | Athens, Greece | NR | NR | CA-125 > 35 U/ml | | | | —Clinical presentation not described
| Dates: NR | Menopausal status (n [%]): | Detected by exam (n [%]): | | Dis+ | Dis- | Tot | —Drawn within 2 days of surgery
| Size of population: | NR | NR | T+ | 48 | 7 | 55 | Quality assessment:
| 126 women | Race/ethnicity (n [%]): | Detected by imaging (n [%]): | T- | 14 | 57 | 71 | Reference standard: +
| Other | NR | NR | Tot | 62 | 64 | 126 | Verification bias: +
| Case series | Risk factors (n [%]): | Combination (n [%]): | | | Lower | Upper | Test reliability/variability: +
| Reference standard: | NR | NR | | Value | 95% CI | 95% CI | Sample size: -
| Surgery/pathology | Inclusion criteria: | Additional data used for diagnosis: | Se | 77.4% | 67.0% | 87.8% | Statistical tests: +
| Reference standard applied to all test negatives?: | NR | NR | Sp | 89.1% | 81.4% | 96.7% | Blinding: +
| Yes | Exclusion criteria: | | PPV | 87.3% | 78.5% | 96.1% | Definition of +/- on screening test: +
| Test reliability established?: | NR | | NPV | 80.3% | 71.0% | 89.5%
| Yes | | | 2) Ovarian masses only (excluding fibroids etc)
| Statistical tests used: | | | | Dis+ | Dis- | Tot
| Se/Sp | | | T+ | 46 | 3 | 49
| Blinding: | | | T- | 8 | 26 | 34
| Yes | | | Tot | 54 | 29 | 83
| Definition of positive and negative on screening test: | | | | | Lower | Upper
| CA-125 > 35 U/ml | | | | Value | 95% CI | 95% CI
| | | | Se | 85.2% | 75.7% | 94.7%
| | | | Sp | 89.7% | 78.6% | 100.0%
| | | | PPV | 93.9% | 87.2% | 100.0%
| | | | NPV | 76.5% | 62.2% | 90.7%
Rehn, Lohmann, and Rempen, 1996 | Geographical location: | Age: | Symptomatic (n [%]): | 1) Sassone's score ≥ 9 | | | | Comments:
#3910 | Wurzburg, Germany | Mean: 43.5 | NR | | Dis+ | Dis- | Tot | —Document overlap in RI between benign and malignant masses
| Dates: Mar 1992 - Dec 1994 | Range: 17–88 | Detected by exam (n [%]): | T+ | 43 | 70 | 113 | —Unclear if prospective or retrospective case series
| Size of population: | Menopausal status (n [%]): | NR | T- | 8 | 189 | 197 | —LMP tumors grouped with malignant
| 310 | Pre (< 45): 227 (73%) | Detected by imaging (n [%]): | Tot | 51 | 259 | 310 | —Overlap noted for PI between malignant and benign masses
| Case series | Post (> 55): 83(27%) | 310(100%) | | | Lower | Upper | —Regression analysis showed negative correlation of PI and tumor size for malignant masses and in total, but independence when only benign lesions analysed
| Reference standard: | Race/ethnicity (n [%]): | Combination (n [%]): | | Value | 95% CI | 95% CI | —TVUS only
| Histopathology | NR | NR | Se | 84.0% | 73.9% | 94.1% | Quality assessment:
| Reference standard applied to all test negatives?: | Risk factors (n [%]): | Additional data used for diagnosis: | Sp | 73.0% | 67.6% | 78.4% | Reference standard: +
| Yes for 300 women 10 premenopausal women were “followed up to resolution” | NR | NR | PPV | 38.1% | 29.1% | 47.0% | Verification bias: +
| Test reliability established?: | Inclusion criteria: | | NPV | 95.9% | 93.2% | 98.7% | Test reliability/variability: -
| Yes | Unclear - presumably women with masses in hospital during time frame who had US | | 2) US morphology descriptive (group 4) | | | | Sample size: -
| Statistical tests used: | Exclusion criteria: | | | Dis+ | Dis- | Tot | Statistical tests: +
| Chi square | Uterine malignancy | | T+ | 46 | 91 | 137 | Blinding: -
| U test | | | T- | 5 | 168 | 173 | Definition of +/- on screening test: +
| Wilcoxon test | | | Tot | 51 | 259 | 310
| Regression analysis | | | | | Lower | Upper
| Blinding: | | | | Value | 95% CI | 95% CI
| NR | | | Se | 90.0% | 81.8% | 98.2%
| Definition of positive and negative on screening test: | | | Sp | 65.0% | 59.2% | 70.8%
| US morphology - Sassone's criteria score ≥ 9 as well as presence of “inhomogeneous echogenicity, irregular wall, or solid portion” considered suggestive of malignancy | | | PPV | 33.6% | 25.7% | 41.5%
| PI ≤ 1.0 | | | NPV | 97.1% | 94.6% | 99.6%
| | | | 3) PI ≤ 1.0
| | | | | Dis+ | Dis- | Tot
| | | | T+ | 34 | 122 | 156
| | | | T- | 17 | 137 | 154
| | | | Tot | 51 | 259 | 310
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 67.0% | 54.1% | 79.9%
| | | | Sp | 53.0% | 46.9% | 59.1%
| | | | PPV | 21.8% | 15.3% | 28.3%
| | | | NPV | 89.0% | 84.0% | 93.9%
Reles, Wein, and Lichten-egger, 1997 | Geographical location: | Age: | Symptomatic (n [%]): | Cancers of non-ovarian origin (n = 7) not included | | | | Comments:
#6090 | Berlin, Germany | NR | NR | 1) TVUS, all patients | | | | —Clinical presentation not described
| Dates: Mar 1992-Aug 1994 | Menopausal status (n [%]): | Detected by exam (n [%]): | | Dis+ | Dis- | Tot | — 2×2 tables for pre and post menopausal subgroups are approximate, with N, Se, Sp consistent with Table 3, but allowing for some discrepancies with PPV or NPV
| Size of population: | Pre (< 45):33 (36.3%) | NR | T+ | 20 | 11 | 31 | Quality assessment:
| 98 women | Post (> 55): 52 (57.1%) | Detected by imaging (n [%]): | T- | 2 | 58 | 60 | Reference standard: +
| Other | Unknown: 5 (5.55%) | NR | Tot | 22 | 69 | 91 | Verification bias: +
| Case series | Race/ethnicity (n [%]): | Combination (n [%]): | | | Lower | Upper | Test reliability/variability: -
| Reference standard: | NR | NR | | Value | 95% CI | 95% CI | Sample size: -
| Surgery/pathology | Risk factors (n [%]): | Additional data used for diagnosis: | Se | 90.9% | 78.9% | 100.0% | Statistical tests:+
| Reference standard applied to all test negatives?: | NR | NR | Sp | 84.1% | 75.4% | 92.7% | Blinding: -
| Yes | Inclusion criteria: | | PPV | 64.5% | 47.7% | 81.4% | Definition of +/- on screening test: +
| Test reliability established?: | NR | | NPV | 96.7% | 92.1% | 100.0%
| Not referenced or discussed | Exclusion criteria: | | 2) TVUS, premenopausal (n = 33)
| Statistical tests used: | NR | | | Dis+ | Dis- | Tot
| Chi-square, Mann-Whitney, Se/Sp | | | T+ | 5 | 6 | 11
| Blinding: | | | T- | 0 | 22 | 22
| NR | | | Tot | 5 | 28 | 33
| Definition of positive and negative on screening test: | | | | | Lower | Upper
| Morphology: Malignant if | | | | Value | 95% CI | 95% CI
| - Complex cystic pattern with irregularly thick septae; - Cystic or polycystic pattern with papillary or indented mural part; - Polycystic pattern with irregularly thick septae and solid part < 50%; - Solid pattern (>50%) with irregular cystic part; - Completely solid homogeneous or inhomogeneous patter | | | Se | 100.0% | 40.0% | 100.0%
| (modified morphology classification from Vera 1986 and Kawai 1992) | | | Sp | 78.6% | 63.4% | 93.8%
| Color Doppler | | | PPV | 45.5% | 16.0% | 74.9%
| Pulsatility index ≤ 1.1 | | | NPV | 100.0% | 86.4% | 100.0%
| Resistive index 0.7 | | | 3) TVUS, postmenopausal (n = 52)
| Lowest measured PI and RI used | | | | Dis+ | Dis- | Tot
| | | | T+ | 13 | 4 | 17
| | | | T- | 2 | 33 | 35
| | | | Tot | 15 | 37 | 52
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 86.7% | 69.5% | 100.0%
| | | | Sp | 89.2% | 79.2% | 99.2%
| | | | PPV | 76.5% | 56.3% | 96.6%
| | | | NPV | 94.3% | 86.6% | 100.0%
| | | | 4) Color Doppler pulsatility index ≤ 1.1
| | | | | Dis+ | Dis- | Tot
| | | | T+ | 18 | 12 | 30
| | | | T- | 2 | 34 | 36
| | | | Tot | 20 | 46 | 66
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 90.0% | 76.9% | 100.0%
| | | | Sp | 74.0% | 61.3% | 86.7%
| | | | PPV | 60.1% | 42.5% | 77.6%
| | | | NPV | 94.5% | 87.0% | 100.0%
| | | | 5) Color Doppler pulsatility index ≤ 1.1, premenopausal (n = 24)
| | | | | Dis+ | Dis- | Tot
| | | | T+ | 4 | 6 | 10
| | | | T- | 1 | 13 | 14
| | | | Tot | 5 | 19 | 24
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 80.0% | 44.9% | 100.0%
| | | | Sp | 68.4% | 47.5% | 89.3%
| | | | PPV | 40.0% | 9.6% | 70.4%
| | | | NPV | 92.9% | 79.4% | 100.0%
| | | | 6) Color Doppler pulsatility index ≤ 1.1, postmenopausal (n = 37)
| | | | | Dis+ | Dis- | Tot
| | | | T+ | 13 | 4 | 17
| | | | T- | 1 | 19 | 20
| | | | Tot | 14 | 23 | 37
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 92.9% | 79.4% | 100.0%
| | | | Sp | 82.6% | 67.1% | 98.1%
| | | | PPV | 76.5% | 56.3% | 96.6%
| | | | NPV | 95.0% | 85.4% | 100.0%
Reuter, Steffens, Schuppler, et al., 1998 | Geographical location: | Age: | Symptomatic (n [%]): | 1) MRI | | | | Comments:
#10990 | Germany | Mean: 48.8 | NR | | Dis+ | Dis- | Tot | —For MRI used different machines, different contrast materials, different imaging techniques with study group
| Dates: Jan 1994 - Aug 1995 | Range: 18–84 | Detected by exam (n [%]): | T+ | 12 | 12 | 24 | —Diagnosis done by consensus in conference (2 gynecologists for US, 2 radiologists for MRI) - not blinded to each other
| Size of population: | Menopausal status (n [%]): | NR | T- | 0 | 41 | 41 | —No mention of whether blinded to pathologic results
| 65 | NR | Detected by imaging (n [%]): | Tot | 12 | 53 | 65 | —Used criteria for malignancy (citation 16) which are not common
| Case series (retrospective) | Race/ethnicity (n [%]): | NR | | | Lower | Upper | —Borderline grouped with malignant
| Reference standard: | NR | Combination (n [%]): | | Value | 95% CI | 95% CI | -TVUS only
| Histopathology | Risk factors (n [%]): | NR | Se | 100.0% | 75.0% | 100.0% | Quality assessment:
| Reference standard applied to all test negatives?: | NR | Additional data used for diagnosis: | Sp | 78.2% | 67.1% | 89.3% | Reference standard: +
| Yes | Inclusion criteria: | NR | PPV | 50.0% | 30.0% | 70.0% | Verification bias: +
| Test reliability established?: | Patients with suspected adnexal tumors in time frame | | NPV | 100.0% | 92.7% | 100.0% | Test reliability/variability: -
| Yes | Exclusion criteria: | | 2) TVUS | | | | Sample size: -
| Statistical tests used: | NR | | | Dis+ | Dis- | Tot | Statistical tests: +/-
| Chi square | | | T+ | 12 | 18 | 30 | Blinding: -
| Blinding: | | | T- | 0 | 35 | 35 | Definition of +/- on screening test: +/-
| NR | | | Tot | 12 | 53 | 65
| Definition of positive and negative on screening test: | | | | | Lower | Upper
| Used criteria from reference [16] | | | | Value | 95% CI | 95% CI
| Malignancy assumed if one or more of the following was present: solid growth or solid component wall with or without necrosis; cystic lesion with thickness of walls or septa more than 3 mm; nodular or papillary projections; excessive multilocularity; infiltration in neighboring organs or pelvic wall; tumor manifestation in the peritoneum, mesentery, omentum; lymphadenopathy. | | | Se | 100.0% | 75.0% | 100.0%
| Benign was none of the above present | | | Sp | 65.5% | 52.7% | 78.3%
| | | | PPV | 40.0% | 22.5% | 57.5%
| | | | NPV | 100.0% | 91.4% | 100.0%
Roman, Muder-spach, Burnett, et al., 1998 | Geographical location: | Age: | Symptomatic (n [%]): | 1) CEA > 3 ng/ml, borderline classified as malignant | | | | Comments:
#3410 | Los Angeles, CA | Mean: 39 | NR | | Dis+ | Dis- | Tot | —Clinical presentation not described
| Dates: Jul 1992-Mar 1994 | Range: 13–80 | Detected by exam (n [%]): | T+ | 7 | 13 | 20 | —Not stratified by age or menopausal status
| Size of population: | Menopausal status (n [%]): | NR | T- | 25 | 181 | 206 | —Borderline tumors included with malignant
| 226 women | NR | Detected by imaging (n [%]): | Tot | 32 | 194 | 226 | Quality assessment:
| Other | Race/ethnicity (n [%]): | NR | | | Lower | Upper | Reference standard: +
| Case series | NR | Combination (n [%]): | | Value | 95% CI | 95% CI | Verification bias: +
| Reference standard: | Risk factors (n [%]): | NR | Se | 21.9% | 7.6% | 36.2% | Test reliability/variability: +
| Surgery/pathology | NR | Additional data used for diagnosis: | Sp | 93.3% | 89.8% | 96.8% | Sample size: -
| Reference standard applied to all test negatives?: | Inclusion criteria: | NR | PPV | 35.0% | 14.1% | 55.9% | Statistical tests: +
| Yes | Isolated pelvic mass with surgery planned | | NPV | 87.9% | 83.4% | 92.3% | Blinding: +
| Test reliability established?: | Exclusion criteria: | | 2) CEA > 3 ng/ml, borderline classified as benign | | | | Definition of +/- on screening test: +
| Yes | Emergency surgery | | | Dis+ | Dis- | Tot
| Statistical tests used: | Evidence of metastases | | T+ | 5 | 15 | 20
| Fisher's exact test, Se/Sp | Past history of cancer | | T- | 17 | 189 | 206
| Blinding: | | | Tot | 22 | 204 | 226
| Yes | | | | | Lower | Upper
| Definition of positive and negative on screening test: | | | | Value | 95% CI | 95% CI
| CEA: > 3.0 ng/ml in nonsmokers, > 5.0 ng/ml in smokers | | | Se | 22.7% | 5.2% | 40.2%
| | | | Sp | 92.6% | 89.1% | 96.2%
| | | | PPV | 25.0% | 6.0% | 44.0%
| | | | NPV | 91.7% | 88.0% | 95.5%
Roman, Muder-spach, Stein, et al., 1997 | Geographical location: | Age: | Symptomatic (n [%]): | 1) Borderline classified as malignant CA-125 > 35 U/ml | | | | Comments:
#6160 | Los Angeles, CA | NR | NR | | Dis+ | Dis- | Tot | —Clinical presentation not described
| Dates: Jul 1992-Mar 1994 | Menopausal status (n [%]): | Detected by exam (n [%]): | T+ | 29 | 54 | 83 | —US authors stated scoring system used, however, description in text makes it seem more of a descriptive not numeric score
| Size of population: | Pre (< 45): 181 (80.1%) | NR | T- | 14 | 129 | 143 | Quality assessment:
| 226 | Post (> 55): 45 (19.9%) | Detected by imaging (n [%]): | Tot | 43 | 183 | 226 | Reference standard:+
| Other | Race/ethnicity (n [%]): | NR | | | Lower | Upper | Verification bias: +
| Non-consecutive case series | NR | Combination (n [%]): | | Value | 95% CI | 95% CI | Test reliability/variability: -
| Reference standard: | Risk factors (n [%]): | NR | Se | 67.4% | 53.4% | 81.4% | Sample size: -
| Surgery/pathology | NR | Additional data used for diagnosis: | Sp | 70.5% | 63.9% | 77.1% | Statistical tests: +
| Reference standard applied to all test negatives?: | Inclusion criteria: | NR | PPV | 34.9% | 24.7% | 45.2% | Blinding: -
| Yes | Isolated pelvic mass with surgery planned | | NPV | 90.2% | 85.3% | 95.1% | Definition of +/- on screening test: +
| Test reliability established?: | Exclusion criteria: | | 2) Any positive tumor marker
| Statistical tests used: | Emergency surgery | | | Dis+ | Dis- | Tot
| Chi-square, logistic regression, Se/Sp | Evidence of metastases | | T+ | 31 | 55 | 86
| Blinding: | Past history of cancer | | T- | 12 | 128 | 140
| NR | | | Tot | 43 | 183 | 226
| Definition of positive and negative on screening test: | | | | | Lower | Upper
| CA-125: >35 U/mL | | | | Value | 95% CI | 95% CI
| HCG: > 15 | | | Se | 72.1% | 58.7% | 85.5%
| AFP: > 10 ng/ml | | | Sp | 70.0% | 63.4% | 76.6%
| LDH: > 350 U/L | | | PPV | 36.1% | 25.9% | 46.2%
| Gray scale ultrasound: | | | NPV | 91.4% | 86.8% | 96.1%
| Cystic with one large (> 2 cm) or multiple nodules or cystic/solid; completely solid masses not appearing to arise from the uterus in postmenopausal women Simplified scoring system used (not described in scoring fashion) | | | 3) Any positive tumor marker, post-menopausal
| Doppler (only if gray scale suspicious) | | | | Dis+ | Dis- | Tot
| PI < 1.0 or | | | T+ | 11 | 6 | 17
| RI < 0.4 | | | T- | 5 | 23 | 28
| | | | Tot | 16 | 29 | 45
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 68.8% | 46.1% | 91.5%
| | | | Sp | 79.3% | 64.6% | 94.0%
| | | | PPV | 64.7% | 42.0% | 87.4%
| | | | NPV | 82.1% | 68.0% | 96.3%
| | | | 4) Ultrasound—all patients
| | | | | Dis+ | Dis- | Tot
| | | | T+ | 38 | 24 | 62
| | | | T- | 5 | 159 | 164
| | | | Tot | 43 | 183 | 226
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 88.4% | 78.8% | 98.0%
| | | | Sp | 86.9% | 82.0% | 91.8%
| | | | PPV | 61.3% | 49.2% | 73.4%
| | | | NPV | 97.0% | 94.3% | 99.6%
| | | | 5) Ultrasound: Premenopausal
| | | | | Dis+ | Dis- | Tot
| | | | T+ | 25 | 13 | 38
| | | | T- | 2 | 141 | 143
| | | | Tot | 27 | 154 | 181
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 92.6% | 82.7% | 100.0%
| | | | Sp | 91.6% | 87.2% | 96.0%
| | | | PPV | 65.9% | 50.8% | 81.0%
| | | | NPV | 98.6% | 96.7% | 100.0%
| | | | 6) Ultrasound: Postmenopausal
| | | | | Dis+ | Dis- | Tot
| | | | T+ | 13 | 11 | 24
| | | | T- | 3 | 18 | 21
| | | | Tot | 16 | 29 | 45
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 81.3% | 62.2% | 100.0%
| | | | Sp | 62.1% | 44.4% | 79.8%
| | | | PPV | 54.2% | 34.3% | 74.1%
| | | | NPV | 85.8% | 70.8% | 100.0%
Salem, White, and Lai, 1994 | Geographical location: | Age: | Symptomatic (n [%]): | 1) PI < 1 | | | | Comments:
#4430 | Toronto, Canada | Range: 15–58 | NR | | Dis+ | Dis- | Tot | —Analysis done on masses not individuals
| Dates: Sep 1992 - Jan 1994 | Menopausal status (n [%]): | Detected by exam (n [%]): | T+ | 10 | 17 | 27 | —No flow detected in 7 of 89 benign lesions; these cases excluded.
| Size of population: | Pre (< 45): 57 (57.6%) | NR | T- | 3 | 65 | 68 | —Scoring system most likely Sasonne or modified but not described at all.
| 99 patients | Peri (45–54): 23 (23.2%) | Detected by imaging (n [%]): | Tot | 13 | 82 | 95 | —But unable to use US morphology to construct 2×2 tables
| 102 masses from among 377 women with adnexal mass at sonography | Post (> 55): 19 (19.2%) | 100% had adnexal mass detected at sonography | | | Lower | Upper | Quality assessment:
| Other | Race/ethnicity (n [%]): | Combination (n [%]): | | Value | 95% CI | 95% CI | Reference standard: +
| Referral series | NR | NR | Se | 76.9% | 54.0% | 99.8% | Verification bias: -, only 99 women had histopathol of 377 women with adnexal masses at US
| Reference standard: | Risk factors (n [%]): | Additional data used for diagnosis: | Sp | 79.3% | 70.5% | 88.0% | Test reliability/variability: +
| Histopathology | NR | NR | PPV | 37.0% | 18.8% | 55.3% | Sample size: -
| Reference standard applied to all test negatives?: | Inclusion criteria: | | NPV | 95.6% | 90.7% | 100.0% | Statistical tests: +
| No | Women with diagnosis of mass referred for surgery | | 2) PI < 1, peri- and postmenopausal patients | | | | Blinding: +
| Test reliability established?: | Exclusion criteria: | | | Dis+ | Dis- | Tot | Definition of +/- on screening test: + for PI
| US - probably Sassone | Studies done not in first 10 days after menstruation in premenopausal women (to avoid luteal phase) | | T+ | 8 | 9 | 17
| PI yes | PI that couldn't be measured due to no flow (present in 7 masses) | | T- | 3 | 22 | 25
| Statistical tests used: | | | Tot | 11 | 31 | 42
| Se, Spec | | | | | Lower | Upper
| Blinding: | | | | Value | 95% CI | 95% CI
| Yes | | | Se | 72.7% | 46.4% | 99.0%
| Definition of positive and negative on screening test: | | | Sp | 71.0% | 55.0% | 86.9%
| Pulsatility index (PI) = (PSV-EDV)/mean velocity. Considered positive if < 1. | | | PPV | 47.1% | 23.3% | 70.8%
| | | | NPV | 88.0% | 75.3% | 100.0%
| | | | 3) PI < 1, premenopausal patients
| | | | | Dis+ | Dis- | Tot
| | | | T+ | 2 | 8 | 10
| | | | T- | 0 | 43 | 43
| | | | Tot | 2 | 51 | 53
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 100.0% | 0.0% | 100.0%
| | | | Sp | 84.3% | 74.3% | 94.3%
| | | | PPV | 20.0% | 0.0% | 44.8%
| | | | NPV | 100.0% | 93.0% | 100.0%
| | | | 4) PI < 1, age > 45 years
| | | | | Dis+ | Dis- | Tot
| | | | T+ | 8 | 3 | 11
| | | | T- | 9 | 22 | 31
| | | | Tot | 17 | 25 | 42
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 47.1% | 23.3% | 70.8%
| | | | Sp | 88.0% | 75.3% | 100.0%
| | | | PPV | 72.7% | 46.4% | 99.0%
| | | | NPV | 71.0% | 55.0% | 86.9%
Sassone, Timor-Tritsch, Artner, et al., 1991 | Geographical location: | Age: | Symptomatic (n [%]): | 1) Sassone ≥ 9 | | | | Comments:
#6780 | New York, NY | Mean: 41.6 | NR | | Dis+ | Dis- | Tot | —This is the original article describing the Sassone scoring system - good description of criteria with photos
| Dates: Jun 1987 - Dec 1989 | Median: 41 | Detected by exam (n [%]): | T+ | 13 | 22 | 35 | —Borderline tumors grouped in with benign
| Size of population: | Range: 20–85 | NR | T- | 0 | 108 | 108 | —No mention of clinical pathway of patients
| 143 women | Menopausal status (n [%]): | Detected by imaging (n [%]): | Tot | 13 | 130 | 143 | —TVUS only
| Retrospective case series | Pre (< 45): 116(80.4%) | NR | | | Lower | Upper | Quality assessment:
| Reference standard: | Post (> 55): 24(16.8%) | Combination (n [%]): | | Value | 95% CI | 95% CI | Reference standard: +
| Histopathology | 3 unknown secondary to hysterectomy (2.1%) | NR | Se | 100.0% | 76.9% | 100.0% | Verification bias: +
| Reference standard applied to all test negatives?: | Race/ethnicity (n [%]): | Additional data used for diagnosis: | Sp | 83.0% | 76.5% | 89.5% | Test reliability/variability: +/-
| Yes | NR | NR | PPV | 37.1% | 21.1% | 53.2% | Sample size: -
| Test reliability established?: | Risk factors (n [%]): | | NPV | 100.0% | 97.2% | 100.0% | Statistical tests: +
| No | NR | | | | | | Blinding: +
| Statistical tests used: | Inclusion criteria: | | | | | | Definition of +/- on screening test: +
| Se, Sp | All laparotomy performed for gynecologic indications in hospital in time frame
| Correlation coefficient for US and pathology | Exclusion criteria:
| Blinding: | Pregnancy
| Yes | Previous BSO
| Definition of positive and negative on screening test: | Previous treated carcinoma
| Sassone ≥ 9
Sawicki, Spiewan-kiewicz, Cendrowski, et al., 2001 | Geographical location: | Age: | Symptomatic (n [%]): | 1) TVUS, morphology only | | | | Comments:
#2450 | Warsaw, Poland | Range: 15–88 | NR | | Dis+ | Dis- | Tot | —Clinical presentation not described
| Dates: NR | Mean for patients with benign lesions: 42.6 (12.3) | Detected by exam (n [%]): | T+ | 64 | 83 | 147 | —Unclear how Doppler is being compared to morphology—independently or as adjunct
| Size of population: | Mean for patients with malignant lesions: 53.1 (12.6) | NR | T- | 10 | 172 | 182 | —Unclear what was included in “Doppler” measurement - RI, vascularization, and “a subjective semiquantitative assessment of the amount of blood flow (area and color scale)” within lesion
| 329 women | Menopausal status (n [%]): | Detected by imaging (n [%]): | Tot | 74 | 255 | 329 | Quality assessment:
| Other | NR | NR | | | Lower | Upper | Reference standard: +
| Case series | Race/ethnicity (n [%]): | Combination (n [%]): | | Value | 95% CI | 95% CI | Verification bias:+
| Reference standard: | NR | NR | Se | 86.5% | 78.7% | 94.3% | Test reliability/variability: -
| Surgery/pathology | Risk factors (n [%]): | Additional data used for diagnosis: | Sp | 67.5% | 61.8% | 73.2% | Sample size: - (formal statistical testing of differences in test characteristics, but no discussion of
| Reference standard applied to all test negatives?: | NR | Premenopausal US on day 7–8 | PPV | 43.6% | 35.6% | 51.6% | Statistical tests: - (basis of comparison not described)
| Yes | Inclusion criteria: | Stage I: 20/74 (27%) | NPV | 94.5% | 91.2% | 97.8% | Blinding:
| Test reliability established?: | NR | Stage II: 9/74 (12.2%) | 2) Color Doppler (unclear if test characteristics calculated based on Doppler alone, or Doppler plus morphology) | | | | Definition of +/- on screening test: - (resistive index threshold given, but not clear how other parameters used)
| Not referenced or discussed | Exclusion criteria: | Stage III: 42/74 (56.7%) | | Dis+ | Dis- | Tot
| Statistical tests used: | NR | Stage IV: 3/74 (4.1%) | T+ | 69 | 14 | 83
| Chi-square, Fishers's exact test, Mann-Whitney, t-test, Se/Sp | | | T- | 5 | 241 | 246
| Blinding: | | | Tot | 74 | 255 | 329
| Not described | | | | | Lower | Upper
| Definition of positive and negative on screening test: | | | | Value | 95% CI | 95% CI
| Gray-scale ultra sound: | | | Se | 93.2% | 87.5% | 98.9%
| (Sassone's criteria) | | | Sp | 94.5% | 91.7% | 97.3%
| - Solid or mixed solid/cystic; - Faded borders; - Septae > 3 mm; - Solid papillary projections into cyst cavity > 3 mm; - > 50 mm free fluid in cul de sac | | | PPV | 83.1% | 75.0% | 91.2%
| Color Doppler: | | | NPV | 98.0% | 96.2% | 99.7%
| RI < 0.5
| Other criteria included presence of “intense” angiogenesis within septae or solid parts of tumor, but unclear how this was used in determining benign vs malignant
Schelling, Braun, Kuhn, et al., 2000 | Geographical location: | Age: | Symptomatic (n [%]): | 1) Ultrasound (any solid component = positive), all patients | | | | Comments:
#2770 | Munich, Germany | NR | NR | | Dis+ | Dis- | Tot | —Clinical presentation not described
| Dates: NR | Menopausal status (n [%]): | Detected by exam (n [%]): | T+ | 38 | 42 | 80 | —Criteria for selecting cases not described
| Size of population: | Pre (< 45): 166 (64.6%) | NR | T- | 1 | 176 | 177 | —For model development - with N = 65 can you have 12 variables in predictive model and still be stable/valid? Too many variables for a predictive model (including also the Doppler variables(9 additional variables)?
| 63 in development set; 257 in validation set | Post (> 55): 91 (35.4%) | Detected by imaging (n [%]): | Tot | 39 | 218 | 257 | Quality assessment:
| Other | Race/ethnicity (n [%]): | NR | | | Lower | Upper | Reference standard: +
| Development and validation | NR | Combination (n [%]): | | Value | 95% CI | 95% CI | Verification bias:+
| Reference standard: | Risk factors (n [%]): | NR | Se | 97.4% | 92.5% | 100.0% | Test reliability/variability: -
| Surgery/pathology | NR | Additional data used for diagnosis: | Sp | 80.7% | 75.5% | 86.0% | Sample size: -
| Reference standard applied to all test negatives?: | Inclusion criteria: | NR | PPV | 47.5% | 36.6% | 58.4% | Statistical tests: +
| Yes | NR | | NPV | 99.4% | 98.3% | 100.0% | Blinding: +
| Test reliability established?: | Exclusion criteria: | | 2) Ultrasound, any solid component, premenopausal | | | | Definition of +/- on screening test: +
| Discussed | History of malignancy | | | Dis+ | Dis- | Tot
| Statistical tests used: | | | T+ | 10 | 25 | 35
| Logistic regression for development; Se/Sp for validation | | | T- | 1 | 130 | 131
| Blinding: | | | Tot | 11 | 155 | 166
| Yes | | | | | Lower | Upper
| Definition of positive and negative on screening test: | | | | Value | 95% CI | 95% CI
| Solid component on morphology, presence of central vascularization on Doppler | | | Se | 90.9% | 73.9% | 100.0%
| | | | Sp | 83.9% | 78.1% | 89.7%
| | | | PPV | 28.6% | 13.6% | 43.5%
| | | | NPV | 99.2% | 97.7% | 100.0%
| | | | 3) Utrasound, any solid component, postmenopausal
| | | | | Dis+ | Dis- | Tot
| | | | T+ | 28 | 17 | 45
| | | | T- | 0 | 46 | 46
| | | | Tot | 28 | 63 | 91
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 100.0% | 89.3% | 100.0%
| | | | Sp | 73.0% | 62.1% | 84.0%
| | | | PPV | 62.2% | 48.1% | 76.4%
| | | | NPV | 100.0% | 93.5% | 100.0%
| | | | 4) Central vascularity on Doppler in solid component, all patients
| | | | | Dis+ | Dis- | Tot
| | | | T+ | 36 | 14 | 50
| | | | T- | 3 | 204 | 207
| | | | Tot | 39 | 218 | 257
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 92.3% | 83.9% | 100.0%
| | | | Sp | 93.6% | 90.3% | 96.8%
| | | | PPV | 72.0% | 59.6% | 84.4%
| | | | NPV | 98.6% | 96.9% | 100.0%
| | | | 5) Central vascularity on Doppler in solid component, premenopausal
| | | | | Dis+ | Dis- | Tot
| | | | T+ | 10 | 9 | 19
| | | | T- | 1 | 146 | 147
| | | | Tot | 11 | 155 | 166
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 90.9% | 73.9% | 100.0%
| | | | Sp | 94.2% | 90.5% | 97.9%
| | | | PPV | 52.6% | 30.2% | 75.1%
| | | | NPV | 99.3% | 98.0% | 100.0%
| | | | 6) Central vascularity on Doppler in solid component, postmenopausal
| | | | | Dis+ | Dis- | Tot
| | | | T+ | 26 | 5 | 31
| | | | T- | 2 | 58 | 60
| | | | Tot | 28 | 63 | 91
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 92.9% | 83.3% | 100.0%
| | | | Sp | 92.1% | 85.4% | 98.7%
| | | | PPV | 83.9% | 70.9% | 96.8%
| | | | NPV | 96.7% | 92.1% | 100.0%
Schneider, Schneider, Reed, et al., 1993 | Geographical location: | Age: | Symptomatic (n [%]): | 1) RI ≤ 0.8 | | | | Comments:
#4830 | Arizona, USA | Mean: 53 | NR | | Dis+ | Dis- | Tot | —RI cutoff calculated from this data (not prospective)
| Academic Center | Median: 53 | Detected by exam (n [%]): | T+ | 15 | 17 | 32 | —RI ≤ 0.8 not uniform in literature (1.0)
| Dates: NR | Range: 10–79 | NR | T- | 1 | 22 | 23 | Quality assessment:
| Size of population: | Menopausal status (n [%]): | Detected by imaging (n [%]): | Tot | 16 | 39 | 55 | Reference standard: +
| 55 women | Pre: 22 (40%) | All patients had ultrasound finding of adnexal mass | | | Lower | Upper | Verification bias: +
| Other | Post: 33 (60%) | Combination (n [%]): | | Value | 95% CI | 95% CI | Test reliability/variability:
| “Cross-sectional” referral | Race/ethnicity (n [%]): | NR | Se | 93.8% | 81.9% | 100.0% | + for CA-125 and Sasonne
| Reference standard: | NR | Additional data used for diagnosis: | Sp | 56.4% | 40.8% | 72.0% | ? for other US
| Histopathology | Risk factors (n [%]): | NR | PPV | 46.9% | 29.6% | 64.2% | Sample size: -
| Reference standard applied to all test negatives?: | NR | | NPV | 95.7% | 87.3% | 100.0% | Statistical tests: +
| Yes | Inclusion criteria: | | 2) Granberg et al method US | | | | Blinding: +
| Test reliability established?: | Women referred to OB/Gyn department with diagnosis of mass and scheduled for surgery already | | | Dis+ | Dis- | Tot | Definition of +/- on screening test: +/-
| Yes Sasonne | Exclusion criteria: | | T+ | 14 | 6 | 20
| ? Granberg | NR | | T- | 2 | 33 | 35
| RI - yes | | | Tot | 16 | 39 | 55
| Statistical tests used: | | | | | Lower | Upper
| Se, Sp | | | | Value | 95% CI | 95% CI
| Blinding: | | | Se | 87.5% | 71.3% | 100.0%
| Yes | | | Sp | 84.6% | 73.3% | 95.9%
| Definition of positive and negative on screening test: | | | PPV | 70.0% | 49.9% | 90.1%
| Sasonne's score | | | NPV | 94.3% | 86.6% | 100.0%
| Granberg [5] method of 2D US | | | 3) Sasonne (cut off 9)
| RI ≤ 0.8 | | | | Dis+ | Dis- | Tot
| CA-125 > 35 U/ml | | | T+ | 14 | 10 | 24
| | | | T- | 2 | 29 | 31
| | | | Tot | 16 | 39 | 55
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 87.5% | 71.3% | 100.0%
| | | | Sp | 74.4% | 60.7% | 88.1%
| | | | PPV | 58.3% | 38.6% | 78.1%
| | | | NPV | 93.5% | 84.9% | 100.0%
| | | | 4) CA-125 > 35 U/ml
| | | | | Dis+ | Dis- | Tot
| | | | T+ | 12 | 6 | 18
| | | | T- | 4 | 33 | 37
| | | | Tot | 16 | 39 | 55
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 75.0% | 53.8% | 96.2%
| | | | Sp | 84.6% | 73.3% | 95.9%
| | | | PPV | 66.7% | 44.9% | 88.4%
| | | | NPV | 89.2% | 79.2% | 99.2%
Schutter, Davelaar, van Kamp, et al., 2002 | Geographical location: | Age: | Symptomatic (n [%]): | 1) CA-125, ovarian cancer vs benign ovarian mass, threshold = 35 u/mL | | | | Comments:
#2160 | Amsterdam and Enschede, The Netherlands | NR | NR | | Dis+ | Dis- | Tot | —Clinical presentation not described
| Dates: Nov 1990-Dec 1992 | Menopausal status (n [%]): | Detected by exam (n [%]): | T+ | 108 | 35 | 143 | Quality assessment:
| Size of population: | NR | NR | T- | 25 | 94 | 119 | Reference standard: +
| 511; serum available for 412 | Race/ethnicity (n [%]): | Detected by imaging (n [%]): | Tot | 133 | 129 | 262 | Verification bias: +
| Other | NR | NR | | | Lower | Upper | Test reliability/variability: +
| Serum bank | Risk factors (n [%]): | Combination (n [%]): | | Value | 95% CI | 95% CI | Sample size: -
| Reference standard: | NR | NR | Se | 81.0% | 74.3% | 87.7% | Statistical tests:
| Surgery/pathology | Inclusion criteria: | Additional data used for diagnosis: | Sp | 73.0% | 65.3% | 80.7% | Blinding: +
| Reference standard applied to all test negatives?: | NR | NR | PPV | 75.6% | 68.5% | 82.6% | Definition of +/- on screening test: +
| Yes | Exclusion criteria: | | NPV | 78.8% | 71.5% | 86.2%
| Test reliability established?: | NR | | 2) CA-125, ovarian cancer vs benign ovarian mass, threshold = 57 u/mL
| Yes | | | | Dis+ | Dis- | Tot
| Statistical tests used: | | | T+ | 102 | 23 | 126
| Se/Sp; logistic regression | | | T- | 31 | 106 | 136
| Blinding: | | | Tot | 133 | 129 | 262
| Yes | | | | | Lower | Upper
| Definition of positive and negative on screening test: | | | | Value | 95% CI | 95% CI
| Varied; “optimal” cutpoints | | | Se | 77.0% | 69.8% | 84.2%
| CA-125: 57 u/mL | | | Sp | 82.0% | 75.4% | 88.6%
| CA-15-3: 26 u/mL | | | PPV | 81.5% | 74.7% | 88.3%
| CA-724: 3. 5 u/mL | | | NPV | 77.6% | 70.6% | 84.6%
| | | | 3) CA-15-3, ovarian cancer vs benign mass, threshold = 26 u/mL
| | | | | Dis+ | Dis- | Tot
| | | | T+ | 82 | 9 | 91
| | | | T- | 51 | 120 | 171
| | | | Tot | 133 | 129 | 262
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 62.0% | 53.8% | 70.2%
| | | | Sp | 93.0% | 88.6% | 97.4%
| | | | PPV | 90.1% | 84.0% | 96.2%
| | | | NPV | 70.4% | 63.5% | 77.2%
| | | | 4) CA-724, Ovarian cancer vs benign ovarian mass, threshold = 3.5 u/mL
| | | | | Dis+ | Dis- | Tot
| | | | T+ | 84 | 18 | 102
| | | | T- | 49 | 111 | 160
| | | | Tot | 133 | 129 | 262
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 63.0% | 54.8% | 71.2%
| | | | Sp | 86.0% | 80.0% | 92.0%
| | | | PPV | 82.3% | 74.9% | 89.7%
| | | | NPV | 69.3% | 62.1% | 76.4%
| | | | 5) CA-125, all malignancy vs all benign, threshold = 35 u/mL
| | | | | Dis+ | Dis- | Tot
| | | | T+ | 136 | 41 | 177
| | | | T- | 90 | 130 | 220
| | | | Tot | 226 | 171 | 397
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 60.0% | 53.6% | 66.4%
| | | | Sp | 76.0% | 69.6% | 82.4%
| | | | PPV | 76.8% | 70.5% | 83.0%
| | | | NPV | 59.0% | 52.5% | 65.5%
| | | | 6) CA-125, all malignancy vs all benign, threshold = 57 u/mL
| | | | | Dis+ | Dis | Tot
| | | | T+ | 118 | 27 | 145
| | | | T- | 108 | 144 | 252
| | | | Tot | 226 | 171 | 397
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 52.0% | 45.5% | 58.5%
| | | | Sp | 84.0% | 78.5% | 89.5%
| | | | PPV | 81.1% | 74.7% | 87.5%
| | | | NPV | 57.0% | 50.9% | 63.1%
| | | | 7) CA 15-3, all malignancy vs all benign, threshold = 26 u/mL
| | | | | Dis+ | Dis- | Tot
| | | | T+ | 106 | 15 | 122
| | | | T- | 120 | 156 | 275
| | | | Tot | 226 | 171 | 397
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 47.0% | 40.5% | 53.5%
| | | | Sp | 91.0% | 86.7% | 95.3%
| | | | PPV | 87.3% | 81.4% | 93.3%
| | | | NPV | 56.5% | 50.7% | 62.4%
| | | | 8) CA-724, all malignancy vs all benign, threshold = 3.5 U/mL
| | | | | Dis+ | Dis- | Tot
| | | | T+ | 118 | 27 | 145
| | | | T- | 108 | 144 | 252
| | | | Tot | 226 | 171 | 397
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 52.0% | 45.5% | 58.5%
| | | | Sp | 84.0% | 78.5% | 89.5%
| | | | PPV | 81.1% | 74.7% | 87.5%
| | | | NPV | 57.0% | 50.9% | 63.1%
Schutter, Kenemans, Sohn, et al., 1994 | Geographical location: | Age: | Symptomatic (n [%]): | Borderline tumors (n = 6) not included | | | | Comments:
#940 | Amsterdam, The Netherlands; and Heidelberg, Koln, Wurzburg, and Ulm, Germany | Mean: 63 | NR | 1) CA-125 > 35 U/ml | | | | —Clinical presentation not described (symptoms vs. no symptoms)
| Dates: Nov 1990-Dec 1992 | Range: 45–88 | Detected by exam (n [%]): | | Dis+ | Dis- | Tot | Quality assessment:
| Size of population: | Menopausal status (n [%]): | 199 (87.3%) | T+ | 68 | 25 | 93 | Reference standard: +
| 276; 48 excluded (13 45 years old or less, 16 not amenorrheic for 12 months, 4 no path dx, 14 additional malignancy, 10 indeterminate pelvic exam, 3 no preop CA-125), for total of 228 | 100% postmenopausal | Detected by imaging (n [%]): | T- | 27 | 102 | 129 | Verification bias: +
| Other | Race/ethnicity (n [%]): | 28 (12.7%) | Tot | 95 | 127 | 222 | Test reliability/variability: -
| Multicenter, prospective, patients referred for pelvic mass | NR | Combination (n [%]): | | | Lower | Upper | Sample size: + (95% CI's given)
| Reference standard: | Risk factors (n [%]): | NR | | Value | 95% CI | 95% CI | Statistical tests: +
| Surgery/pathology | NR | Additional data used for diagnosis: | Se | 71.6% | 62.5% | 80.6% | Blinding: -
| Reference standard applied to all test negatives?: | Inclusion criteria: | Stage distribution: | Sp | 80.3% | 73.4% | 87.2% | Definition of +/- on screening test: +
| Yes | 45 years old | I: 16/72 (22.2%) | PPV | 73.1% | 64.1% | 82.1%
| Test reliability established?: | Amenorrheic > 12 months | II: 7/72 (9.7%) | NPV | 79.1% | 72.0% | 86.1%
| Not referenced or discussed | Schedule for surgery with tissue diagnosis | III: 34/72 (47.2%) | 2) Ultrasound: Finkler score > 7 (as described)
| Statistical tests used: | No history of bilateral oophorectomy or additional cancer | IV: 15/72 (20.8%) | | Dis+ | Dis- | Tot
| Se/Sp; logistic regression | Exclusion criteria: | | T+ | 84 | 46 | 130
| Blinding: | NR | | T- | 11 | 81 | 92
| No | | | Tot | 95 | 127 | 222
| Definition of positive and negative on screening test: | | | | | Lower | Upper
| Ultrasound: Positive if multiseptated or irregular cystic mass “consistent in appearance with ovarian tumor; or presence of ascites | | | | Value | 95% CI | 95% CI
| CA-125: > 35 U/mL | | | Se | 88.4% | 82.0% | 94.9%
| | | | Sp | 63.8% | 55.4% | 72.1%
| | | | PPV | 64.6% | 56.4% | 72.8%
| | | | NPV | 88.0% | 81.4% | 94.7%
Schutter, Sohn, Kristen, et al., 1998 | Geographical location: | Age: | Symptomatic (n [%]): | 1) PE | | | | Comments:
#730 | Germany | Mean: 63 | NR | | Dis+ | Dis- | Tot | —Borderline tumors (n = 4) omitted from 2×2 tables by authors
| Dates: NR | Median: 61 | Detected by exam (n [%]): | T+ | 54 | 24 | 78 | —Note “semi-quantitative parameters” of Finkler scoring system
| Size of population: | Range: 45–88 | NR | T- | 5 | 68 | 73 | —Finkler scoring system? variable
| 155 women | Menopausal status (n [%]): | Detected by imaging (n [%]): | Tot | 59 | 92 | 151 | Quality assessment:
| Other | Post (> 55): 155 (100%) | NR | | | Lower | Upper | Reference standard: +
| Unclear | Race/ethnicity (n [%]): | Combination (n [%]): | | Value | 95% CI | 95% CI | Verification bias: - unclear how many negatives didn't have surgery
| Reference standard: | NR (assume 100% white) | NR | Se | 91.5% | 84.4% | 98.6% | Test reliability/variability: + for PE, U/S, CA-125
| Histology | Risk factors (n [%]): | Additional data used for diagnosis: | Sp | 73.9% | 64.9% | 82.9% | Sample size: -
| Reference standard applied to all test negatives?: | NR | NR | PPV | 69.2% | 59.0% | 79.5% | Statistical tests: +
| Yes | Inclusion criteria: | | NPV | 93.2% | 87.4% | 98.9% | Blinding: -
| Test reliability established?: | NR (see citation 25) | | 2) US | | | | Definition of +/- on screening test: +
| For pelvic exam - No | Exclusion criteria: | | | Dis+ | Dis- | Tot
| CA-125 - Yes | NR | | T+ | 51 | 28 | 79
| CA-72-4 - ? (mostly in gastric CA) they set own cutoff point here | | | T- | 8 | 64 | 72
| US - Yes | | | Tot | 59 | 92 | 151
| Statistical tests used: | | | | | Lower | Upper
| Chi-square | | | | Value | 95% CI | 95% CI
| ROC | | | Se | 86.4% | 77.7% | 95.2%
| Logistic regression | | | Sp | 69.6% | 60.2% | 79.0%
| Blinding: | | | PPV | 64.6% | 54.0% | 75.1%
| No | | | NPV | 88.9% | 81.6% | 96.1%
| Definition of positive and negative on screening test: | | | 3) CA-125 ≥ 35 U/ml
| Table 1 | | | | Dis+ | Dis- | Tot
| Exam - clinical impression of malignancy | | | T+ | 41 | 15 | 56
| US - Finkler Score 7–10 | | | T- | 18 | 77 | 95
| CA-125 - ≥ 35 U/ml | | | Tot | 59 | 92 | 151
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 69.5% | 57.7% | 81.2%
| | | | Sp | 83.7% | 76.1% | 91.2%
| | | | PPV | 73.2% | 61.6% | 84.8%
| | | | NPV | 81.1% | 73.2% | 88.9%
Scoutt, McCarthy, Lange, et al., 1994 | Geographical location: | Age: | Symptomatic (n [%]): | 1) Data provided for mass, not patient MRI, malignant vs. benign; threshold for positive MR = indeterminate or malignant | | | | Comments:
#4530 | New Haven, CT | Median: 40 | NR | | Dis+ | Dis- | Tot | —Clinical presentation not described
| Dates: 1988-1990 | Range: 2–87 | Detected by exam (n [%]): | T+ | 21 | 11 | 32 | —Length of followup not described
| Size of population: | Menopausal status (n [%]): | NR | T- | 1 | 87 | 88 | Quality assessment:
| 103 patients with 121 masses; data provided on 120 | NR | Detected by imaging (n [%]): | Tot | 22 | 98 | 120 | Reference standard: -
| Other | Race/ethnicity (n [%]): | NR | | | Lower | Upper | Verification bias: -
| Case series | NR | Combination (n [%]): | | Value | 95% CI | 95% CI | Test reliability/variability: -
| Reference standard: | Risk factors (n [%]): | NR | Se | 95.5% | 86.8% | 100.0% | Sample size: -
| Surgery | NR | Additional data used for diagnosis: | Sp | 88.8% | 82.5% | 95.0% | Statistical tests: +
| Reference standard applied to all test negatives?: | Inclusion criteria: | NR | PPV | 65.6% | 49.2% | 82.1% | Blinding: +
| No; 11 with “classic” leiomyomas, 2 with "no mass' | NR | | NPV | 98.9% | 96.6% | 100.0% | Definition of +/- on screening test: +
| Test reliability established?: | Exclusion criteria:
| Not referenced or discussed | NR
| Statistical tests used:
| Se/Sp
| Blinding:
| Yes
| Definition of positive and negative on screening test:
| Malignancy: solid or highly complex, mural nodules, septations > 3 mm, ascites.
| Indeterminate if not definitely benign or malignant
Sengoku, Satoh, Saitoh, et al., 1994 | Geographical location: | Age: | Symptomatic (n [%]): | 1) CA-125 > 35 U/ml, benign vs malignant | | | | Comments:
#4390 | Asahikawa, Japan | Mean (SD): 49 (15) | NR | | Dis+ | Dis- | Tot | —Clinical presentation not described
| Dates: Apr 1991-May 1992 | Range: 19–80 | Detected by exam (n [%]): | T+ | 13 | 3 | 16 | —Small numbers
| Size of population: | Menopausal status (n [%]): | NR | T- | 3 | 9 | 12 | —No description of where PI < 1.5 comes from
| 28 women | Pre (< 45): 17 (60.7%) | Detected by imaging (n [%]): | Tot | 16 | 12 | 28 | Quality assessment:
| Other | Post (> 55): 11 (39.3%) | NR | | | Lower | Upper | Reference standard: +
| Case series | Race/ethnicity (n [%]): | Combination (n [%]): | | Value | 95% CI | 95% CI | Verification bias: +
| Reference standard: | NR | NR | Se | 81.3% | 62.1% | 100.0% | Test reliability/variability: +
| Surgery/pathology | Risk factors (n [%]): | Additional data used for diagnosis: | Sp | 75.0% | 50.5% | 99.5% | Sample size: -
| Reference standard applied to all test negatives?: | NR | NR | PPV | 81.3% | 62.1% | 100.0% | Statistical tests: +
| Yes | Inclusion criteria: | | NPV | 75.0% | 50.5% | 99.5% | Blinding: -
| Test reliability established?: | NR | | 2) Ultrasound morphology | | | | Definition of +/- on screening test: +
| Discussed | Exclusion criteria: | | | Dis+ | Dis- | Tot
| Statistical tests used: | NR | | T+ | 13 | 4 | 17
| Se/Sp, t-test | | | T- | 3 | 8 | 11
| Blinding: | | | Tot | 16 | 12 | 28
| No | | | | | Lower | Upper
| Definition of positive and negative on screening test: | | | | Value | 95% CI | 95% CI
| Ultrsound morphology | | | Se | 81.3% | 62.1% | 100.0%
| Sassone system (referenced, not described) | | | Sp | 66.7% | 40.0% | 93.3%
| Pulsatility index: < 1.5 | | | PPV | 76.5% | 56.3% | 96.6%
| CA-125> > 35 | | | NPV | 72.7% | 46.4% | 99.0%
| | | | 3) Pulsatility index < 1.5
| | | | | Dis+ | Dis- | Tot
| | | | T+ | 13 | 1 | 14
| | | | T- | 3 | 11 | 14
| | | | Tot | 16 | 12 | 28
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 81.3% | 62.1% | 100.0%
| | | | Sp | 91.7% | 76.0% | 100.0%
| | | | PPV | 92.9% | 79.4% | 100.0%
| | | | NPV | 78.6% | 57.1% | 100.0%
Shabana and Onsrud, 1994 | Geographical location: | Age: | Symptomatic (n [%]): | 1) CA-125 > 25 U/ml | | | | Comments:
#4400 | Trondheim, Norway | NR | NR | | Dis+ | Dis- | Tot | —Not prospective data
| Dates: NR | Menopausal status (n [%]): | Detected by exam (n [%]): | T+ | 26 | 2 | 28 | —Only 26 with benign pelvic masses included in analysis - no discussion of this in text.
| Size of population: | NR | NR | T- | 4 | 24 | 28 | —CA-125 cutoff - 25 - not discussed in text
| 85 women | Race/ethnicity (n [%]): | Detected by imaging (n [%]): | Tot | 30 | 26 | 56 | —Unclear how the three groups chosen
| Other - Case control | NR | NR | | | Lower | Upper | Quality assessment:
| Three groups compared in terms of serum markers:33 with ovarian Ca, 26 with benign pelvic masses, and 26 with normal pelvis | Risk factors (n [%]): | Combination (n [%]): | | Value | 95% CI | 95% CI | Reference standard: +
| Reference standard: | NR | NR | Se | 86.7% | 74.5% | 98.8% | Verification bias: +
| Histopathology for all but those with “normal pelvis” which was assessed at laparoscopy | Inclusion criteria: | Additional data used for diagnosis: | Sp | 92.3% | 82.1% | 100.0% | Test reliability/variability: +
| Reference standard applied to all test negatives?: | NR | NR | PPV | 92.9% | 83.3% | 100.0% | Sample size: -
| Yes | Exclusion criteria: | | NPV | 85.7% | 72.8% | 98.7% | Statistical tests: +
| Test reliability established?: | NR | | | | | | Blinding: -
| Yes for CA-125 | | | | | | | Definition of +/- on screening test: -
| Statistical tests used:
| Se, Sp, ROC
| Blinding:
| NR
| Definition of positive and negative on screening test:
| CA-125 > 25 U/ml
Siegel, Dehdashti, Mutch, et al., 2003 | Geographical location: | Age: | Symptomatic (n [%]): | 1) Results provided only for newly diagnosed pelvic masses (n = 26) | | | | Comments:
#1960 | St Louis, MO; Houston, TX; Indianapolis, IN; | Mean: 55 | NR | Borderline excluded (faint uptake by 1 reader, none by other) | | | | —Clinical presentation not described
| Dates: NR | Range: 31–78 | Detected by exam (n [%]): | | Dis+ | Dis- | Tot | —Not a commonly used test modality
| Size of population: | Menopausal status (n [%]): | NR | T+ | 7 | 4 | 11 | Quality assessment:
| 35; 2 did not undergo surgery | NR | Detected by imaging (n [%]): | T- | 0 | 14 | 14 | Reference standard: +
| Other | Race/ethnicity (n [%]): | NR | Tot | 7 | 18 | 25 | Verification bias: +
| Validation | NR | Combination (n [%]): | | | Lower | Upper | Test reliability/variability: +
| Reference standard: | Risk factors (n [%]): | NR | | Value | 95% CI | 95% CI | Sample size: -
| Surgery | NR | Additional data used for diagnosis: | Se | 100.0% | 57.1% | 100.0% | Statistical tests: +
| Reference standard applied to all test negatives?: | Inclusion criteria: | NR | Sp | 77.8% | 58.6% | 97.0% | Blinding: +
| Yes | NR | | PPV | 63.6% | 35.2% | 92.1% | Definition of +/- on screening test: +
| Test reliability established?: | Exclusion criteria: | | NPV | 100.0% | 78.6% | 100.0%
| Yes | NR | | NPV | 100.0% | 78.6% | 100.0%
| Statistical tests used: | | | Specificity increased to 82% when re-read with clinical information available
| Se/Sp
| Blinding:
| Yes
| Definition of positive and negative on screening test:
| “Focal increased uptake of radiotracer at sites not corresponding to obvious normal anatomic structures”
Smikle, Lunt, and Hankins, 1995 | Geographical location: | Age: | Symptomatic (n [%]): | 1)CA-125 >= 35 U/ml in postmenopausal women (age >50) | | | | Comments:
#6290 | USA | Those with benign lesions: mean age - 45 (14.7) | NR | | Dis+ | 5 | Tot | —Borderline tumors grouped in with malignant
| Dates: Jun 1990 - Aug 1992 | Those with malignant lesions: mean - 56.9 (13.9) | Detected by exam (n [%]): | T+ | 11 | 26 | 37 | —Of 195 charts identified, only 100 had CA-125 levels for analysis
| Size of population: | Menopausal status (n [%]): | NR | T- | 2 | 32 | 34 | —State that platelet count failed to distinguish benign from malignant, however, data not reported such that could be included in meta-analysis
| 195 | Not clear for those for whom CA-125 was available (n = 100) 50 were > 50 years old and 50 were <=50 | Detected by imaging (n [%]): | Tot | 13 | 58 | 71 | —Not recorded whether TVUS or abdominal US done
| Retrosceptive case series | Race/ethnicity (n [%]): | NR | | | Lower | Upper | Quality assessment:
| Reference standard: | NR | Combination (n [%]): | | Value | 95% CI | 95% CI | Reference standard: +
| Histopathology | Risk factors (n [%]): | NR | Se | 84.6% | 65.0% | 100.0% | Verification bias: +
| Reference standard applied to all test negatives?: | NR | Additional data used for diagnosis: | Sp | 55.2% | 42.4% | 68.0% | Test reliability/variability: -
| Yes | Inclusion criteria: | NR | PPV | 29.7% | 15.0% | 44.5% | Sample size: -
| Test reliability established?: | Chart review of all cases with operative reports of “rule-out malignancy” “pelvic mass” “adnexal mass” in time frame | | NPV | 94.1% | 86.2% | 100.0% | Statistical tests: +
| Yes | Exclusion criteria: | | 2) CA-125 in women <= 50 | | | | Blinding: +/-
| Statistical tests used: | NR | | | Dis+ | 5 | Tot | Definition of +/- on screening test: +
| Fisher exact test | | | T+ | 2 | 12 | 14
| Blinding: | | | T- | 0 | 36 | 36
| NR | | | Tot | 2 | 48 | 50
| Definition of positive and negative on screening test: | | | | | Lower | Upper
| CA-125 >= 35 U/ml | | | | Value | 95% CI | 95% CI
| | | | Se | 100.0% | -50.0% | 100.0%
| | | | Sp | 75.0% | 62.8% | 87.3%
| | | | PPV | 14.3% | 0.0% | 32.6%
| | | | NPV | 100.0% | 91.7% | 100.0%
| | | | 3) CA-125 for all women combined
| | | | | Dis+ | 5 | Tot
| | | | T+ | 13 | 17 | 30
| | | | T- | 2 | 68 | 70
| | | | Tot | 15 | 85 | 100
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 86.7% | 69.5% | 100.0%
| | | | Sp | 80.0% | 71.5% | 88.5%
| | | | PPV | 43.3% | 25.6% | 61.1%
| | | | NPV | 97.1% | 93.2% | 100.0%
Sohaib, Mills, Sahdev, et al., 2005 | Geographical location: | Age: | Symptomatic (n [%]): | 1) US | | | | Comments:
#7430 | UK | Mean: 53 | NR | | Dis+ | Dis- | Tot | —Borderline tumors grouped in with malignant
| Dates: NR | Range: 19–86 | Detected by exam (n [%]): | T+ | 29 | 26 | 55 | —Se, Sp reported for CA-125, however, no mention of what cutpoint used was in article, and not enough raw data for extraction - authors do state, however, that that MRI performed better than US in cases with normal levels of CA-125.
| Size of population: | Menopausal status (n [%]): | NR | T- | 0 | 17 | 17 | - TVUS done in 65/72 cases - unable to stratify results
| 89, however only data for 72 | NR | Detected by imaging (n [%]): | Tot | 29 | 43 | 72 | Quality assessment:
| Prospective case series | Race/ethnicity (n [%]): | NR | | | Lower | Upper | Reference standard: +
| Reference standard: | NR | Combination (n [%]): | | Value | 95% CI | 95% CI | Verification bias: +
| Histopathology | Risk factors (n [%]): | NR | Se | 100.0% | 89.7% | 100.0% | Test reliability/variability: +
| Reference standard applied to all test negatives?: | NR | Additional data used for diagnosis: | Sp | 39.5% | 24.9% | 54.1% | Sample size: -
| Yes | Inclusion criteria: | NR | PPV | 52.7% | 39.5% | 65.9% | Statistical tests: +
| Test reliability established?: | Referral to hospital for adnexal mass in time frame | | NPV | 100.0% | 82.4% | 100.0% | Blinding: +
| Yes | Exclusion criteria: | | 2) MRI | | | | Definition of +/- on screening test: +
| Statistical tests used: | NR | | | Dis+ | Dis- | Tot
| ROC curves | | | T+ | 28 | 7 | 35
| Student's t-test | | | T- | 1 | 36 | 37
| Mann-Whitney U test | | | Tot | 29 | 43 | 72
| Chi square | | | | | Lower | Upper
| Blinding: | | | | Value | 95% CI | 95% CI
| Yes | | | Se | 96.6% | 90.0% | 100.0%
| Definition of positive and negative on screening test: | | | Sp | 83.7% | 72.7% | 94.7%
| US - morphology and RI and PI were noted and a “subjective assessment was made as to whether each mass was benign or malignant” and then assigned to groups: 1) benign, 2) probably benign, 3) possibly malignant, 4) probably malignant, 5) malignant | | | PPV | 80.0% | 66.7% | 93.3%
| For Se and Sp calcs, groups 1 and 2 were evaluated together as were 3, 4, 5. | | | NPV | 97.3% | 92.1% | 100.0%
| MRI - classified into malignant or benign by radiologist “impression” and into same 5 categories.
Soper, Hunter, Daly, et al., 1990 | Geographical location: | Age: | Symptomatic (n [%]): | 1) CA-125—All malignancies, > 35 U/mL as threshold | | | | Comments:
#6590 | Durham, NC | NR | NR | | Dis+ | Dis- | Tot | —Unclear if this represents all patients with adnexal mass
| Dates: Jan 1985-Jan 1986 | Menopausal status (n [%]): | Detected by exam (n [%]): | T+ | 38 | 14 | 52 | —Clinical presentation not described
| Size of population: | NR | NR | T- | 16 | 32 | 48 | —Borderline tumors included with malignant
| 100 women | Race/ethnicity (n [%]): | Detected by imaging (n [%]): | Tot | 54 | 46 | 100 | Quality assessment:
| Other | NR | NR | | | Lower | Upper | Reference standard: +
| Single center | Risk factors (n [%]): | Combination (n [%]): | | Value | 95% CI | 95% CI | Verification bias: +
| Prospective series | NR | NR | Se | 70.4% | 58.2% | 82.5% | Test reliability/variability: +
| Reference standard: | Inclusion criteria: | Additional data used for diagnosis: | Sp | 69.6% | 56.3% | 82.9% | Sample size: -
| Pathology | “Diagnostic laparotomy for pelvic mass” | NR | PPV | 73.1% | 61.0% | 85.1% | Statistical tests: -
| Reference standard applied to all test negatives?: | Exclusion criteria: | | NPV | 66.7% | 53.3% | 80.0% | Blinding: -
| Yes | NR | | 2) CA-125—ovarian cancer, > 35 U/mL as threshold | | | | Definition of +/- on screening test: N/AS
| Test reliability established?: | | | | Dis+ | Dis- | Tot
| Yes (reference) | | | T+ | 38 | 22 | 60
| Statistical tests used: | | | T- | 4 | 36 | 40
| NR | | | Tot | 42 | 58 | 100
| Blinding: | | | | | Lower | Upper
| Assays done after surgery | | | | Value | 95% CI | 95% CI
| Definition of positive and negative on screening test: | | | Se | 90.5% | 81.6% | 99.4%
| | | | Sp | 62.1% | 49.6% | 74.6%
| | | | PPV | 63.3% | 51.1% | 75.5%
| | | | NPV | 90.0% | 80.7% | 99.3%
| | | | 3) CA-125—All malignancies, > 65 U/ml as threshold
| | | | | Dis+ | Dis- | Tot
| | | | T+ | 42 | 8 | 50
| | | | T- | 12 | 38 | 50
| | | | Tot | 54 | 46 | 100
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 77.8% | 66.7% | 88.9%
| | | | Sp | 82.6% | 71.7% | 93.6%
| | | | PPV | 84.0% | 73.8% | 94.2%
| | | | NPV | 76.0% | 64.2% | 87.8%
| | | | 4) CA-125—-Ovarian cancer, > 65 U/ml as threshold
| | | | | Dis+ | Dis- | Tot
| | | | T+ | 35 | 15 | 50
| | | | T- | 7 | 43 | 50
| | | | Tot | 42 | 58 | 100
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 83.3% | 72.1% | 94.6%
| | | | Sp | 74.1% | 62.9% | 85.4%
| | | | PPV | 70.0% | 57.3% | 82.7%
| | | | NPV | 86.0% | 76.4% | 95.6%
| | | | 5) TAG-72—-Ovarian cancer
| | | | | Dis+ | Dis- | Tot
| | | | T+ | 21 | 4 | 25
| | | | T- | 21 | 54 | 75
| | | | Tot | 42 | 58 | 100
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 50.0% | 34.9% | 65.1%
| | | | Sp | 93.1% | 86.6% | 99.6%
| | | | PPV | 84.0% | 69.6% | 98.4%
| | | | NPV | 72.0% | 61.8% | 82.2%
| | | | 6) CA-15-3—Ovarian cancer
| | | | | Dis+ | Dis- | Tot
| | | | T+ | 23 | 11 | 34
| | | | T- | 19 | 47 | 66
| | | | Tot | 42 | 58 | 100
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 54.8% | 39.7% | 69.8%
| | | | Sp | 81.0% | 70.9% | 91.1%
| | | | PPV | 67.6% | 51.9% | 83.4%
| | | | NPV | 71.2% | 60.3% | 82.1%
| | | | Results not reported separately, but CA-125 > 65 sensitivity of 79%, specificity of 86% in patients > 50.
Stein, Laifer-Narin, Johnson, et al., 1995 | Geographical location: | Age: | Symptomatic (n [%]): | 1) Ultrasound morphology (transvaginal in all but 23) | | | | Comments:
#4280 | Los Angeles, CA | NR | NR | | Dis+ | Dis- | Tot | —Denominator should include those excluded because of findings
| Dates: Jul 1992-Feb 1993 | Menopausal status (n [%]): | Detected by exam (n [%]): | T+ | 46 | 47 | 93 | —Results not presented by menopausal status
| Size of population: | Pre (< 45):114 (70.8%) | NR | T- | 1 | 76 | 77 | —Analysis, 2×2 tables done for masses not patients
| 161 patients, 170 masses | Post (> 55): 39 (24.2%) | Detected by imaging (n [%]): | Tot | 47 | 123 | 170 | Quality assessment:
| Other | 8 (4.9%) post hysterectomy | NR | | | Lower | Upper | Reference standard:
| Single center series | Race/ethnicity (n [%]): | Combination (n [%]): | | Value | 95% CI | 95% CI | Verification bias: -
| Reference standard: | NR | NR | Se | 97.9% | 93.7% | 100.0% | Test reliability/variability: +
| Surgery/pathology | Risk factors (n [%]): | Additional data used for diagnosis: | Sp | 61.8% | 53.2% | 70.4% | Sample size:+
| Reference standard applied to all test negatives?: | NR | NR | PPV | 49.5% | 39.3% | 59.6% | Statistical tests: +
| Yes | Inclusion criteria: | | NPV | 98.7% | 96.2% | 100.0% | Blinding: -
| Test reliability established?: | NR | | 2) Color Doppler-internal flow within solid component or septation | | | | Definition of +/- on screening test:
| References provided | Exclusion criteria: | | | Dis+ | Dis- | Tot
| Statistical tests used: | Premenopausal with simple or hemorrhagic cysts that resolved on followup, or if examined on any day other than days 3–10 of menstrual cycle; corpus luteum cyst on pathology; masses determined to arise from uterus on ultrasound | | T+ | 36 | 38 | 74
| Mann-Whitney | | | T- | 11 | 85 | 96
| Blinding: | | | Tot | 47 | 123 | 170
| Unclear if radiologists were blinded to clinical data | | | | | Lower | Upper
| Definition of positive and negative on screening test: | | | | Value | 95% CI | 95% CI
| PI < 1.0 | | | Se | 76.6% | 64.5% | 88.7%
| RI < 0.4 | | | Sp | 69.1% | 60.9% | 77.3%
| Morphology: suggestive of malignancy if complex cystic with solid mural nodules, complex cystic with thick septations ≥ 3 mm, predominately solid, or solid | | | PPV | 48.6% | 37.3% | 60.0%
| | | | NPV | 88.5% | 82.2% | 94.9%
| | | | 3) Spectral Doppler—pulsatility index < 1.0
| | | | | Dis+ | Dis- | Tot
| | | | T+ | 31 | 42 | 73
| | | | T- | 16 | 81 | 97
| | | | Tot | 47 | 123 | 170
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 67.0% | 53.6% | 80.4%
| | | | Sp | 66.0% | 57.6% | 74.4%
| | | | PPV | 42.5% | 31.1% | 53.8%
| | | | NPV | 83.5% | 76.1% | 90.9%
| | | | 4) Spectral Doppler—resistive index < 0.4
| | | | | Dis+ | Dis- | Tot
| | | | T+ | 11 | 12 | 23
| | | | T- | 36 | 111 | 147
| | | | Tot | 47 | 123 | 170
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 23.4% | 11.3% | 35.5%
| | | | Sp | 90.2% | 85.0% | 95.5%
| | | | PPV | 47.8% | 27.4% | 68.2%
| | | | NPV | 75.5% | 68.6% | 82.5%
Strigini, Gadducci, Del Bravo, et al., 1996 | Geographical location: | Age: | Symptomatic (n [%]): | 1) Ultrasound: Premenopausal | | | | Comments:
#4000 | Pisa, Italy | Median: 43 | NR | | Dis+ | Dis- | Tot | —Clinical presentation not described
| Dates: Jan 1993-June 1994 | Range: 18–80 | Detected by exam (n [%]): | T+ | 6 | 2 | 8 | —Unclear how many excluded by resolution on serial scans
| Size of population: | Menopausal status (n [%]): | NR | T- | 0 | 67 | 67 | —US criteria descriptive - not reproducible? - no discussion of variability of interpretation
| 109 women | Pre (< 45): 75 (69%) | Detected by imaging (n [%]): | Tot | 6 | 69 | 75 | Quality assessment:
| Other | Post (> 55): 34 (31%) | NR | | | Lower | Upper | Reference standard: +
| Case series | Race/ethnicity (n [%]): | Combination (n [%]): | | Value | 95% CI | 95% CI | Verification bias: -
| Reference standard: | NR | NR | Se | 100.0% | 40.0% | 100.0% | Test reliability/variability: -
| Surgery | Risk factors (n [%]): | Additional data used for diagnosis: | Sp | 97.1% | 93.1% | 100.0% | Sample size: -
| Reference standard applied to all test negatives?: | NR | “Most” premenopausal women followed over several menstrual cycles to rule out functional cyst | PPV | 75.0% | 45.0% | 100.0% | Statistical tests: +
| Yes | Inclusion criteria: | | NPV | 100.0% | 92.0% | 100.0% | Blinding: +
| Test reliability established?: | Not clearly described | | 2) Ultrasound: Postmenopausal | | | | Definition of +/- on screening test: +
| No | Consecutive patients scheduled for laparotomy for adnexal mass in time frame | | | Dis+ | Dis- | Tot
| Statistical tests used: | Exclusion criteria: | | T+ | 10 | 2 | 12
| Mann-Whitney U test, chi-square | NR | | T- | 3 | 19 | 22
| Blinding: | | | Tot | 13 | 21 | 34
| Unclear | | | | | Lower | Upper
| Definition of positive and negative on screening test: | | | | Value | 95% CI | 95% CI
| Ultrasound: solid, irregular structure, thick septae, irregular margins | | | Se | 76.9% | 54.0% | 99.8%
| Doppler: PI < 1 | | | Sp | 90.5% | 77.9% | 100.0%
| CA-125: > 65 U/mL | | | PPV | 83.3% | 62.2% | 100.0%
| | | | NPV | 86.4% | 72.0% | 100.0%
| | | | 3) Ultrasound: Combined pre and post
| | | | | Dis+ | Dis- | Tot
| | | | T+ | 16 | 4 | 20
| | | | T- | 3 | 86 | 89
| | | | Tot | 19 | 90 | 109
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 84.2% | 67.8% | 100.0%
| | | | Sp | 95.6% | 91.3% | 99.8%
| | | | PPV | 80.0% | 62.5% | 97.5%
| | | | NPV | 96.6% | 92.9% | 100.0%
| | | | 4) Doppler: Premenopausal
| | | | | Dis+ | Dis- | Tot
| | | | T+ | 5 | 19 | 24
| | | | T- | 1 | 50 | 51
| | | | Tot | 6 | 69 | 75
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 83.3% | 53.5% | 100%
| | | | Sp | 72.5% | 61.9% | 83.0%
| | | | PPV | 20.8% | 4.6% | 37.1%
| | | | NPV | 98.0% | 94.2% | 100%
| | | | 5) Doppler: Postmenopausal
| | | | | Dis+ | Dis- | Tot
| | | | T+ | 11 | 4 | 15
| | | | T- | 2 | 17 | 19
| | | | Tot | 13 | 21 | 34
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 84.6% | 65.0% | 100%
| | | | Sp | 81.0% | 64.2% | 97.7%
| | | | PPV | 73.3% | 51.0% | 95.7%
| | | | NPV | 89.5% | 75.7% | 100%
| | | | 6) Doppler: pre and post combined
| | | | | Dis+ | Dis- | Tot
| | | | T+ | 16 | 23 | 39
| | | | T- | 3 | 67 | 70
| | | | Tot | 19 | 90 | 109
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 84.2% | 67.8% | 100.0%
| | | | Sp | 74.4% | 65.4% | 83.5%
| | | | PPV | 41.0% | 25.6% | 56.5%
| | | | NPV | 95.7% | 91.0% | 100.0%
| | | | 7) CA-125: Premenopausal
| | | | | Dis+ | Dis- | Tot
| | | | T+ | 3 | 7 | 10
| | | | T- | 3 | 62 | 65
| | | | Tot | 6 | 69 | 75
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 50.0% | 10.0% | 90.0%
| | | | Sp | 89.9% | 82.7% | 97.0%
| | | | PPV | 30.0% | 1.6% | 58.4%
| | | | NPV | 95.4% | 90.3% | 100.0%
| | | | 8) CA-125: Postmenopausal
| | | | | Dis+ | Dis- | Tot
| | | | T+ | 8 | 2 | 10
| | | | T- | 5 | 19 | 24
| | | | Tot | 13 | 21 | 34
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 61.5% | 35.1% | 88.0%
| | | | Sp | 90.5% | 77.9% | 100%
| | | | PPV | 80.0% | 55.2% | 100%
| | | | NPV | 79.2% | 62.9% | 95.4%
| | | | 9) CA-125: combined
| | | | | Dis+ | Dis- | Tot
| | | | T+ | 77 | 9 | 86
| | | | T- | 8 | 81 | 89
| | | | Tot | 85 | 90 | 175
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 90.6% | 84.4% | 96.8%
| | | | Sp | 90.0% | 83.8% | 96.2%
| | | | PPV | 89.5% | 83.1% | 96.0%
| | | | NPV | 91.0% | 85.1% | 97.0%
Szpurek, Moszyniki, and Sajdak, 2004 | Geographical location: | Age: | Symptomatic (n [%]): | 1) Doppler index (cutoff DS ≥ 4) postmenopausal women only (n = 101) | | | | Comments:
#1530 | Poland | Pre-menopause: | NR | | Dis+ | Dis- | Tot | —Cut off point for DS calculated for this study
| Dates: NR | Mean (SD): 37.4 (9.7) | Detected by exam (n [%]): | T+ | 68 | 0 | 68 | Quality assessment:
| Size of population: | Post-menopause: | NR | T- | 6 | 27 | 33 | Reference standard: +
| 464 women | Mean (SD): 63.4 (8.7) | Detected by imaging (n [%]): | Tot | 74 | 27 | 101 | Verification bias: -
| Case series | Menopausal status (n [%]): | NR | | | Lower | Upper | Test reliability/variability: -
| Reference standard: | Pre: 363 (78%) | Combination (n [%]): | | Value | 95% CI | 95% CI | Sample size:+
| Pathology | Post: 101 (22%) | NR | Se | 91.9% | 85.7% | 98.1% | Statistical tests: +
| Reference standard applied to all test negatives?: | Race/ethnicity (n [%]): | Additional data used for diagnosis: | Sp | 100.0% | 88.9% | 100.0% | Blinding: -
| Yes | NR | DS index | PPV | 100.0% | 95.6% | 100.0% | Definition of +/- on screening test: -
| Test reliability established?: | Risk factors (n [%]): | 1 point given for each of the following: | NPV | 81.8% | 68.7% | 95.0%
| No | NR | Number of vessels (≥ 5) | AUC = 0.9775
| Statistical tests used: | Inclusion criteria: | Location of vessels (in septae, in papillae or solid parts) | 2) Doppler index (cutoff DS ≥ 4) all women(n = 464)
| Se, Sp, ROC | Women undergoing surgery for ovarian mass who had had Doppler u/s done at the hospital | Arrangement of vessels (Irregular, random) | | Dis+ | Dis- | Tot
| Blinding: | Exclusion criteria: | Shape of velocity waves (smooth; low waveform amplitude) | T+ | 143 | 20 | 163
| No | NR | Presence of protodiastolic notch (absent) | T- | 22 | 279 | 301
| Definition of positive and negative on screening test: | | | Tot | 165 | 299 | 464
| DS index ≥ 4 | | | | | Lower | Upper
| Doppler Subjective Index | | | | Value | 95% CI | 95% CI
| | | | Se | 86.7% | 81.5% | 91.9%
| | | | Sp | 93.3% | 90.5% | 96.1%
| | | | PPV | 87.7% | 82.7% | 92.8%
| | | | NPV | 92.7% | 89.8% | 95.6%
| | | | AUC = 0.9315
| | | | 3) Doppler index (cutoff DS ≥ 4) premenopause
| | | | | Dis+ | Dis- | Tot
| | | | T+ | 75 | 20 | 95
| | | | T- | 16 | 252 | 268
| | | | Tot | 91 | 272 | 363
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 82.4% | 74.6% | 90.2%
| | | | Sp | 92.6% | 89.5% | 95.7%
| | | | PPV | 78.9% | 70.7% | 87.1%
| | | | NPV | 94.0% | 91.2% | 96.9%
Tailor, Bourne, Campbell, et al., 2003 | Geographical location: | Age: | Symptomatic (n [%]): | 1) US for the first screening episode | | | | Comments:
#1970 | UK | Mean: 48 | 0 (0%) | | Dis+ | 5 | Tot | —Borderline grouped in with malignant
| Dates: NR | Range: 17–78 | Detected by exam (n [%]): | T+ | 6 | 76 | 82 | —Good data on family history specific risk (however, data organized by screen events, not by patient)
| Size of population: | Menopausal status (n [%]): | 0 (0%) | T- | 1 | 2417 | 2418 | —Menopause not defined
| 2500 screened | Pre (< 45): 1629 (65%) | Detected by imaging (n [%]): | Tot | 7 | 2493 | 2500 | —Unable to calculate 2×2 table for CA-125 as don't know either the true negative rate or the N
| Screening study | Post (> 55): 644 (26%) | 0 | | | Lower | Upper | —Subjective morphologic criteria used
| Reference standard: | And 227(9%) were post hysterectomy | Combination (n [%]): | | Value | 95% CI | 95% CI | —Inclusion criteria shifted through study period
| Histopathology or repeat US at between 12 weeks and six months depending on characteristic of first US and individual family history | Race/ethnicity (n [%]): | NR | Se | 85.7% | 59.8% | 100.0% | —TVUS only
| Reference standard applied to all test negatives?: | NR | Additional data used for diagnosis: | Sp | 97.0% | 96.3% | 97.6% | Quality assessment:
| No | Risk factors (n [%]): | NR | PPV | 7.3% | 1.7% | 13.0% | Reference standard: -
| Test reliability established?: | See below | | NPV | 100.0% | 99.9% | 100.0% | Verification bias: +/-
| No for US | Inclusion criteria: | | 2) US for the second screening episode (n = 998) | | | | Test reliability/variability: -
| Yes for CA-125 | Self-referred women in time frame for screening | | | Dis+ | 5 | Tot | Sample size:+
| Statistical tests used: | Women with at least 1 relative with ovarian cancer and another with another cancer | | T+ | 3 | 11 | 14 | Statistical tests: +
| Se Sp, | Exclusion criteria: | | T- | 0 | 984 | 984 | Blinding: +
| Posterior, prior oddss | NR | | Tot | 3 | 995 | 998 | Definition of +/- on screening test: -
| Blinding: | | | | | Lower | Upper
| Not described - but prospective study | | | | Value | 95% CI | 95% CI
| Definition of positive and negative on screening test: | | | Se | 100.0% | 0.0% | 100.0%
| US - considered abnormal is: “ovary enlarged (>95^th^ centile), a cyst was detected, and areas of hypo- or hyperechogenicity were seenwhich were inconsistent with normalphysiology” | | | Sp | 98.9% | 98.2% | 99.5%
| CA-125 - range used | | | PPV | 21.4% | 0.0% | 42.9%
| | | | NPV | 100.0% | 99.7% | 100.0%
| | | | 3) for >= 3^rd^ screen episode (n = 733)
| | | | | Dis+ | 5 | Tot
| | | | T+ | 2 | 6 | 8
| | | | T- | 0 | 725 | 725
| | | | Tot | 2 | 731 | 733
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 100.0% | -50.0% | 100.0%
| | | | Sp | 99.2% | 98.5% | 99.8%
| | | | PPV | 25.0% | 0.0% | 55.0%
| | | | NPV | 100.0% | 99.6% | 100.0%
Takac, 1998 | Geographical location: | Age: | Symptomatic (n [%]): | 1) Resistive index ≤ 0.4 | | | | Quality assessment:
#3240 | Maribor, Slovenia | Overall not reported; mean age of patients with benign masses 42 (13.5), malignant 53.3 (17.1) | NR | | Dis+ | Dis- | Tot | Reference standard: +
| Dates: Jan 1994-Dec 1995 | Menopausal status (n [%]): | Detected by exam (n [%]): | T+ | 32 | 2 | 34 | Verification bias: -
| Size of population: | NR | 120 (100%) had mass on examination in clinic—but unclear what initial presentation | T- | 7 | 76 | 83 | Test reliability/variability: +
| 120 women | Race/ethnicity (n [%]): | Detected by imaging (n [%]): | Tot | 39 | 78 | 117 | Sample size: -
| Other | NR | NR | | | Lower | Upper | Statistical tests: -
| Case series | Risk factors (n [%]): | Combination (n [%]): | | Value | 95% CI | 95% CI | Blinding: +
| Reference standard: | NR | NR | Se | 82.1% | 70.0% | 94.1% | Definition of +/- on screening test:
| Surgery | Inclusion criteria: | Additional data used for diagnosis: | Sp | 97.4% | 93.9% | 100.0%
| Reference standard applied to all test negatives?: | Adnexal mass that had surgery | Premenopausal US in follicular phase | PPV | 94.1% | 86.2% | 100.0%
| Yes | Exclusion criteria: | | NPV | 91.6% | 85.6% | 97.5%
| Test reliability established?: | Not undergoing surgery | | 3 patients with absent vascularization (2 benign, 1 malignant) excluded from analysis in paper; reported Se = 82%, Sp = 97%
| Yes; referenced and discussed
| Statistical tests used:
| Mann-Whitney
| Blinding:
| Not mentioned
| Definition of positive and negative on screening test:
| ROC done on varying definitions for resistive index
| Both highest and lowest measured RI used in calculating final RI
Tanir, Ozalp, Yalcin, et al., 2003 | Geographical location: | Age: | Symptomatic (n [%]): | 1) VEGF—threshold 68.7 | | | | Comments:
#1850 | Eskisehir, Turkey | Reported separately by diagnosis: | NR | | Dis+ | Dis- | Tot | —Clinical presentation not described
| Dates: Aug 1991-Sept 2002 | Non-neoplastic 39.0 (2.0) | Detected by exam (n [%]): | T+ | 11 | 6 | 17 | — Borderline tumors grouped in with malignant
| Size of population: | Benign 42.2 (5.2) | NR | T- | 1 | 44 | 45 | —Unable to calculate 2×2 tables by menopausal status, but AUC's given:
| 63 women | Malignant 56.9 (4.2) | Detected by imaging (n [%]): | Tot | 12 | 50 | 62 | Premenopausal
| Other | Menopausal status (n [%]): | NR | | | Lower | Upper | VEGF: AUC 0.938
| Case series | Pre (< 45): 40 (63%) | Combination (n [%]): | | Value | 95% CI | 95% CI | CA-125: AUC 0.769
| Reference standard: | Post (> 55): 23 (37%) | NR | Se | 92.0% | 76.7% | 100.0% | Postmenopausal
| Surgery/pathology | Race/ethnicity (n [%]): | Additional data used for diagnosis: | Sp | 88.0% | 79.0% | 97.0% | VEGF: AUC 0.902
| Reference standard applied to all test negatives?: | NR | Ultrasound (including Doppler) | PPV | 64.7% | 42.0% | 87.4% | CA-125: 0.873
| Yes | Risk factors (n [%]): | | NPV | 97.8% | 93.5% | 100.0% | Reported Se Sp inconsistent with reported LR+ and LR-, 2×2 tables uncertain.
| Test reliability established?: | NR | | 2) CA-125 ≥ 37 U/mL | | | | Quality assessment:
| Yes | Inclusion criteria: | | | Dis+ | Dis- | Tot | Reference standard: +
| Statistical tests used: | NR | | T+ | 11 | 23 | 34 | Verification bias: +
| ROC | Exclusion criteria: | | T- | 1 | 27 | 28 | Test reliability/variability: +
| Blinding: | NR | | Tot | 12 | 50 | 62 | Sample size: -
| Yes | | | | | Lower | Upper | Statistical tests: +
| Definition of positive and negative on screening test: | | | | Value | 95% CI | 95% CI | Blinding:_
| Varied cutoff for VEGF, CA-125 | | | Se | 92.0% | 76.7% | 100.0% | Definition of +/- on screening test: +
| | | | Sp | 54.0% | 40.2% | 67.8%
| | | | PPV | 32.4% | 16.6% | 48.1%
| | | | NPV | 96.4% | 89.6% | 100.0%
Tay and Chua, 1994 | Geographical location: | Age: | Symptomatic (n [%]): | 1) Serum CA-125 > 35 U/ml | | | | Comments:
#4450 | Singapore | Mean (SD): 38.6 (12.9) | NR | | Dis+ | Dis- | Tot | —Unclear how patients chosen (“cysts”)
| Dates: Oct 1991 - Apr 1992 | Menopausal status (n [%]): | Detected by exam (n [%]): | T+ | 8 | 21 | 29 | —Study compares salivary CA-125 with urine and serum
| Size of population: | NR | NR | T- | 1 | 74 | 75 | —There appears to be an error in reported statistics - not all of Se, Sp, PPV, and NPV can be correct. “In this study the false positive rate was 22%…” suggests that the Sp reported as 79.2 % was in error and should be 78% (or 77.9% as shown in our 2×2 table abstraction).
| 105 women | Race/ethnicity (n [%]): | Detected by imaging (n [%]): | Tot | 9 | 95 | 104 | Quality assessment:
| Other | NR | NR | | | Lower | Upper | Reference standard: +
| Prospective study of patients admitted to single center with mass for surgery | Risk factors (n [%]): | Combination (n [%]): | | Value | 95% CI | 95% CI | Verification bias: +
| Reference standard: | NR | 105 (100%) | Se | 88.9% | 68.4% | 100.0% | Test reliability/variability: +
| Histopathology | Inclusion criteria: | Additional data used for diagnosis: | Sp | 77.9% | 69.6% | 86.2% | Sample size: - not discussed
| Reference standard applied to all test negatives?: | Patients admitted to hospital with diagnosis of “ovarian cysts” for elective surgery. | NR | PPV | 27.6% | 11.3% | 43.9% | Statistical tests: +
| Yes | Exclusion criteria: | | NPV | 98.7% | 96.1% | 100.0% | Blinding: -
| Test reliability established?: | NR | | | | | | Definition of +/- on screening test: +
| Yes
| Statistical tests used:
| Se, Sp
| Blinding:
| Definition of positive and negative on screening test:
| CA-125 > 35 U/mL
Tekay and Jouppila, 1992 | Geographical location: | Age: | Symptomatic (n [%]): | 1) RI <=0.6 | | | | Comments:
#10970 | Finland | Premenopausal - mean 37 range 17–50 | NR | | Dis+ | Dis- | Tot | —Borderline tumors grouped with malignant
| Dates: NR | Post menopausal - mean age 60 range 42–74 | Detected by exam (n [%]): | T+ | 9 | 17 | 26 | —Although data collected on US morphology and PI, only data for RI able to be extracted into 2×2 table
| Size of population: | Menopausal status (n [%]): | NR | T- | 2 | 44 | 46 | —Overlap in PI and RI noted for all malignant and benign tumors
| 72 | Pre (< 45): 46 (63.9%) | Detected by imaging (n [%]): | Tot | 11 | 61 | 72 | —68 examined with TVUS, 4 with abdominal US - unable to stratify results
| Case series | Post (> 55): 26(36.1%) | NR | | | Lower | Upper | Quality assessment:
| Reference standard: | Race/ethnicity (n [%]): | Combination (n [%]): | | Value | 95% CI | 95% CI | Reference standard: +
| Histopathology | NR | NR | Se | 82.0% | 59.3% | 100.0% | Verification bias: +
| Reference standard applied to all test negatives?: | Risk factors (n [%]): | Additional data used for diagnosis: | Sp | 72.0% | 60.7% | 83.3% | Test reliability/variability: -
| Yes | NR | NR | PPV | 34.6% | 16.3% | 52.9% | Sample size: -
| Test reliability established?: | Inclusion criteria: | | NPV | 95.7% | 89.8% | 100.0% | Statistical tests: +
| Yes | Referral to hospital for adnexal mass who underwent surgery | | 2) RI <+ 0.5 | | | | Blinding: +
| Statistical tests used: | Exclusion criteria: | | | Dis+ | Dis- | Tot | Definition of +/- on screening test: +
| Se, Sp | NR | | T+ | 5 | 7 | 12
| Mann-Whitney U test | | | T- | 6 | 54 | 60
| Blinding: | | | Tot | 11 | 61 | 72
| Not mentioned but prospective | | | | | Lower | Upper
| Definition of positive and negative on screening test: | | | | Value | 95% CI | 95% CI
| RI <= 0.6 or 0.5 | | | Se | 46.0% | 16.5% | 75.5%
| | | | Sp | 89.0% | 81.1% | 96.9%
| | | | PPV | 41.7% | 13.8% | 69.6%
| | | | NPV | 90.0% | 82.4% | 97.6%
Tepper, Lerner-Geva, Altaras, et al., 1995 | Geographical location: | Age: | Symptomatic (n [%]): | 1) RI (cutoff < 0.4), only considering patients in whom blood flow velocity waveforms could be detected, borderline tumors excluded | | | | Comments:
#4090 | Kfar Saba, Israel | Mean (SD): 44.3 | NR | | Dis+ | Dis- | Tot | —To translate data into 2×2 table, abstractor had to round figures, so could be introducing error
| Dates: 1990-1993 | Range: 8–79 | Detected by exam (n [%]): | T+ | 17 | 3 | 20 | —Unclear inclusion criteria
| Size of population: | Menopausal status (n [%]): | NR | T- | 8 | 79 | 87 | —Interobserver variability not discussed
| 217 women | NR | Detected by imaging (n [%]): | Tot | 25 | 82 | 107 | Tumors of low malignant potential are not included in 2×2 tables
| Other | Race/ethnicity (n [%]): | NR | | | Lower | Upper | Authors calculated Se/Sp only on patients in whom blood flow velocity waveforms could be detected:
| All patients admitted to hospital with mass for surgery | NR | Combination (n [%]): | | Value | 95% CI | 95% CI | 25/38 (65.8%) malignant tumors
| Reference standard: | Risk factors (n [%]): | NR | Se | 68.0% | 49.7% | 86.3% | 12/14 (85.7%) borderline tumors
| Histopathology | NR | Additional data used for diagnosis: | Sp | 96.3% | 92.3% | 100.0% | 82/165 (49.7%) benign tumors
| Reference standard applied to all test negatives?: | Inclusion criteria: | NR | PPV | 85.0% | 69.4% | 100.0% | Quality assessment:
| Yes | Admitted to hospital for surgery for diagnosis of adnexal mass | | NPV | 90.8% | 84.7% | 96.9% | Reference standard: +
| Test reliability established?: | Exclusion criteria: | | 2) RI (cutoff < 0.4), borderline tumors counted as malignant | | | | Verification bias: ±
| Yes, by reference | NR | | | Dis+ | Dis- | Tot | Test reliability/variability: -
| Statistical tests used: | | | T+ | 19 | 3 | 22 | Sample size: -
| Se, Sp | | | T- | 33 | 162 | 195 | Statistical tests: +/-
| Blinding: | | | Tot | 52 | 165 | 217 | Blinding: -
| NR | | | | | Lower | Upper | Definition of +/- on screening test: +
| Definition of positive and negative on screening test: | | | | Value | 95% CI | 95% CI
| RI cutoff of < 0.4 (literature standard) compared with 0.47 (study mean) and 0.53 (mean + 2SD) | | | Se | 36.5% | 23.5% | 49.6%
| | | | Sp | 98.2% | 96.1% | 100.0%
| | | | PPV | 86.4% | 72.0% | 100.0%
| | | | NPV | 83.1% | 77.8% | 88.3%
| | | | 3) RI (cutoff < 0.4) borderline tumors counted as benign
| | | | | Dis+ | Dis- | Tot
| | | | T+ | 17 | 5 | 22
| | | | T- | 21 | 174 | 195
| | | | Tot | 38 | 179 | 217
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 44.7% | 28.9% | 60.5%
| | | | Sp | 97.2% | 94.8% | 99.6%
| | | | PPV | 77.3% | 59.8% | 94.8%
| | | | NPV | 89.2% | 84.9% | 93.6%
| | | | 4) RI (cutoff < 0.47)
| | | | | Dis+ | Dis- | Tot
| | | | T+ | 33 | 23 | 56
| | | | T- | 5 | 142 | 147
| | | | Tot | 38 | 165 | 203
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 86.8% | 76.1% | 97.6%
| | | | Sp | 86.1% | 80.8% | 91.3%
| | | | PPV | 58.9% | 46.0% | 71.8%
| | | | NPV | 96.6% | 93.7% | 99.5%
| | | | 5) RI (cutoff < 0.53)
| | | | | Dis+ | Dis- | Tot
| | | | T+ | 38 | 43 | 81
| | | | T- | 0 | 122 | 122
| | | | Tot | 38 | 165 | 203
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 100.0% | 92.1% | 100.0%
| | | | Sp | 73.9% | 67.2% | 80.6%
| | | | PPV | 46.9% | 36.0% | 57.8%
| | | | NPV | 100.0% | 97.5% | 100.0%
Tian, Zhang, Jiao, et al., 2000 | Geographical location: | Age: | Symptomatic (n [%]): | 1) Tc-99m | | | | Comments:
#2670 | Beijing, China | Benign | “Most” had “no symptoms other than slight abdominal pain” | | Dis+ | Dis- | Tot | —Small study
| Dates: April 1996-Nov 1998 | Range: 15–72 | Detected by exam (n [%]): | T+ | 22 | 7 | 29 | —Different numbers of patients had different tests
| Size of population: | Malignant | 65 (91.5%; unclear if screening exam) | T- | 1 | 41 | 42 | —Clinical presentation not reported
| 71 women | Range: 25–70 | Detected by imaging (n [%]): | Tot | 23 | 48 | 71 | —Explicitly states that readers blinded to clinical history
| Other | Menopausal status (n [%]): | 28 (39.4%); MRI or CT | | | Lower | Upper | —No description of CT-MRI diagnostic criteria (unclear if analysis based on outcome of either CT or MRI or both)
| Case series | NR | Combination (n [%]): | | Value | 95% CI | 95% CI | Quality assessment:
| Reference standard: | Race/ethnicity (n [%]): | NR | Se | 92.0% | 80.9% | 100.0% | Reference standard: +
| Surgery/pathology | NR | Additional data used for diagnosis: | Sp | 54.0% | 39.9% | 68.1% | Verification bias: +
| Reference standard applied to all test negatives?: | Risk factors (n [%]): | NR | PPV | 75.9% | 60.3% | 91.4% | Test reliability/variability: -
| Yes | NR | | NPV | 97.6% | 93.0% | 100.0% | Sample size: -
| Test reliability established?: | Inclusion criteria: | | 2) CA-125 (>35 U/ml) | | | | Statistical tests: -
| Not referenced or discussed | Mass, scheduled for laparoscopy | | | Dis+ | Dis- | Tot | Blinding: +
| Statistical tests used: | Exclusion criteria: | | T+ | 20 | 12 | 32 | Definition of +/- on screening test: +
| Chi-square, t-test | NR | | T- | 3 | 18 | 21
| Blinding: | | | Tot | 23 | 30 | 53
| Yes; explicitly stated | | | | | Lower | Upper
| Definition of positive and negative on screening test: | | | | Value | 95% CI | 95% CI
| Grade 1 or 2 uptake of c-99m, no move with peristalsis or volume change of bladder, or signs of intestinal, peritoneal, or lymphatic involvement | | | Se | 87.0% | 73.2% | 100.0%
| | | | Sp | 60.0% | 42.5% | 77.5%
| | | | PPV | 62.5% | 45.7% | 79.3%
| | | | NPV | 85.7% | 70.7% | 100.0%
| | | | 3) CT-MRI
| | | | | Dis+ | Dis- | Tot
| | | | T+ | 10 | 8 | 18
| | | | T- | 3 | 7 | 10
| | | | Tot | 13 | 15 | 28
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 76.9% | 54.0% | 99.8%
| | | | Sp | 46.7% | 21.4% | 71.9%
| | | | PPV | 55.6% | 32.6% | 78.5%
| | | | NPV | 70.0% | 41.6% | 98.4%
Timmerman, Verrelst, Bourne, et al., 1999 | Geographical location: | Age: | Symptomatic (n [%]): | 1) CA-125 ≥ 35 (borderline included as malignant) | | | | Comments:
#5940 | UK | Mean: | NR | | Dis+ | Dis- | Tot | —Clinical presentation not described
| Dates: Aug 1994 - Aug 1996 | Pre 40 | Detected by exam (n [%]): | T+ | 39 | 23 | 62 | Quality assessment:
| Size of population: | Post 64 | NR | T- | 10 | 101 | 111 | Reference standard: +
| 173 women | Range: 22–93 | Detected by imaging (n [%]): | Tot | 49 | 124 | 173 | Verification bias: +
| Other | Menopausal status (n [%]): | NR | | | Lower | Upper | Test reliability/variability: +
| Consecutive case series | Pre (< 45): 83 (48.0%) | Combination (n [%]): | | Value | 95% CI | 95% CI | Sample size: -
| Reference standard: | Post (> 55): 90 (52.0%) | NR | Se | 79.6% | 68.3% | 90.9% | Statistical tests: +
| Histopathology | Race/ethnicity (n [%]): | Additional data used for diagnosis: | Sp | 81.5% | 74.7% | 88.3% | Blinding: +/-
| Reference standard applied to all test negatives?: | NR | NR | PPV | 62.9% | 50.9% | 74.9% | Definition of +/- on screening test: +/-
| Yes | Risk factors (n [%]): | | NPV | 91.0% | 85.7% | 96.3%
| Test reliability established?: | NR | | 2) CA-125 ≥ 35 (borderline included as benign)
| Yes | Inclusion criteria: | | | Dis+ | Dis- | Tot
| Statistical tests used: | Prospective patients to get surgery for mass | | T+ | 34 | 27 | 61
| Logistic regression ROC Se Sp | Exclusion criteria: | | T- | 10 | 102 | 112
| Blinding: | No CA-125 preoperatively available | | Tot | 44 | 129 | 173
| NR - prospective | | | | | Lower | Upper
| Definition of positive and negative on screening test: | | | | Value | 95% CI | 95% CI
| CA-125 ≥ 35 | | | Se | 77.3% | 64.9% | 89.7%
| | | | Sp | 79.1% | 72.0% | 86.1%
| | | | PPV | 55.7% | 43.3% | 68.2%
| | | | NPV | 91.1% | 85.8% | 96.4%
Timor-Tritsch, Lerner, Montea-gudo, et al., 1993 | Geographical location: | Age: | Symptomatic (n [%]): | 1) Sassone morphologic criteria | | | | Comments:
#10840 | USA | Mean: 43.2 | NR | | Dis+ | Dis- | Tot | —Excluded from analysis those masses in which no flow could be measured (although none were CA)
| Dates: Apr 1991 - May 1992 | Range: 13–74 | Detected by exam (n [%]): | T+ | 11 | 9 | 20 | —Borderline tumors grouped in with malignant
| Size of population: | Menopausal status (n [%]): | NR | T- | 1 | 61 | 62 | —RI and PI cutpoints calculated from results of patient series (predefined cutpoints not used)
| 93 patients | NR | Detected by imaging (n [%]): | Tot | 12 | 70 | 82 | —Don't mention cutpoint for Sassone's criteria (assume 9 from original article)
| 115 masses | Race/ethnicity (n [%]): | NR | | | Lower | Upper | —Clinical pathway not illuminated
| Case series | NR | Combination (n [%]): | | Value | 95% CI | 95% CI | —Although much of the article data was reported for masses not individuals, these 2×2 tables are for individuals
| Reference standard: | Risk factors (n [%]): | NR | Se | 93.7% | 80.0% | 100.0% | —TVUS only
| Histopathology | NR | Additional data used for diagnosis: | Sp | 87.1% | 79.2% | 95.0% | Quality assessment:
| Reference standard applied to all test negatives?: | Inclusion criteria: | NR | PPV | 55.0% | 33.2% | 76.8% | Reference standard: +
| Yes | Presenting to hospital with diagnosis of mass in time frame | | NPV | 98.4% | 95.3% | 100.0% | Verification bias: +
| Test reliability established?: | Exclusion criteria: | | 2) PI < 0.62 | | | | Test reliability/variability: -
| Yes | NR | | | Dis+ | Dis- | Tot | Sample size: -
| Statistical tests used: | | | T+ | 11 | 2 | 13 | Statistical tests: +/-
| Se, Sp | | | T- | 2 | 68 | 70 | Blinding: +
| Blinding: | | | Tot | 12 | 70 | 83 | Definition of +/- on screening test: +
| Not described but prospective | | | | | Lower | Upper
| Definition of positive and negative on screening test: | | | | Value | 95% CI | 95% CI
| Sassone scoring system | | | Se | 87.5% | 68.8% | 100.0%
| Used (cutoff not mentioned but assume >= 9) | | | Sp | 97.4% | 93.7% | 100.0%
| RI < 0.46 | | | PPV | 84.6% | 65.0% | 100.0%
| PI < 0.62 | | | NPV | 97.1% | 93.2% | 100.0%
| | | | 3) RI < 0.46
| | | | | Dis+ | Dis- | Tot
| | | | T+ | 11 | 1 | 12
| | | | T- | 1 | 69 | 70
| | | | Tot | 12 | 70 | 82
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 93.8% | 80.2% | 100.0%
| | | | Sp | 98.7% | 96.0% | 100.0%
| | | | PPV | 91.7% | 76.0% | 100.0%
| | | | NPV | 98.6% | 95.8% | 100.0%
Tingulstad, Hagen, Skjeldestad, et al., 1996 | Geographical location: | Age: | Symptomatic (n [%]): | 1) CA-125 > 25 U/ml | | | | Comments:
#3890 | Norway | NR | NR | | Dis+ | Dis- | Tot | —RMI study - no cutoffs in analysis
| Dates: Feb 1992 - Feb 1994 | Menopausal status (n [%]): | Detected by exam (n [%]): | T+ | 45 | 22 | 67 | —No description of inter
| Size of population: | Pre (< 45): 82 (47.4%) | NR | T- | 11 | 95 | 106 | Quality assessment:
| 173 women | Post (> 55): 91 (52.6%) | Detected by imaging (n [%]): | Tot | 56 | 117 | 173 | Reference standard: +
| Other | (defined as > 12 months amenorrhea or age > 50 if hysterectomy) | NR | | | Lower | Upper | Verification bias: +
| Consecutive patient series | Race/ethnicity (n [%]): | Combination (n [%]): | | Value | 95% CI | 95% CI | Test reliability/variability: -/intraobserver variability with US
| Reference standard: | NR | NR | Se | 80.0% | 69.5% | 90.5% | Sample size: -
| Histopathology | Risk factors (n [%]): | Additional data used for diagnosis: | Sp | 81.0% | 73.9% | 88.1% | Statistical tests: +
| Reference standard applied to all test negatives?: | NR | NR | PPV | 67.2% | 55.9% | 78.4% | Blinding: -
| Yes | Inclusion criteria: | | NPV | 89.6% | 83.8% | 95.4% | Definition of +/- on screening test: +
| Test reliability established?: | Age >30 with pelvic mass scheduled for surgery | | 2) CA-125 > 50 U/ml
| Yes | Exclusion criteria: | | | Dis+ | Dis- | Tot
| Statistical tests used: | NR | | T+ | 41 | 7 | 48
| Chi square, Se Sp, ROC | | | T- | 15 | 110 | 125
| Mann-Whitney U test | | | Tot | 56 | 117 | 173
| Blinding: | | | | | Lower | Upper
| NR - prospective | | | | Value | 95% CI | 95% CI
| Definition of positive and negative on screening test: | | | Se | 73.0% | 61.4% | 84.6%
| CA-125 - range | | | Sp | 94.0% | 89.7% | 98.3%
| US ≥ 2, where | | | PPV | 85.4% | 75.4% | 95.4%
| 1 point assigned for each of the following: | | | NPV | 88.0% | 82.3% | 93.7%
| multilocular cystic lesion | | | 3) US score > 2
| solid areas | | | | Dis+ | Dis- | Tot
| bilateral lesion | | | T+ | 38 | 21 | 59
| ascites | | | T- | 18 | 96 | 114
| intra-abdominal ascites | | | Tot | 56 | 117 | 173
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 68.0% | 55.8% | 80.2%
| | | | Sp | 82.0% | 75.0% | 89.0%
| | | | PPV | 64.4% | 52.2% | 76.6%
| | | | NPV | 84.2% | 77.5% | 90.9%
| | | | 4) Menopausal status (postmenopausal = malignant)
| | | | | Dis+ | Dis- | Tot
| | | | T+ | 45 | 46 | 91
| | | | T- | 11 | 71 | 82
| | | | Tot | 56 | 117 | 173
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 80.4% | 70.0% | 90.8%
| | | | Sp | 60.7% | 51.8% | 69.5%
| | | | PPV | 49.5% | 39.2% | 59.7%
| | | | NPV | 86.6% | 79.2% | 94.0%
Torres, Derchain, Faundes, et al., 2002 | Geographical location: | Age: | Symptomatic (n [%]): | 1) CA-125 > 35 U/ml | | | | Comments:
#2170 | Sao Paulo, Brazil | NR | NR | | Dis+ | Dis- | Tot | —RMI study so no exact cutoffs given, rather 2×2 tables done at various levels
| Dates: Jan 1996 - Mar 1998 | Menopausal status (n [%]): | Detected by exam (n [%]): | T+ | 52 | 23 | 75 | —Unclear where patients referred from or how decision to do surgery done
| Size of population: | NR | NR | T- | 15 | 68 | 83 | -No discussion of variability in US
| 158 women | Race/ethnicity (n [%]): | Detected by imaging (n [%]): | Tot | 67 | 91 | 158 | Quality assessment:
| Other | NR | NR | | | Lower | Upper | Reference standard: +
| Series | Risk factors (n [%]): | Combination (n [%]): | | Value | 95% CI | 95% CI | Verification bias: +
| Reference standard: | NR | NR | Se | 78.0% | 68.1% | 87.9% | Test reliability/variability:CA-125 +
| Histopathology | Inclusion criteria: | Additional data used for diagnosis: | Sp | 75.0% | 66.1% | 83.9% | US -
| Reference standard applied to all test negatives?: | Pelvic mass who had surgery in time frame | NR | PPV | 69.3% | 58.9% | 79.8% | Sample size: -
| Yes | Exclusion criteria: | | NPV | 81.9% | 73.6% | 90.2% | Statistical tests: +
| Test reliability established?: | Lung masses, | | 2) US score ≥2 | | | | Blinding: +/- (not discussed but prospective)
| Yes | Signs of hepatic or intraperitoneal mets | | | Dis+ | Dis- | Tot | Definition of +/- on screening test: +/-
| Statistical tests used: | | | T+ | 55 | 30 | 85
| Se, Sp | | | T- | 12 | 61 | 73
| Regression | | | Tot | 67 | 91 | 158
| Blinding: | | | | | Lower | Upper
| NR - but prospective | | | | Value | 95% CI | 95% CI
| Definition of positive and negative on screening test: | | | Se | 82.0% | 72.8% | 91.2%
| US score - range from other RMI literature (0–8) | | | Sp | 67.0% | 57.3% | 76.7%
| CA-125 - range | | | PPV | 64.7% | 54.5% | 74.9%
| | | | NPV | 83.6% | 75.1% | 92.1%
| | | | 3) US score ≥3
| | | | | Dis+ | Dis- | Tot
| | | | T+ | 50 | 26 | 76
| | | | T- | 17 | 65 | 82
| | | | Tot | 67 | 91 | 158
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 75.0% | 64.6% | 85.4%
| | | | Sp | 71.0% | 61.7% | 80.3%
| | | | PPV | 65.8% | 55.1% | 76.5%
| | | | NPV | 79.3% | 70.5% | 88.0%
| | | | 4) Menopausal status (menopausal = malignant)
| | | | | Dis+ | Dis- | Tot
| | | | T+ | 49 | 28 | 77
| | | | T- | 18 | 63 | 81
| | | | Tot | 67 | 91 | 158
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 73.0% | 62.4% | 83.6%
| | | | Sp | 69.0% | 59.5% | 78.5%
| | | | PPV | 63.6% | 52.9% | 74.4%
| | | | NPV | 77.8% | 68.7% | 86.8%
Troiano, Quedens-Case, and Taylor, 1997 | Geographical location: | Age: | Symptomatic (n [%]): | 1) CA-125 ≥ 36 U/ml | | | | Comments:
#3680 | New Haven, CT | NR | NR | | Dis+ | Dis- | Tot | —Reported sensitivity/specificity not consistent with data provided in Table 1 of paper
| Dates: 1991-1996 | Menopausal status (n [%]): | Detected by exam (n [%]): | T+ | 17 | 88 | 105 | —Diagnostic criteria not explicit
| Size of population: | Pre (< 45): 102 (70.8%) | NR | T- | 3 | 36 | 39 | —Unable to calculate 2×2 table for ultrasound results
| 144 women | Post (> 55): 42 (29.2%) | Detected by imaging (n [%]): | Tot | 20 | 124 | 144 | —Borderline tumors grouped with malignant
| Other | Race/ethnicity (n [%]): | NR | | | Lower | Upper | Quality assessment:
| Case series | NR | Combination (n [%]): | | Value | 95% CI | 95% CI | Reference standard: +
| Reference standard: | Risk factors (n [%]): | NR | Se | 85.0% | 69.4% | 100.0% | Verification bias: -
| Surgery (45); serial ultrasound (followup 1–6 years) | NR | Additional data used for diagnosis: | Sp | 29.0% | 21.0% | 37.0% | Test reliability/variability: -
| Reference standard applied to all test negatives?: | Inclusion criteria: | NR | PPV | 16.2% | 9.1% | 23.2% | Sample size: -
| See above | NR | | NPV | 92.3% | 83.9% | 100.0% | Statistical tests: -
| Test reliability established?: | Exclusion criteria: | | 2) CA-125≥ 36 U/ml, postmenopausal | | | | Blinding: -
| Not referenced or discussed | NR | | | Dis+ | Dis- | Tot | Definition of +/- on screening test: -
| Statistical tests used: | | | T+ | 10 | 25 | 35
| Descriptive | | | T- | 0 | 7 | 7
| Blinding: | | | Tot | 10 | 32 | 42
| No | | | | | Lower | Upper
| Definition of positive and negative on screening test: | | | | Value | 95% CI | 95% CI
| Solid components, thickened septation, nodules; Dopplers; no explicit scoring or cutpoint used. | | | Se | 100.0% | 70.0% | 100.0%
| CA-125 ≥ 36 U/m; | | | Sp | 21.9% | 7.6% | 36.2%
| | | | PPV | 28.6% | 13.6% | 43.5%
| | | | NPV | 100.0% | 57.1% | 100.0%
Valentin, 1997 | Geographical location: | Age: | Symptomatic (n [%]): | 1) PI (cutoff < 1) | | | | Comments:
#6170 | Malmo, Sweden | Mean: 47.8 | NR | | Dis+ | Dis- | Tot | —Negative surgeries but with diagnosis of myoma were excluded (7)
| Dates: NR | Range: 20–90 | Detected by exam (n [%]): | T+ | 19 | 74 | 93 | —Unclear why the 5 who had only diagnostic laparoscopy were excluded
| Size of population: | Menopausal status (n [%]): | NR | T- | 4 | 38 | 42 | —LMP tumors lumped in with malignant
| 151 women | Pre (< 45): 92 (62.9%) | Detected by imaging (n [%]): | Tot | 23 | 112 | 135 | —Visibility of color lakes is subjective evaluation of Doppler, uncertain reliability
| Other | Post (> 55): 53 (37.1%) | NR | | | Lower | Upper | Quality assessment:
| Prospective study at university hospital of consecutive patients with adnexal mass scheduled for surgery | 6 women who had undergoing hysterectomy were classified a pre or post menopausal on the basis of age. | Combination (n [%]): | | Value | 95% CI | 95% CI | Reference standard: +
| Reference standard: | Race/ethnicity (n [%]): | NR | Se | 82.6% | 67.1% | 98.1% | Verification bias: +
| Histopathology | NR | Additional data used for diagnosis: | Sp | 33.9% | 25.2% | 42.7% | Test reliability/variability: -
| Reference standard applied to all test negatives?: | Risk factors (n [%]): | NR | PPV | 20.4% | 12.2% | 28.6% | Sample size: -
| Yes, but 49 were excluded for technical reasons | NR | | NPV | 90.5% | 81.6% | 99.4% | Statistical tests: +
| Test reliability established?: | Inclusion criteria: | | 2) Color lakes visible on Doppler | | | | Blinding: -
| Statistical tests used: | NR | | | Dis+ | Dis- | Tot | Definition of +/- on screening test: -
| Se, Sp, regression | Exclusion criteria: | | T+ | 21 | 42 | 63
| Blinding: | 49 excluded for:uninterpretable US examinations (12), surgery canceled (replaced by laparoscopy) (5), biopsy with cytologic diagnosis (3), or clinical followup (22), myoma at time of surgery (7) | | T- | 3 | 85 | 88
| NR | | | Tot | 24 | 127 | 151
| Definition of positive and negative on screening test: | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 87.5% | 74.3% | 100.0%
| | | | Sp | 66.9% | 58.7% | 75.1%
| | | | PPV | 33.3% | 21.7% | 45.0%
| | | | NPV | 96.6% | 92.8% | 100.0%
| | | | 3) Menopausal status (post =T+)
| | | | | Dis+ | Dis- | Tot
| | | | T+ | 19 | 5 | 24
| | | | T- | 37 | 90 | 127
| | | | Tot | 56 | 95 | 151
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 33.9% | 21.5% | 46.3%
| | | | Sp | 94.7% | 90.2% | 99.2%
| | | | PPV | 79.2% | 62.9% | 95.4%
| | | | NPV | 70.9% | 63.0% | 78.8%
| | | | Multiple logistic regression model constructed for multilocular solid tumors - results not reported here.
Valentin, 1999b | Geographical location: | Age: | Symptomatic (n [%]): | 1) “Subjective”Morphology alone | | | | Quality assessment:
#3100 | Malmo, Sweden | NR | NR | | Dis+ | Dis- | Tot | Reference standard: -
| Dates: NR | Menopausal status (n [%]): | Detected by exam (n [%]): | T+ | 21 | 6 | 27 | Verification bias: -
| Size of population: | Pre (< 45): 98 (59.5%) | NR | T- | 3 | 143 | 146 | Test reliability/variability: -
| 173 women | Peri (45–55): | Detected by imaging (n [%]): | Tot | 24 | 149 | 173 | Sample size: -
| Other | Post (> 55): 70 (40.5%) | NR | | | Lower | Upper | Statistical tests: +
| Series | Race/ethnicity (n [%]): | Combination (n [%]): | | Value | 95% CI | 95% CI | Blinding: -
| Reference standard: | NR | NR | Se | 87.5% | 74.3% | 100.0% | Definition of +/- on screening test: +
| Pathology | Risk factors (n [%]): | Additional data used for diagnosis: | Sp | 96.0% | 92.8% | 99.1%
| Reference standard applied to all test negatives?: | NR | NR | PPV | 77.8% | 62.1% | 93.5%
| Yes | Inclusion criteria: | | NPV | 97.9% | 95.6% | 100.0%
| Test reliability established?: | NR | | 2) Morphology plus Doppler
| No | Exclusion criteria: | | | Dis+ | Dis- | Tot
| Statistical tests used: | NR | | T+ | 20 | 5 | 25
| Chi-square | | | T- | 4 | 144 | 148
| Blinding: | | | Tot | 24 | 149 | 173
| No | | | | | Lower | Upper
| Definition of positive and negative on screening test: | | | | Value | 95% CI | 95% CI
| Morphology: solid components | | | Se | 83.3% | 68.4% | 98.2%
| Lerner score: ≥ 3 | | | Sp | 96.6% | 93.8% | 99.5%
| Color score: ≥ 40 or 65 | | | PPV | 80.0% | 64.3% | 95.7%
| Pulsatility < 1.0 | | | NPV | 97.3% | 94.7% | 99.9%
| Resistive index < 0.4 | | | 3) Lerner score
| Time-averaged max velocity: ≥ 7.2 cm/s | | | | Dis+ | Dis- | Tot
| Peak systolic velocity: ≥ 14.4 cm/s | | | T+ | 22 | 96 | 118
| | | | T- | 2 | 53 | 55
| | | | Tot | 24 | 149 | 173
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 91.7% | 80.6% | 100.0%
| | | | Sp | 35.6% | 27.9% | 43.3%
| | | | PPV | 18.6% | 11.6% | 25.7%
| | | | NPV | 96.4% | 91.4% | 100.0%
| | | | 4) Time-averaged max velocity
| | | | | Dis+ | Dis- | Tot
| | | | T+ | 24 | 61 | 85
| | | | T- | 0 | 59 | 59
| | | | Tot | 24 | 120 | 144
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 100.0% | 87.5% | 100.0%
| | | | Sp | 49.2% | 40.2% | 58.1%
| | | | PPV | 28.2% | 18.7% | 37.8%
| | | | NPV | 100.0% | 94.9% | 100.0%
| | | | 5) Morphology plus peak systolic velocity
| | | | | Dis+ | Dis- | Tot
| | | | T+ | 19 | 44 | 63
| | | | T- | 5 | 99 | 104
| | | | Tot | 24 | 143 | 167
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 79.2% | 62.9% | 95.4%
| | | | Sp | 69.2% | 61.7% | 76.8%
| | | | PPV | 30.2% | 18.8% | 41.5%
| | | | NPV | 95.2% | 91.1% | 99.3%
| | | | 6) Morphology plus color score
| | | | | Dis+ | Dis- | Tot
| | | | T+ | 17 | 39 | 56
| | | | T- | 7 | 106 | 113
| | | | Tot | 24 | 145 | 169
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 70.8% | 52.6% | 89.0%
| | | | Sp | 73.1% | 65.9% | 80.3%
| | | | PPV | 30.4% | 18.3% | 42.4%
| | | | NPV | 93.8% | 89.4% | 98.2%
| | | | 7) Morphology
| | | | | Dis+ | Dis- | Tot
| | | | T+ | 23 | 94 | 117
| | | | T- | 1 | 55 | 56
| | | | Tot | 24 | 149 | 173
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 95.8% | 87.8% | 100.0%
| | | | Sp | 36.9% | 29.2% | 44.7%
| | | | PPV | 19.7% | 12.5% | 26.9%
| | | | NPV | 98.2% | 94.7% | 100.0%
| | | | 8) Resistance index
| | | | | Dis+ | Dis- | Tot
| | | | T+ | 6 | 7 | 13
| | | | T- | 18 | 113 | 131
| | | | Tot | 24 | 120 | 144
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 25.0% | 7.7% | 42.3%
| | | | Sp | 94.2% | 90.0% | 98.4%
| | | | PPV | 46.2% | 19.1% | 73.3%
| | | | NPV | 86.3% | 80.4% | 92.2%
| | | | 9) Pulsatility index
| | | | | Dis+ | Dis- | Tot
| | | | T+ | 21 | 81 | 102
| | | | T- | 3 | 39 | 42
| | | | Tot | 24 | 120 | 144
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 87.5% | 74.3% | 100.0%
| | | | Sp | 32.5% | 24.1% | 40.9%
| | | | PPV | 20.6% | 12.7% | 28.4%
| | | | NPV | 92.9% | 85.1% | 100.0%
Valentin, 2000 | Geographical location: | Age: | Symptomatic (n [%]): | 1) Lerner score ≥ 3 | | | | Comments:
#2760 | Malmo, Sweden | Median: pre 37.5 | NR | | Dis+ | Dis- | Tot | —Undetectable velocity measures classified as “benign”
| Dates: NR | for post 66 | Detected by exam (n [%]): | T+ | 22 | 53 | 75 | —LMP tumors grouped into malignant
| Size of population: | Range: 18–88 | NR | T- | 2 | 96 | 98 | —Lerner score not described
| 173 women | Menopausal status (n [%]): | Detected by imaging (n [%]): | Tot | 24 | 149 | 173 | Quality assessment:
| Other | Pre: 98 (56.6%) | NR | | | Lower | Upper | Reference standard: +
| Consecutive patients scheduled for surgery in university hospital | Post: 70 (40.5%) | Combination (n [%]): | | Value | 95% CI | 95% CI | Verification bias: +
| Reference standard: | 4 hysterectomy | NR | Se | 91.7% | 80.6% | 100.0% | Test reliability/variability: -
| Histopathology | 1 unknown | Additional data used for diagnosis: | Sp | 64.4% | 56.7% | 72.1% | Sample size: -
| Reference standard applied to all test negatives?: | Race/ethnicity (n [%]): | NR | PPV | 29.3% | 19.0% | 39.6% | Statistical tests: +
| Yes | NR | | NPV | 98.0% | 95.2% | 100.0% | Blinding: -
| Test reliability established?: | Risk factors (n [%]): | | 2) PI < 1.0 | | | | Definition of +/- on screening test: +/-
| Lerner's ? | NR | | | Dis+ | Dis- | Tot
| PI and RI yes | Inclusion criteria: | | T+ | 21 | 81 | 102
| Valentin's Doppler variable - no | Women admitted to hospital for surgery due to pelvic mass during time frame | | T- | 3 | 68 | 71
| Statistical tests used: | Exclusion criteria: | | Tot | 24 | 149 | 173
| Se, Sp | 26 excluded because 10 surgery canceled or replaced with cytology, 13 had normal US preop of whom 9 had normal laparoscopy and 4 had normal US followup | | | | Lower | Upper
| Blinding: | | | | Value | 95% CI | 95% CI
| NR - prospective though | | | Se | 87.5% | 74.3% | 100.0%
| Definition of positive and negative on screening test: | | | Sp | 45.6% | 37.6% | 53.6%
| Lerner's score [4] >3 | | | PPV | 20.6% | 12.7% | 28.4%
| RI < 0.4 | | | NPV | 95.8% | 91.1% | 100.0%
| PI < 1.0 | | | 3) RI < 0.4
| | | | | Dis+ | Dis- | Tot
| | | | T+ | 6 | 7 | 13
| | | | T- | 18 | 142 | 160
| | | | Tot | 24 | 149 | 173
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 25.0% | 7.7% | 42.3%
| | | | Sp | 95.3% | 91.9% | 98.7%
| | | | PPV | 46.2% | 19.1% | 73.3%
| | | | NPV | 88.8% | 83.9% | 93.6%
| | | | Additional analyses for combination ofLerner score ≥3 and Doppler variable positive, combined as “both” or “either” = T+
Valentin, Hagen, Tingulstad, et al., 2001 | Geographical location: | Age: | Symptomatic (n [%]): | 1) “Pattern recognition” (threshold not defined, but referenced) | | | | Comments:
#2340 | Trondheim, Norway, and Malmo, Sweden | NR | NR | | Dis+ | Dis- | Tot | —For CA-125 - unable to get data for 2×2 table as it is reported in Means only
| Dates: NR | Menopausal status (n [%]): | Detected by exam (n [%]): | T+ | 30 | 9 | 39 | —For US - scoring system broken into parts in tables - unable to reassemble to get 2×2 table for US alone
| Size of population: | NR | NR | T- | 6 | 91 | 97 | —Threshold given in references 1 and 2 (Valentin et al, Ultrasound Obstet Gynecol 1999;14:273–83, and 1999:14:338–47)
| 136 | Race/ethnicity (n [%]): | Detected by imaging (n [%]): | Tot | 36 | 100 | 136 | —Clinical presentation not described
| Other | NR | NR | | | Lower | Upper | Quality assessment:
| Prospective validation | Risk factors (n [%]): | Combination (n [%]): | | Value | 95% CI | 95% CI | Reference standard: +
| Reference standard: | NR | NR | Se | 83.3% | 71.2% | 95.5% | Verification bias: -
| Surgery | Inclusion criteria: | Additional data used for diagnosis: | Sp | 91.0% | 85.4% | 96.6% | Test reliability/variability: +
| Reference standard applied to all test negatives?: | Scheduled for surgery for adnexal mass | NR | PPV | 76.9% | 63.7% | 90.1% | Sample size: - (wide CI's)
| Yes | Exclusion criteria: | | NPV | 93.8% | 89.0% | 98.6% | Statistical tests: +
| Test reliability established?: | Surgery cancelled | | | | | | Blinding: -
| Referenced | No histology | | | | | | Definition of +/- on screening test: + (not given here, but referenced)
| Statistical tests used: | Death
| ROC, logistic regression | Multiple lesions in same ovary
| Blinding:
| No
| Definition of positive and negative on screening test:
| “Pattern recognition” referenced, but not described in this paper
van Nagell Jr., DePriest, Reedy, et al., 2000 | Geographical location: | Age: | Symptomatic (n [%]): | 1) For the screened population as a whole | | | | Comments:
#2730 | USA | Mean (SD): 54.7 (10.7) | 0 (0%) | | Dis+ | 5 | Tot | —4 patients developed ovarian CA 12+ months after screen - these were included in the true negative analysis (because they had failed in 12 month followup)
| Dates: 1987 - 1999 | Range: 25–92 | Detected by exam (n [%]): | T+ | 17 | 163 | 180 | —Borderline tumors grouped in with benign
| Size of population: | Menopausal status (n [%]): | 0 (0%) | T- | 4 | 14285 | 14289 | —TVUS only
| 14469 | NR | Detected by imaging (n [%]): | Tot | 21 | 14448 | 14469 | Quality assessment:
| 180with persistently abnormal screens leading to surgery | Race/ethnicity (n [%]): | 180 (1.2%) | | | Lower | Upper | Reference standard: -
| Screening study | NR | Combination (n [%]): | | Value | 95% CI | 95% CI | Verification bias: +
| Reference standard: | Risk factors (n [%]): | NR | Se | 81.0% | 64.2% | 97.7% | Test reliability/variability: -
| Histopathology | NR | Additional data used for diagnosis: | Sp | 98.9% | 98.7% | 99.0% | Sample size:+
| Reference standard applied to all test negatives?: | Inclusion criteria: | NR | PPV | 9.4% | 5.2% | 13.7% | Statistical tests: +
| No | Age >=50 or age >=25 with documented family history of ovarian CA | | NPV | 100.0% | 99.9% | 100.0% | Blinding: +
| Normal screens were repeated in one year | Exclusion criteria: | | 2) Adding the 4 (Table 6) who got CA > 12 months out | | | | Definition of +/- on screening test: +/-
| Abnormal screens were repeated in 4–6 weeks with morphology, CA-125 and Doppler | NR | | | Dis+ | 5 | Tot
| Test reliability established?: | | | T+ | 17 | 163 | 180
| yes | | | T- | 8 | 14281 | 14289
| Statistical tests used: | | | Tot | 25 | 14444 | 14469
| Chi square | | | | | Lower | Upper
| Fisher's exact test | | | | Value | 95% CI | 95% CI
| Kaplan Meier survival curve plotted | | | Se | 68.0% | 49.7% | 86.3%
| Blinding: | | | Sp | 98.9% | 98.7% | 99.0%
| Prospective | | | PPV | 9.4% | 5.2% | 13.7%
| Definition of positive and negative on screening test: | | | NPV | 99.9% | 99.9% | 100.0%
| US - ovarian volume > 20cm3 for premenopausal women, and > 10cm3 for postmenopausal women
| Or any cystic ovarian tumor with a solid or papillary projection into its lumen.
| For subsequent screening DePriest scoring system used with CA-125 and doppler
Vasilev, Schlaerth, Campeau, et al., 1988 | Geographical location: | Age: | Symptomatic (n [%]): | 1) All patients CA-125 ≥ 35 U/ml | | | | Comments:
#6770 | Los Angeles, CA | NR | NR | | Dis+ | Dis- | Tot | —Unclear what implications of “nonconsecutive” are—how many patients not included
| Dates: Mar 1984-Feb 1986 | Menopausal status (n [%]): | Detected by exam (n [%]): | T+ | 14 | 37 | 51 | —Text description does not match data provided in Table 3
| Size of population: | ≤ 50: 152 (83.1%) | NR | T- | 4 | 128 | 132 | —Borderline grouped with malignant
| 182 women | > 50: 31 (17.0%) | Detected by imaging (n [%]): | Tot | 18 | 165 | 183 | Quality assessment:
| Other | Race/ethnicity (n [%]): | NR | | | Lower | Upper | Reference standard: -
| Nonconsecutive case series | NR | Combination (n [%]): | | Value | 95% CI | 95% CI | Verification bias: -
| Reference standard: | Risk factors (n [%]): | NR | Se | 77.8% | 58.6% | 97.0% | Test reliability/variability: +
| Surgery/pathology | NR | Additional data used for diagnosis: | Sp | 77.6% | 71.2% | 83.9% | Sample size: -
| Reference standard applied to all test negatives?: | Inclusion criteria: | NR | PPV | 27.5% | 15.2% | 39.7% | Statistical tests: +
| Yes | Preoperative diagnosis of pelvic mass | | NPV | 97.0% | 94.0% | 99.9% | Blinding: -
| Test reliability established?: | Exclusion criteria: | | 2) Age ≤ 50 | | | | Definition of +/- on screening test: +
| Yes | NR | | | Dis+ | Dis- | Tot
| Statistical tests used: | | | T+ | 6 | 35 | 41
| NR | | | T- | 0 | 111 | 111
| Blinding: | | | Tot | 6 | 146 | 152
| Yes | | | | | Lower | Upper
| Definition of positive and negative on screening test: | | | | Value | 95% CI | 95% CI
| > 35 u/ML | | | Se | 100.00% | 50.00% | 100.00%
| | | | Sp | 76.00% | 69.10% | 83.00%
| | | | PPV | 14.60% | 3.80% | 25.50%
| | | | NPV | 100.00% | 97.30% | 100.00%
| | | | 3) Age > 50
| | | | | Dis+ | Dis- | Tot
| | | | T+ | 8 | 2 | 10
| | | | T- | 4 | 17 | 21
| | | | Tot | 12 | 19 | 31
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 66.7% | 40.0% | 93.3%
| | | | Sp | 89.5% | 75.7% | 100.0%
| | | | PPV | 80.0% | 55.2% | 100.0%
| | | | NPV | 81.0% | 64.2% | 97.7%
Vuento, Pirhonen, Makinen, et al., 1995 | Geographical location: | Age: | Symptomatic (n [%]): | 1) Combined US morphology and Doppler | | | | Comments:
#4070 | Turku, Finland | Mean (SD): 59 | 100% asymptomatic | | Dis+ | Dis- | Tot | —Population based study
| Dates: NR | Range: 56–61 | Detected by exam (n [%]): | T+ | 1 | 159 | 160 | —Some potential for verification bias, but registry capture reasonable alternative
| Size of population: | Menopausal status (n [%]): | NR | T- | 0 | 1204 | 1204 | Quality assessment:
| 1846 in initial pool; 1364 (74%) consented | Post (> 55): 1364 (100%) | Detected by imaging (n [%]): | Tot | 1 | 1363 | 1364 | Reference standard: +
| Screening study | Race/ethnicity (n [%]): | NR | | | Lower | Upper | Verification bias: +
| Reference standard: | NR | Combination (n [%]): | | Value | 95% CI | 95% CI | Test reliability/variability: -
| Cases reported to Finnish Cancer Registry over 2 ½ year followup; true negative considered no cancer within 1 year | Risk factors (n [%]): | NR | Se | 100.0% | 0.0% | 100.0% | Sample size:+
| Reference standard applied to all test negatives?: | Family history: 376 (27.6%) | Additional data used for diagnosis: | Sp | 88.3% | 86.6% | 90.0% | Statistical tests: +
| Yes | Inclusion criteria: | NR | PPV | 0.6% | 0.0% | 1.8% | Blinding: +
| Test reliability established?: | Presenting for mammography | | NPV | 100.0% | 99.8% | 100.0% | Definition of +/- on screening test: +
| Not referenced or described | Exclusion criteria: | | Positive case was borderline
| Statistical tests used: | NR | | 2 cancers, 1 Stage 1A and 1 Stage III, within 2 years
| Chi-square | | | 2) Combined US morphology and Doppler, results of followup US in 160 women with abnormal screening ultrasound on first screen
| Blinding: | | | | Dis+ | Dis- | Tot
| Yes | | | T+ | 1 | 27 | 28
| Definition of positive and negative on screening test: | | | T- | 0 | 132 | 132
| Negative: not visualized, volume less than 8 cc, uniformly hypoechogenic; PI < 1.0 - lowest measured value used | | | Tot | 1 | 159 | 160
| US - Fleischer criteria | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 100.0% | 0.0% | 100.0%
| | | | Sp | 83.0% | 77.2% | 88.9%
| | | | PPV | 3.6% | 0.0% | 10.4%
| | | | NPV | 100.0% | 97.7% | 100.0%
Wakahara, Kikkawa, Nawa, et al., 2001 | Geographical location: | Age: | Symptomatic (n [%]): | 1) Ultrasound—Including borderline as cancer | | | | Comments:
#2370 | Nagoya, Japan | Mean (SD): 40.3 | NR | | Dis+ | Dis- | Tot | —Clinical presentation not described
| Dates: 1994-1999 | Range: 11–79 | Detected by exam (n [%]): | T+ | 69 | 37 | 106 | —Not stratified by menopausal status
| Size of population: | Menopausal status (n [%]): | NR | T- | 15 | 171 | 186 | Quality assessment:
| 292 women | NR | Detected by imaging (n [%]): | Tot | 84 | 208 | 292 | Reference standard: +
| Other | Race/ethnicity (n [%]): | NR | | | Lower | Upper | Verification bias: +
| Case series | NR | Combination (n [%]): | | Value | 95% CI | 95% CI | Test reliability/variability: -
| Reference standard: | Risk factors (n [%]): | NR | Se | 82.1% | 74.0% | 90.3% | Sample size: -
| Surgery/pathology | NR | Additional data used for diagnosis: | Sp | 82.2% | 77.0% | 87.4% | Statistical tests: +
| Reference standard applied to all test negatives?: | Inclusion criteria: | NR | PPV | 65.1% | 56.0% | 74.2% | Blinding: -
| Yes | Presence of adnexal mass, scheduled for surgery | | NPV | 91.9% | 88.0% | 95.8% | Definition of +/- on screening test: +
| Test reliability established?: | Exclusion criteria: | | 2) Ultrasound—classifying borderline as benign
| Not referenced or discussed | NR | | | Dis+ | Dis- | Tot
| Statistical tests used: | | | T+ | 57 | 49 | 106
| Se/Sp | | | T- | 9 | 177 | 186
| Blinding: | | | Tot | 66 | 226 | 292
| Yes | | | | | Lower | Upper
| Definition of positive and negative on screening test: | | | | Value | 95% CI | 95% CI
| Positive ultrasound: cyst with irregular solid component or thickened septum, or solid mass. | | | Se | 86.4% | 78.1% | 94.6%
| Ultrasound interpretation by gyn oncologist, not radiologist | | | Sp | 78.3% | 72.9% | 83.7%
| CA-125: 35 U/mL | | | PPV | 53.8% | 44.3% | 63.3%
| CA-19-9: 37 IU/mL | | | NPV | 95.2% | 92.1% | 98.2%
| CA-72-4: 4 U/mL | | | 3) CA-125 > 35 U/ml; borderline classified as malignant
| | | | | Dis+ | Dis- | Tot
| | | | T+ | 62 | 22 | 84
| | | | T- | 77 | 131 | 208
| | | | Tot | 139 | 153 | 292
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 44.6% | 36.3% | 52.9%
| | | | Sp | 85.6% | 80.1% | 91.2%
| | | | PPV | 73.8% | 64.4% | 83.2%
| | | | NPV | 63.0% | 56.4% | 69.5%
| | | | 4) CA-125 > 35 U/ml; borderline classified as benign
| | | | | Dis+ | Dis- | Tot
| | | | T+ | 51 | 88 | 139
| | | | T- | 15 | 138 | 153
| | | | Tot | 66 | 226 | 292
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 77.3% | 67.2% | 87.4%
| | | | Sp | 61.1% | 54.7% | 67.4%
| | | | PPV | 36.7% | 28.7% | 44.7%
| | | | NPV | 90.2% | 85.5% | 94.9%
| | | | 5) CA 19-9 > 37 IU/ml, borderline classified as malignant
| | | | | Dis+ | Dis- | Tot
| | | | T+ | 29 | 78 | 107
| | | | T- | 55 | 127 | 182
| | | | Tot | 84 | 205 | 289
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 34.5% | 24.4% | 44.7%
| | | | Sp | 62.0% | 55.3% | 68.6%
| | | | PPV | 27.1% | 18.7% | 35.5%
| | | | NPV | 69.8% | 63.1% | 76.5%
| | | | 6) CA 19-9 >37 IU/ml, Borderline classified as benign
| | | | | Dis+ | Dis- | Tot
| | | | T+ | 24 | 83 | 107
| | | | T- | 42 | 140 | 182
| | | | Tot | 66 | 223 | 289
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 36.4% | 24.8% | 48.0%
| | | | Sp | 62.8% | 56.4% | 69.1%
| | | | PPV | 22.4% | 14.5% | 30.3%
| | | | NPV | 76.9% | 70.8% | 83.0%
| | | | 7) CA-72-4 > 4 U/ml, borderline classified as malignant
| | | | | Dis+ | Dis- | Tot
| | | | T+ | 23 | 18 | 41
| | | | T- | 28 | 104 | 132
| | | | Tot | 51 | 122 | 173
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 45.1% | 31.4% | 58.8%
| | | | Sp | 85.2% | 79.0% | 91.5%
| | | | PPV | 56.1% | 40.9% | 71.3%
| | | | NPV | 78.8% | 71.8% | 85.8%
| | | | 8) CA-72-4 > 4 U/ml, borderline classified as benign
| | | | | Dis+ | Dis- | Tot
| | | | T+ | 20 | 21 | 41
| | | | T- | 20 | 116 | 136
| | | | Tot | 40 | 137 | 177
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 50.0% | 34.5% | 65.5%
| | | | Sp | 84.7% | 78.6% | 90.7%
| | | | PPV | 48.8% | 33.5% | 64.1%
| | | | NPV | 85.3% | 79.3% | 91.2%
Weiner, Thaler, Beck, et al., 1992 | Geographical location: | Age: | Symptomatic (n [%]): | 1) CA-125 > 35 U/ml | | | | Comments:
#6480 | Haifa, Israel | Range: 20–69 | NR | | Dis+ | Dis- | Tot | —LMP grouped with malignant for analysis
| Dates: NR | Menopausal status (n [%]): | Detected by exam (n [%]): | T+ | 14 | 14 | 28 | —Classification of sonographic findings unclear [7] reference doesn't illuminate scoring system
| Size of population: | NR | NR | T- | 3 | 22 | 25 | —PPV for CA-125 reported in article as 45% (this may be typographical error)
| 62 women | Race/ethnicity (n [%]): | Detected by imaging (n [%]): | Tot | 17 | 36 | 53 | —Borderline cystadenocarcinomas are classified as malignant in 2×2 tables
| Other | NR | NR | | | Lower | Upper | Quality assessment:
| Prospective surgical candidates in single center | Risk factors (n [%]): | Combination (n [%]): | | Value | 95% CI | 95% CI | Reference standard: +
| Reference standard: | NR | NR | Se | 82.4% | 64.2% | 100.0% | Verification bias: +
| Histopathology | Inclusion criteria: | Additional data used for diagnosis: | Sp | 61.1% | 45.2% | 77.0% | Test reliability/variability:
| Reference standard applied to all test negatives?: | Women referred to US department for suspicion of pelvic tumor 62 referred - 9 with cysts that disappeared after 6 weeks | NR | PPV | 50.0% | 31.5% | 68.5% | + for CA-125 and PI
| No - 9 had “functional cysts” which had regressed on followup US | Exclusion criteria: | | NPV | 88.0% | 75.3% | 100.0% | - for US
| Test reliability established?: | NR | | 2) PI < 1.0 | | | | Sample size: -
| CA-125 - yes | | | | Dis+ | Dis- | Tot | Statistical tests: +
| PI +/- | | | T+ | 16 | 1 | 17 | Blinding: -
| Statistical tests used: | | | T- | 1 | 35 | 36 | Definition of +/- on screening test:
| Se, Sp | | | Tot | 17 | 36 | 53 | + for CA-125 and PI
| Blinding: | | | | | Lower | Upper | - for US
| NR - prospective study | | | | Value | 95% CI | 95% CI
| Definition of positive and negative on screening test: | | | Se | 94.1% | 82.9% | 100.0%
| CA-125 > 35 U/ml | | | Sp | 97.2% | 91.9% | 100.0%
| PI < 1.0 | | | PPV | 94.1% | 82.9% | 100.0%
| US - {7} - not described | | | NPV | 97.2% | 91.9% | 100.0%
| | | | 3) US
| | | | | Dis+ | Dis- | Tot
| | | | T+ | 16 | 11 | 27
| | | | T- | 1 | 25 | 26
| | | | Tot | 17 | 36 | 53
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 94.1% | 82.9% | 100.0%
| | | | Sp | 69.4% | 54.4% | 84.5%
| | | | PPV | 59.3% | 40.7% | 77.8%
| | | | NPV | 96.2% | 88.8% | 100.0%
Woolas, Conaway, Xu, et al., 1995 | Geographical location: | Age: | Symptomatic (n [%]): | 1) CA-125 > 35 U/ml | | | | Comments:
#4140 | Durham, NC, and London, UK | NR | NR | | Dis+ | Dis- | Tot | —Clinical presentation not described
| Dates: NR | Menopausal status (n [%]): | Detected by exam (n [%]): | T+ | 150 | 55 | 205 | —Spectrum of disease (cancer stage distribution) adequately described
| Size of population: | NR | All patients with “clinically detected masses” | T- | 42 | 182 | 224 | —Unclear how subjects selected (random, consecutive, or to approximated distribution of disease
| 429 | Race/ethnicity (n [%]): | Detected by imaging (n [%]): | Tot | 192 | 237 | 429 | —Not stratified by age or menopausal status
| Other | NR | NR | | | Lower | Upper | —Prevalence of cancer higher than would be expected in general population
| Series from two hospitals | Risk factors (n [%]): | Combination (n [%]): | | Value | 95% CI | 95% CI | Quality assessment:
| Reference standard: | NR | NR | Se | 78.1% | 72.3% | 83.9% | Reference standard: +
| Surgery, pathology | Inclusion criteria: | Additional data used for diagnosis: | Sp | 76.8% | 71.4% | 82.2% | Verification bias: +
| Reference standard applied to all test negatives?: | NR | 148 primary ovarian cancers | PPV | 73.2% | 67.1% | 79.2% | Test reliability/variability: +
| Yes | Exclusion criteria: | 26% Stage I | NPV | 81.3% | 76.1% | 86.4% | Sample size: +
| Test reliability established?: | NR | 3% Stage II | 2) M-CSF | | | | Statistical tests: +
| Yes | | 55% Stage III | | Dis+ | Dis- | Tot | Blinding: +
| Statistical tests used: | | 16% Stage IV | T+ | 127 | 57 | 184 | Definition of +/- on screening test: +
| ROC, logistic modeling | | | T- | 65 | 180 | 245
| Blinding: | | | Tot | 192 | 237 | 429
| Not described | | | | | Lower | Upper
| Definition of positive and negative on screening test: | | | | Value | 95% CI | 95% CI
| CA-125: 35 u/ML | | | Se | 66.2% | 59.5% | 72.9%
| M-CSF: 3.1 ng/ml | | | Sp | 76.0% | 70.6% | 81.4%
| OVX 1: 12.1 U/mL | | | PPV | 69.0% | 62.3% | 75.7%
| LASA: 200.0 mg/ml | | | NPV | 73.5% | 67.9% | 79.0%
| CA 15-3: 32.0 u/ml | | | 3) OVX1
| CA-72-4: 3.8 u/ml | | | | Dis+ | Dis- | Tot
| CA 19-9: 39.0 u/ml | | | T+ | 77 | 41 | 118
| CA 54/61: 20.0 u/ml | | | T- | 115 | 196 | 311
| | | | Tot | 192 | 237 | 429
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 40.1% | 33.2% | 47.0%
| | | | Sp | 82.7% | 77.9% | 87.5%
| | | | PPV | 65.3% | 56.7% | 73.8%
| | | | NPV | 63.0% | 57.7% | 68.4%
| | | | 4) LASA
| | | | | Dis+ | Dis- | Tot
| | | | T+ | 100 | 29 | 129
| | | | T- | 92 | 208 | 300
| | | | Tot | 192 | 237 | 429
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 52.1% | 45.0% | 59.2%
| | | | Sp | 87.8% | 83.6% | 92.0%
| | | | PPV | 77.5% | 70.3% | 84.7%
| | | | NPV | 69.3% | 64.1% | 74.6%
| | | | 5) CA 15-3
| | | | | Dis+ | Dis- | Tot
| | | | T+ | 120 | 32 | 152
| | | | T- | 72 | 205 | 277
| | | | Tot | 192 | 237 | 429
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 62.5% | 55.7% | 69.3%
| | | | Sp | 86.5% | 82.1% | 90.9%
| | | | PPV | 78.9% | 72.5% | 85.4%
| | | | NPV | 74.0% | 68.8% | 79.2%
| | | | 6) CA-72-4
| | | | | Dis+ | Dis- | Tot
| | | | T+ | 104 | 20 | 124
| | | | T- | 88 | 217 | 305
| | | | Tot | 192 | 237 | 429
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 54.2% | 47.2% | 61.2%
| | | | Sp | 91.6% | 88.1% | 95.1%
| | | | PPV | 83.9% | 77.4% | 90.3%
| | | | NPV | 71.1% | 66.1% | 76.2%
| | | | 7) CA 19-9
| | | | | Dis+ | Dis- | Tot
| | | | T+ | 46 | 28 | 74
| | | | T- | 146 | 209 | 355
| | | | Tot | 192 | 237 | 429
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 24.0% | 18.0% | 30.0%
| | | | Sp | 88.2% | 84.1% | 92.3%
| | | | PPV | 62.2% | 51.1% | 73.2%
| | | | NPV | 58.9% | 53.8% | 64.0%
| | | | 8) CA 54/61
| | | | | Dis+ | Dis- | Tot
| | | | T+ | 100 | 28 | 128
| | | | T- | 92 | 209 | 301
| | | | Tot | 192 | 237 | 429
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 52.1% | 45.0% | 59.2%
| | | | Sp | 88.2% | 84.1% | 92.3%
| | | | PPV | 78.1% | 71.0% | 85.3%
| | | | NPV | 69.4% | 64.2% | 74.6%
Wu, Lee, Chen, et al., 1994 | Geographical location: | Age: | Symptomatic (n [%]): | 1) RI < 0.4 | | | | Comments:
#10900 | Taiwan | Range: 11–81 | NR | | Dis+ | Dis- | Tot | —Clinical pathway not described
| Dates: Jul 1990 - Dec 1993 | Menopausal status (n [%]): | Detected by exam (n [%]): | T+ | 70 | 8 | 78 | —Combined TVUS and abdominal US (no N for each reported) unable to stratify
| Size of population: | NR | NR | T- | 33 | 299 | 332 | Quality assessment:
| 410 | Race/ethnicity (n [%]): | Detected by imaging (n [%]): | Tot | 103 | 307 | 410 | Reference standard: +
| Case series | NR | NR | | | Lower | Upper | Verification bias: +
| Reference standard: | Risk factors (n [%]): | Combination (n [%]): | | Value | 95% CI | 95% CI | Test reliability/variability:
| Histopathology | NR | NR | Se | 68.0% | 59.0% | 77.0% | Sample size:
| Reference standard applied to all test negatives?: | Inclusion criteria: | Additional data used for diagnosis: | Sp | 97.4% | 95.6% | 99.2% | Statistical tests:
| Yes | Suspected malignancy on the basis of suspicious ultrasound | NR | PPV | 89.7% | 83.0% | 96.5% | Blinding:
| Test reliability established?: | Exclusion criteria: | | NPV | 90.1% | 86.8% | 93.3% | Definition of +/- on screening test:
| Yes | Patients examined during luteal phase
| Statistical tests used:
| Chi square
| Fisher exact
| Student t test
| Linear regression
| Blinding:
| Not mentioned (prospective)
| Definition of positive and negative on screening test:
| Positive: RI > 0.4
Yamashita, Hatanaka, Torashima, et al., 1997 | Geographical location: | Age: | Symptomatic (n [%]): | 1) LR model (validation set) cutoff = 0.49 | | | | Comments:
#6120 | Japan | NR | NR | | Dis+ | Dis- | Tot | —Low malignant potential treated as malignant in this analysis.
| Dates: NR | Menopausal status (n [%]): | Detected by exam (n [%]): | T+ | 21 | 4 | 25 | —LR model fit 5 variables to 50 positive cases (at limit of 1:10 rule of thumb)
| Size of population: | NR | NR | T- | 7 | 43 | 50 | —2×2 table reported to validation doesn't match articles reported Se, Sp. Our abstraction based on 2×2 table.
| 104 women | Race/ethnicity (n [%]): | Detected by imaging (n [%]): | Tot | 28 | 47 | 75 | —Validation in separate data set.
| Other | NR | 100% ultrasound | | | Lower | Upper | Quality assessment:
| MRI series | Risk factors (n [%]): | Combination (n [%]): | | Value | 95% CI | 95% CI | Reference standard: +
| Reference standard: | NR | NR | Se | 75.0% | 59.0% | 91.0% | Verification bias:
| Histopathology | Inclusion criteria: | Additional data used for diagnosis: | Sp | 91.5% | 83.5% | 99.5% | Test reliability/variability: -
| Reference standard applied to all test negatives?: | Ovarian masses and MRI to further investigate indeterminate ultrasound | LR model | PPV | 84.0% | 69.6% | 98.4% | Sample size: -
| Yes | Exclusion criteria: | Logit(y)= | NPV | 86.0% | 76.4% | 95.6% | Statistical tests: +
| Test reliability established?: | NR | -2.7 + 0.4 (tumor size) | | | | | Blinding: +
| No | | + 1.8 (ascites) | | | | | Definition of +/- on screening test: -, cutoff was data driven.
| Statistical tests used: | | + 1.4 (bilateral)
| LR | | + 0.5 (complex internal architecture)
| Blinding: | | + 1.6 (solid or irregular wall structure)
| Yes for MRI, independent interpretation by 3 radiologists - surgical and pathological reports were not available | | Where tumor size (cm), other variables scored 1if present; 0 if absent.
| Definition of positive and negative on screening test: | | Best discrimination obtained in test set with cutoff our 0.49.
| MRI evaluated for 1) size; 2) bilaterality; 3) wall structure; 4) internal architectures; 5) presence of thick (< 3 mm) septa; 6) signal intensity; 7) ascites
Yamashita, Torashima, Hatanaka, et al., 1995 | Geographical location: | Age: | Symptomatic (n [%]): | 1) Transvaginal ultrasound, benign vs malignant, all readings by 5 radiologists (results presented by lesion, not patient; 19 patients had malignancy, 61 benign lesions) | | | | Comments:
#4290 | Kumamoto, Japan | Mean (SD): 43 | NR | | Dis+ | Dis- | Tot | —Observer variability measured
| Dates: NR | Range: 13–74 | Detected by exam (n [%]): | T+ | 17 | 10 | 27 | Kappa 0.71 for pre-contrast MRI, 0.73 for contrast enhanced MRI, 0.62 for transvaginal ultrasound
| Size of population: | Menopausal status (n [%]): | NR | T- | 2 | 51 | 53 | —Se/Sp calculated by lesion, not patient—CI's subsequently smaller
| 72 women | NR | Detected by imaging (n [%]): | Tot | 19 | 61 | 80 | —Not stratified by age, menopausal status
| 80 masses | Race/ethnicity (n [%]): | NR | | | Lower | Upper | —Clinical presentation not described
| Other | NR; presumably 100% Asian | Combination (n [%]): | | Value | 95% CI | 95% CI | LMP tumors grouped in with malignant
| Consecutive case series | Risk factors (n [%]): | NR | Se | 89.0% | 74.9% | 100.0% | Quality assessment:
| Reference standard: | NR | Additional data used for diagnosis: | Sp | 84.0% | 74.8% | 93.2% | Reference standard: +
| Surgery/pathology | Inclusion criteria: | NR | PPV | 63.0% | 44.7% | 81.2% | Verification bias: +
| Reference standard applied to all test negatives?: | Pelvic mass, scheduled for surgery | | NPV | 96.2% | 91.1% | 100.0% | Test reliability/variability: +
| Yes | Exclusion criteria: | | 2) Preconstrast MRI, benign vs malignant | | | | Sample size: -
| Test reliability established?: | NR | | | Dis+ | Dis- | Tot | Statistical tests: +
| Inter-rater reliability measured | | | T+ | 15 | 4 | 19 | Blinding: +
| Statistical tests used: | | | T- | 4 | 57 | 61 | Definition of +/- on screening test: +
| ROC, kappa | | | Tot | 19 | 61 | 80
| Blinding: | | | | | Lower | Upper
| Yes | | | | Value | 95% CI | 95% CI
| Definition of positive and negative on screening test: | | | Se | 78.0% | 59.4% | 96.6%
| Benign if 3 of 4 criteria:; - Diameter ≤ 4 cm; - Entirely cystic; - Lesion wall < 3mm; - No internal structure | | | Sp | 93.0% | 86.6% | 99.4%
| Malignancy if 2 of 5 criteria:; - Diameter > 4 cm; - Wall or septum > 3mm; - Nodularity, vegetations, or large solid component; - Necrosis or hemorrhage in lesion | | | PPV | 78.9% | 60.6% | 97.3%
| And/or if any 1 of the following criteria:; - Involvement of adjacent organs or pelvic sidewall; - Peritoneal, mesenteric, or omental lesions; - Ascites; - Adenopathy | | | NPV | 93.4% | 87.2% | 99.7%
| Borderline tumors classified as malignant | | | 3) Contrast-enhanced MRI, benign vs malignant
| | | | | Dis+ | Dis- | Tot
| | | | T+ | 17 | 4 | 21
| | | | T- | 2 | 57 | 59
| | | | Tot | 19 | 61 | 80
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 91.0% | 78.1% | 100.0%
| | | | Sp | 93.0% | 86.6% | 99.4%
| | | | PPV | 81.0% | 64.2% | 97.7%
| | | | NPV | 96.6% | 92.0% | 100.0%
Zanetta, Vergani, and Lissoni, 1994 | Geographical location: | Age: | Symptomatic (n [%]): | 1) US Sassone | | | | Comments:
#10850 | Milan, Italy | NR | 71(88.8%) | | Dis+ | Dis- | Tot | —N = 80 however, n = 78 for all the cases that they report
| Dates: May 1992 - May 1993 | Menopausal status (n [%]): | Detected by exam (n [%]): | T+ | 32 | 11 | 43 | —Borderline grouped with malignant
| Size of population: | NR | NR | T- | 1 | 36 | 37 | —Overlap in both RI and PI noted in malignant and benign lesions
| 80 | Race/ethnicity (n [%]): | Detected by imaging (n [%]): | Tot | 33 | 47 | 80 | —TVUS only
| Case series | NR | 5(6.3%) (infertility work up imaging) | | | Lower | Upper | Quality assessment:
| Reference standard: | Risk factors (n [%]): | Combination (n [%]): | | Value | 95% CI | 95% CI | Reference standard: +
| Histopathology | NR | NR | Se | 97.0% | 91.2% | 100.0% | Verification bias: +
| Reference standard applied to all test negatives?: | Inclusion criteria: | Additional data used for diagnosis: | Sp | 76.0% | 63.8% | 88.2% | Test reliability/variability: -
| Yes | Surgical referral to hospital secondary to mass | 4 (5%) referred for abdominal enlargement but were asymptomatic | PPV | 74.4% | 61.4% | 87.5% | Sample size: -
| Test reliability established?: | Exclusion criteria: | | NPV | 97.3% | 92.1% | 100.0% | Statistical tests: +
| Yes | NR | | 2) CA 126 > 30 | | | | Blinding: +/-
| Statistical tests used: | | | | Dis+ | Dis- | Tot | Definition of +/- on screening test: +
| Se, Sp | | | T+ | 30 | 19 | 49
| Blinding: | | | T- | 3 | 28 | 31
| Not mentioned (prospective) | | | Tot | 33 | 47 | 80
| Definition of positive and negative on screening test: | | | | | Lower | Upper
| US morphology - Sassone's criteria | | | | Value | 95% CI | 95% CI
| Doppler: | | | Se | 91.0% | 81.2% | 100.0%
| PI>=1.0 | | | Sp | 60.0% | 46.0% | 74.0%
| RI range investigated (0.50, 0.56, 0.60) | | | PPV | 61.2% | 47.6% | 74.9%
| CA-125 >30U/ml | | | NPV | 90.3% | 79.9% | 100.0%
| | | | 3) PI 1.0
| | | | | Dis+ | Dis- | Tot
| | | | T+ | 32 | 6 | 38
| | | | T- | 1 | 41 | 42
| | | | Tot | 33 | 47 | 80
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 97.0% | 91.2% | 100.0%
| | | | Sp | 87.0% | 77.4% | 96.6%
| | | | PPV | 84.2% | 72.6% | 95.8%
| | | | NPV | 97.6% | 93.0% | 100.0%
| | | | 4) RI 0.60
| | | | | Dis+ | Dis- | Tot
| | | | T+ | 30 | 7 | 37
| | | | T- | 3 | 40 | 43
| | | | Tot | 33 | 47 | 80
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 91.0% | 81.2% | 100.0%
| | | | Sp | 85.0% | 74.8% | 95.2%
| | | | PPV | 81.1% | 68.5% | 93.7%
| | | | NPV | 93.0% | 85.4% | 100.0%
| | | | 5) RI 0.56
| | | | | Dis+ | Dis- | Tot
| | | | T+ | 28 | 4 | 32
| | | | T- | 5 | 43 | 48
| | | | Tot | 33 | 47 | 80
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 85.0% | 72.8% | 97.2%
| | | | Sp | 91.0% | 82.8% | 99.2%
| | | | PPV | 87.5% | 76.0% | 99.0%
| | | | NPV | 89.6% | 80.9% | 98.2%
| | | | 6) RI 0.50
| | | | | Dis+ | Dis- | Tot
| | | | T+ | 22 | 2 | 24
| | | | T- | 11 | 45 | 56
| | | | Tot | 33 | 47 | 80
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 67.0% | 51.0% | 83.0%
| | | | Sp | 96.0% | 90.4% | 100.0%
| | | | PPV | 91.7% | 80.6% | 100.0%
| | | | NPV | 80.4% | 70.0% | 90.8%
Zhang, Barnhill, Zhang, et al., 1999 | Geographical location: | Age: | Symptomatic (n [%]): | 2) CA-125 > 35 U/ml | | | | Comments:
#3020 | London, England | NR | NR | | Dis+ | Dis- | Tot | —Training set originally contained non-epithelial ovarian cancer and other cancers as well as non-ovarian benign conditions but the ANN couldn't be trained so they narrowed the training set to epithelial ovarian malignancy vs known benign ovarian conditions. This may be less applicable to real life than leaving all the other conditions in as well.
| Dates: NR | Menopausal status (n [%]): | Detected by exam (n [%]): | T+ | 75 | 29 | 104 | Quality assessment:
| Size of population: | NR | NR | T- | 6 | 57 | 63 | Reference standard: +
| 429 women | Race/ethnicity (n [%]): | Detected by imaging (n [%]): | Tot | 81 | 86 | 167 | Verification bias: -
| Registry | NR | NR | | | Lower | Upper | Test reliability/variability: -
| Reference standard: | Risk factors (n [%]): | Combination (n [%]): | | Value | 95% CI | 95% CI | Sample size: +
| Pathology | NR | NR | Se | 92.6% | 86.9% | 98.3% | Statistical tests: +
| Reference standard applied to all test negatives?: | Inclusion criteria: | Additional data used for diagnosis: | Sp | 66.3% | 56.3% | 76.3% | Blinding: -
| Yes | Pelvic mass/had pathology | NR | PPV | 72.1% | 63.5% | 80.7% | Definition of +/- on screening test: -
| Test reliability established?: | Exclusion criteria: | | NPV | 90.5% | 83.2% | 97.7%
| Statistical tests used: | NR
| Se, Sp, ROC
| Blinding:
| NR
| Definition of positive and negative on screening test:
| Artificial Neural Network (ANN), cutoff 0.5
| Ca 125 > 35U/ml
Zimmer, Tepper, and Akselrod, 2003 | Geographical location: | Age: | Symptomatic (n [%]): | 1) Benign vs malignant, from 28 preoperative images | | | | Comments:
#1740 | Dates: NR | NR | NR | | Dis+ | Dis- | Tot | —Clinical presentation not described
| Size of population: | Menopausal status (n [%]): | Detected by exam (n [%]): | T+ | 20 | 0 | 20 | —Spectrum of disease not described
| 28 images; number of patients not described | NR | NR | T- | 5 | 3 | 8 | Quality assessment:
| Other | Race/ethnicity (n [%]): | Detected by imaging (n [%]): | Tot | 25 | 3 | 28 | Reference standard: +
| Development of quantitative analytic method for ultrasound images; initial validation | NR | NR | | | Lower | Upper | Verification bias: -
| Reference standard: | Risk factors (n [%]): | Combination (n [%]): | | Value | 95% CI | 95% CI | Test reliability/variability: -
| Presumably surgery/pathology | NR | NR | Se | 80.0% | 64.3% | 95.7% | Sample size: -
| Reference standard applied to all test negatives?: | Inclusion criteria: | Additional data used for diagnosis: | Sp | 100.0% | 0.0% | 100.0% | Statistical tests: -
| Yes | NR | NR | PPV | 100.0% | 85.0% | 100.0% | Blinding: + (computerized)
| Test reliability established?: | Exclusion criteria: | | NPV | 37.5% | 4.0% | 71.0% | Definition of +/- on screening test: +
| Not described | NR
| Statistical tests used:
| Not described
| Blinding:
| Yes
| Definition of positive and negative on screening test:
| Algorithm based on lesion size, structure, turbidity, amount of solid material

Evidence Table 4. Question 4: What is the accuracy of explicit scoring systems which incorporate various combinations of imaging findings, patient risk factors, and/or CA-125 levels for detecting malignancy? Have these scoring systems been applied to a population of women before laparoscopy or laparotomy?

Study | Study Design | Patients | Clinical Presentation | Items Included in Scoring System | Results | | | | Comments/Quality Scoring
Adonakis, Para-skevaidis, Tsiga, et al., 1996 | Geographical location: | Age: | Symptomatic (n [%]): | 1) TVUS criteria for abnormal include any of the following: a) abnormal morphology - hyper- or hypo-echoic; b) irregular “outline;” c) volume > 18 ml for premenopausal and > 9 ml for postmenopausal women | 1) PE + CA-125 (“ambiguous” PE considered abnormal; no histological verification of test negatives) | | | | Comments:
#810 | Ioannina, Greece | Mean: 58.1 | NR | 2) CA-125 > 35 U/ml | | Dis+ | Dis- | Tot | —2×2 tables constructed from Table 2 and data reported in text; not able to reproduce the Se, Sp and PPV reported in Table 3 of manuscript
| Dates: | Range: 45–80 | Detected by exam (n [%]): | 3) Pelvic examination abnormal when there is a palpable adnexal mass | T+ | 3 | 177 | 180 | —Only one followup visit was required for patients with negative screening - some patients who subsequently developed cancer could have been missed
| Mar 1991-Jun 1993 | Menopausal status (n [%]): | NR | | T- | 0 | 1820 | 1820 | Quality assessment:
| Size of population: | Pre: 1302 | Detected by imaging (n [%]): | | Tot | 3 | 1997 | 2000 | Reference standard: +
| 2000 screened | Peri: 293 | 59 | | | | Lower | Upper | Verification bias: - (only one followup visit was required for test negatives who did not have surgery)
| Screening study | Post: 405 | 115 with “ambiguous” exam | | | Value | 95% CI | 95% CI | Test reliability/variability: -
| Reference standard: | Race/ethnicity | Combination (n [%]): | | Se | 100.0% | 0.0% | 100.0% | Sample size: +
| Histology or followup (at least 1 visit with CA-125 1 year later) | (n [%]): | NR | | Sp | 91.1% | 89.9% | 92.4% | Statistical tests: - (not enough data given to reproduce results reported)
| Reference standard applied to all test negatives?: | NR | Additional data used for diagnosis: | | PPV | 1.7% | 0.0% | 3.5% | Blinding: -
| Yes | Risk factors (n [%]): | NR | | NPV | 100.0% | 99.8% | 100.0% | Definition of +/- on screening test: +
| Statistical tests used: | NR | | | 2) PE + CA-125 (“ambiguous” PE considered normal; no histological verification of 145 TVUS test negatives) | | | | Explicit validation method?: -
| Se, Sp, PPV | Inclusion criteria: | | | | Dis+ | Dis- | Tot
| Blinding: | Age ≥45 years “without any evidence of adnexal pathology” | | | T+ | 2 | 63 | 65
| No | Exclusion criteria: | | | T- | 1 | 114 | 115
| Definition of positive and negative on screening test: | Prior history of ovarian cancer, any other malignancy, bilateral salpingo-oophorectomy or ascites | | | Tot | 3 | 177 | 180
| See Scoring column | | | | | | Lower | Upper
| | | | | | Value | 95% CI | 95% CI
| | | | | Se | 66.7% | 13.3% | 100.0%
| | | | | Sp | 64.4% | 57.4% | 71.5%
| | | | | PPV | 3.1% | 0.0% | 7.3%
| | | | | NPV | 99.1% | 97.4% | 100.0%
| | | | | 3) PE + CA-125 +TVUS (“ambiguous” PE considered normal; no histological verification of 145 TVUS test negatives)
| | | | | | Dis+ | Dis- | Tot
| | | | | T+ | 3 | 68 | 71
| | | | | T- | 0 | 109 | 109
| | | | | Tot | 3 | 177 | 180
| | | | | | | Lower | Upper
| | | | | | Value | 95% CI | 95% CI
| | | | | Se | 100.0% | 0.0% | 100.0%
| | | | | Sp | 61.6% | 54.4% | 68.7%
| | | | | PPV | 4.2% | 0.0% | 8.9%
| | | | | NPV | 100.0% | 97.2% | 100.0%
Alcazar, Errasti, Zornoza, et al., 1999 | Geographical location: | Age: | Symptomatic (n [%]): | 1) CA-125 ≥ 35 U/ml | 1) Combination of RI ≤ 0.4 and CA-125 ≥ 35 U/ml | | | | Quality assessment:
#3110 | Pamplona, Spain | Mean: 47.4 | NR | 2) RI ≤ 0.4 | | Dis+ | Dis- | Tot | Reference standard: +
| Dates: | Range: 17–79 | Detected by exam (n [%]): | | T+ | 42 | 1 | 43 | Verification bias: +
| Jan 1995-Feb 1998 | Menopausal status (n [%]): | NR | | T- | 14 | 37 | 51 | Test reliability/variability: -
| Size of population: | Pre: 52 (55.3%) | Detected by imaging (n [%]): | | Tot | 56 | 38 | 94 | Sample size -
| 94 women of 480 women screened: | Post: 42 (44.7%) | All 100% | | | | Lower | Upper | Statistical tests: +
| Registry | Race/ethnicity (n [%]): | Combination (n [%]): | | | Value | 95% CI | 95% CI | Blinding: -
| Retrospective single-institution series | NR | NR | | Se | 75.0% | 63.7% | 86.3% | Definition of +/- on screening test: +
| Reference standard: | Risk factors (n [%]): | Additional data used for diagnosis: | | Sp | 97.4% | 92.3% | 100.0% | Explicit validation method?: -
| Histopathology | NR | Morphological evaluation including presence of at least one of: Multilocularity, gross septations (> 3 mm), gross papillary projections (> 3 mm), solid wall nodules, irregular borders, solid mass or ascites | | PPV | 97.7% | 93.2% | 100.0%
| Reference standard applied to all test negatives?: | Inclusion criteria: | | | NPV | 72.5% | 60.3% | 84.8%
| Yes | Diagnosed as having an adnexal mass and sonographically suspicious findings; transvaginal color Doppler and CA-125 level before surgery; and definitive histopathological diagnosis
| Statistical tests used: | Exclusion criteria:
| Se, Sp, ROC curves/AUC | NR
| Blinding:
| No
| Definition of positive and negative on screening test:
| Yes
Andersen, Knudsen, Rix, et al., 2003 | Geographical location: | Age: | Symptomatic (n [%]): | 1) CA-125 Absolute value of serum CA-125 (IMX, Abbott Labs) | 1) RMI2 (among all patients; 45 of whom had clinical followup in lieu of histopathological diagnosis) | | | | Comments:
#1810 | Northern Jutland, Denmark | Range: 30 or older | NR | 2) Ultrasound score (U; transvaginal) based on presence of the following factors: solid areas (1) multilocularity (1) bilaterality (1) ascites (1) extraovarian tumors (1) | Test + = RMI2 ≥ 200 | | | | —No data on pre- versus postmenopausal women
| Dates: | Menopausal status (n [%]): | Detected by exam (n [%]): | If total ≥ 2, then U = 4 | Test - =RMI2 < 200 | | | | —Predictive value of ultrasound and CA-125 in postmenopausal women cannot be estimated from this report
| Jul 1999-Aug 2001 | NR | NR | If total < 2, then U = 1 | | Dis+ | Dis- | Tot | —Included borderline as malignant category
| Size of population: | Race/ethnicity (n [%]): | Detected by imaging (n [%]): | 3) Menopausal score (M): Postmenopausal (> 1 year of amenorrhea) = 4 Premenopausal = 1 | T+ | 72 | 37 | 109 | Quality assessment:
| 447 | NR | NR | RMI2 = U × M × CA-125 (Tingulstad, Hagen, Skjeldestad, et al., 1996 [#3890]) | T- | 30 | 308 | 338 | Reference standard: +
| Registry | Risk factors (n [%]): | Combination (n [%]): | | Tot | 102 | 345 | 447 | Verification bias: +
| Reference standard: | NR | All had palpable or US demonstrated pelvic mass | | | | Lower | Upper | Test reliability/variability: ? (unclear from title of reference: Tingulstad, Hagen, Skjeldestad, et al., 1996 [#3890])
| Histology or repeat exam every 2–3 months | Inclusion criteria: | Additional data used for diagnosis: | | | Value | 95% CI | 95% CI | Sample size: -
| Reference standard applied to all test negatives?: | 30 years of age or older; pelvic mass identified in region | Vaginal ultrasound | | Se | 70.6% | 61.7% | 79.4% | Statistical tests: +
| No; in 45 cases, patients did not have histology and were observed at 2- to 3- month intervals. No patients were lost to followup. | Exclusion criteria: | Menopausal status | | Sp | 89.3% | 86.0% | 92.5% | Blinding: -
| Statistical tests used: | None | CA-125 | | PPV | 66.1% | 57.2% | 74.9% | Definition of +/- on screening test: +
| Se, Sp | | | | NPV | 91.1% | 88.1% | 94.2% | Explicit validation method?: + (this is a validation study)
| Blinding: | | | | 2) RMI2 data limited only to surgically treated patients (all verified with histopathology)
| No | | | | | Dis+ | Dis- | Tot
| Definition of positive and negative on screening test: | | | | T+ | 72 | 37 | 109
| Well defined, including cutoff value of 200 | | | | T- | 30 | 263 | 293
| RMI2 = U × M × CA-125 (Tingulstad, Hagen, Skjeldestad, et al., 1996 [#3890]) | | | | Tot | 102 | 300 | 402
| | | | | | | Lower | Upper
| | | | | | Value | 95% CI | 95% CI
| | | | | Se | 70.6% | 61.7% | 79.4%
| | | | | Sp | 87.7% | 83.9% | 91.4%
| | | | | PPV | 66.1% | 57.2% | 74.9%
| | | | | NPV | 89.8% | 86.3% | 93.2%
| | | | | Results were reported, but have not been abstracted, for the following: Analysis that considered Stage 1 ovarian cancer as a “benign” disease resulting in Se 95.5% (63/66) and Sp 87.9% (335/381)
Andolf, Jorgensen, and Astedt, 1990 | Geographical location: | Age: | Symptomatic (n [%]): | 1) Bimanual PE | 1) Either US or PE abnormal | | | | Comments:
#1200 | Lund, Sweden | Range: 40–70 | NR | 2) Abdominal US | | Dis+ | Dis- | Tot | —Results are not stratified by risk group or by menopausal status
| Dates: | Menopausal status (n [%]): | Detected by exam (n [%]): | | T+ | 8 | 206 | 214 | —The portions of diagnostic evaluation that would normally lead to referral (e.g., symptomatic presentation or positive findings on bimanual pelvic exam) are incorporated into the diagnostic assessment in this study.
| Oct 1984-Jul 1987 | Pre (< 45): 330 (41%) | 106 total | | T- | 0 | 587 | 587 | Quality assessment:
| Size of population: | Peri (45–55): 212 (26%) | 51 (7.9%) of women with normal US | | Tot | 8 | 793 | 801 | Reference standard: +
| 801 women | Post (> 55): 259 (32%) | 55 women with abnormal US | | | | Lower | Upper | Verification bias: +
| Screening study Registry | Race/ethnicity (n [%]): | Detected by imaging (n [%]): | | | Value | 95% CI | 95% CI | Test reliability/variability: -
| Reference standard: | NR | 163 women total | | Se | 100.0% | 62.5% | 100.0% | Sample size: -
| Histopathology | Risk factors (n [%]): | 108 women with normal manual exam | | Sp | 74.0% | 71.0% | 77.1% | Statistical tests: +
| Reference standard applied to all test negatives?: | NR | 55 women with abnormal manual exam | | PPV | 3.7% | 1.2% | 6.3% | Blinding: -
| No, women without abnormality or cysts < 20 mm diameter considered normal and not verified. Ascertainment of ovarian cancer in test negative relies on Sweden's public health cancer registry system, which is well validated. | Inclusion criteria: | Combination (n [%]): | | NPV | 100.0% | 99.5% | 100.0% | Definition of +/- on screening test: -
| Statistical tests used: | Women between 40–70 years of age in one of 4 groups: | 55 women with abnormal exam and US | | 2) Both US and PE abnormal | | | | Explicit validation method?: -
| Se, Sp | 1) abdominal pain, frequent micturition or irregular bleeding; | Additional data used for diagnosis: | | | Dis+ | Dis- | Tot
| Blinding: | 2) nulliparity; 3) family history of breast, endometrial or ovarian cancer; | None | | T+ | 5 | 50 | 55
| None | 4) previous history of cancer | | | T- | 3 | 743 | 746
| Definition of positive and negative on screening test: | Exclusion criteria: | | | Tot | 8 | 793 | 801
| NR | NR | | | | | Lower | Upper
| | | | | | Value | 95% CI | 95% CI
| | | | | Se | 62.5% | 29.0% | 96.0%
| | | | | Sp | 93.7% | 92.0% | 95.4%
| | | | | PPV | 9.1% | 1.5% | 16.7%
| | | | | NPV | 99.6% | 99.1% | 100.0%
Asif, Sattar, Dawood, et al., 2004 | Geographical location: | Age: | Symptomatic (n [%]): | 1) CA-125 Absolute value of serum CA-125 by solid phase two-site chemiluminescent enzyme immunometric assay using Immulite CA-125 kit (DPC, USA) | 1) RMI1 with cutoff value of 200 | | | | Comments:
#1580 | Rawalpindi, Pakistan | Mean (SD): 41.4 | NR | 2) Ultrasound score (U; transvaginal) based on presence of the following factors: solid areas (1) multilocularity (1) bilaterality (1) ascites (1) extraovarian tumors (1) | | Dis+ | Dis- | Tot | —No stratification by menopausal status
| Dates: | Menopausal status (n [%]): | Detected by exam (n [%]): | If total is 0, then U = 0 | T+ | 47 | 3 | 50 | —Incomplete data reporting makes exact numbers in 2×2 tables uncertain: There is some discrepancy with PPV and NPV reported in paper; couldn't find 2×2 cell values to match Se, Sp, PPV and NPV assuming 55 Disease+ and 45 Disease- patients.
| Jan 2001 to Jan 2002 | Pre (< 45): 56 (56%) | NR | If total is 1, then U = 1 | T- | 8 | 42 | 50 | Quality assessment:
| Size of population: | Post (> 55): 44 (44%) | Detected by imaging (n [%]): | If total ≥ 2, then U = 3 | Tot | 55 | 45 | 100 | Reference standard: +
| 100 women | ≥ 1 year amenorrhea | NR | 3) Menopausal score (M): Postmenopausal (> 1 year of amenorrhea) = 3 Premenopausal = 1 | | | Lower | Upper | Verification bias: +
| Surgical case series | Race/ethnicity (n [%]): | Combination (n [%]): | RMI1 = U × M × CA-125 (Jacobs, Oram, Fairbanks, et al., 1990 [#6820]) | | Value | 95% CI | 95% CI | Test reliability/variability: -
| Reference standard: | NR | NR | | Se | 85.0% | 75.6% | 94.4% | Sample size: -
| Histopathological diagnosis | Risk factors (n [%]): | Additional data used for diagnosis: | | Sp | 93.0% | 85.5% | 100.0% | Statistical tests: +
| Reference standard applied to all test negatives?: | NR | NR | | PPV | 94.0% | 87.4% | 100.0% | Blinding: _
| Yes | Inclusion criteria: | | | NPV | 84.0% | 73.8% | 94.2% | Definition of +/- on screening test: -, did not choose a priori cutoff values
| Statistical tests used: | Consecutive women admitted to one of 2 military hospitalsfor elective surgical exploration and resection of proven ovarian mass | | | 2) RMI1 with cutoff value of 125 | | | | Explicit validation method?: + (this was a validation of RMI1)
| Se, Sp, PPV, NPV | Exclusion criteria: | | | | Dis+ | Dis- | Tot
| Blinding: | None | | | T+ | 48 | 5 | 53
| None | | | | T- | 7 | 40 | 47
| Definition of positive and negative on screening test: | | | | Tot | 55 | 45 | 100
| Implicitly defined by use of Jacobs instrument (Jacobs, Oram, Fairbanks, et al., 1990 [#6820]), but analysis considered multiple cutoff values | | | | | | Lower | Upper
| | | | | | Value | 95% CI | 95% CI
| | | | | Se | 87.0% | 78.1% | 95.9%
| | | | | Sp | 88.0% | 78.5% | 97.5%
| | | | | PPV | 90.6% | 82.7% | 98.4%
| | | | | NPV | 85.1% | 74.9% | 95.3%
| | | | | Results were reported, but have not been abstracted, for the following combinations:
| | | | | RMI1 with cutoff levels of 25, 50, 75, 100, 150, 175, 190, 250, 300
Aslam, Banerjee, Carr, et al., 2000 | Geographical location: | Age: | Symptomatic (n [%]): | 1) Tailor model LR1 uses age, TAMXV (Doppler), papillary projection score (US): P = 1/(1 + e - z), where z = 0.1273 × age + 0.2794 × TAMXV + 4.4136 × PPS - 14.2046 Cutoff = 50% | 1) Tailor model LR1 | | | | Comments:
#2690 | South London, UK | Mean: 45.6 | NR | 2) Timmerman model LR3 uses CA-125, morphologic and demographic data. Z = 0.5948 × menopausal status + 0.0205 × CA-125 + 0.5446 × ascites - 0.762 × unilocularity 1.1606 × smooth + 1.5409 × PPS + 0.7633 × bilateral - 1.0889 | | Dis+ | Dis- | Tot | —Although study applied reference standard to all test negative women, study included only women already referred for surgery; thus, there is a referral bias in the population.
| Dates: | Range: 20–78 | Detected by exam (n [%]): | P > 50% assumed to be diagnostic of malignancy | T+ | 15 | 5 | 20 | —Borderlines counted as malignant
| NR | Menopausal status (n [%]): | NR | 3) LR1 + LR2 | T- | 18 | 62 | 80 | Quality assessment:
| Size of population: | Pre: 63 (63%) | Detected by imaging (n [%]): | 4) LR1 + LR3 | Tot | 33 | 67 | 100 | Reference standard: +
| 100 women | Post: 37 (37%) | NR | 5) LR1 + LR2 + LR3 | | | Lower | Upper | Verification bias: +
| Registry | ≥ 1 year amenorrhea or age > 50 if status post hysterectomy | Combination (n [%]): | Where LR2 = Alcazar (1998) model using morphologic features with Doppler blood flow variables | | Value | 95% CI | 95% CI | Test reliability/variability: -
| Reference standard: | Race/ethnicity (n [%]): | NR | Ascites = 1 or 0 | Se | 45.0% | 28.0% | 62.0% | Sample size: -
| Histopathological diagnosis from laparotomy | NR | Additional data used for diagnosis: | | Sp | 93.0% | 86.9% | 99.1% | Statistical tests: +
| Reference standard applied to all test negatives?: | Risk factors (n [%]): | NR | | PPV | 75.0% | 56.0% | 94.0% | Blinding: -
| Yes | NR | | | NPV | 77.5% | 68.3% | 86.7% | Definition of +/- on screening test: +
| Statistical tests used: | Inclusion criteria: | | | AUC 0.86 (0.77 to 0.94) | | | | Explicit validation method?: + (study validates 2 previously reported models)
| Se, Sp, ROC curves/AUC | Women with known adnexal masses and due to undergo surgery at one of 3 UK hospitals | | | 2) Timmerman model LR3
| Blinding: | Exclusion criteria: | | | | Dis+ | Dis- | Tot
| No | None | | | T+ | 24 | 6 | 30
| Definition of positive and negative on screening test: | | | | T- | 9 | 61 | 70
| NA | | | | Tot | 33 | 67 | 100
| | | | | | | Lower | Upper
| | | | | | Value | 95% CI | 95% CI
| | | | | Se | 73.0% | 57.9% | 88.1%
| | | | | Sp | 91.0% | 84.1% | 97.9%
| | | | | PPV | 80.0% | 65.7% | 94.3%
| | | | | NPV | 87.1% | 79.3% | 95.0%
| | | | | AUC 0.93 (0.89 to 0.98)
| | | | | 3) LR1+LR2
| | | | | | Dis+ | Dis- | Tot
| | | | | T+ | 20 | 5 | 25
| | | | | T- | 13 | 62 | 75
| | | | | Tot | 33 | 67 | 100
| | | | | | | Lower | Upper
| | | | | | Value | 95% CI | 95% CI
| | | | | Se | 61.0% | 44.4% | 77.6%
| | | | | Sp | 93.0% | 86.9% | 99.1%
| | | | | PPV | 80.0% | 64.3% | 95.7%
| | | | | NPV | 82.7% | 74.1% | 91.2%
| | | | | AUC 0.85
| | | | | 4) LR1 + LR3
| | | | | | Dis+ | Dis- | Tot
| | | | | T+ | 26 | 4 | 30
| | | | | T- | 7 | 63 | 70
| | | | | Tot | 33 | 67 | 100
| | | | | | | Lower | Upper
| | | | | | Value | 95% CI | 95% CI
| | | | | Se | 79.0% | 65.1% | 92.9%
| | | | | Sp | 94.0% | 88.3% | 99.7%
| | | | | PPV | 86.7% | 74.5% | 98.8%
| | | | | NPV | 90.0% | 83.0% | 97.0%
| | | | | AUC 0.95
| | | | | 5) LR2 + LR3
| | | | | | Dis+ | Dis- | Tot
| | | | | T+ | 24 | 11 | 35
| | | | | T- | 9 | 56 | 65
| | | | | Tot | 33 | 67 | 100
| | | | | | | Lower | Upper
| | | | | | Value | 95% CI | 95% CI
| | | | | Se | 73.0% | 57.9% | 88.1%
| | | | | Sp | 84.0% | 75.2% | 92.8%
| | | | | PPV | 68.6% | 53.2% | 84.0%
| | | | | NPV | 86.2% | 77.8% | 94.6%
| | | | | AUC 0.88
Aslam, Tailor, Lawton, et al., 2000 | Geographical location: | Age: | Symptomatic (n [%]): | 1) RMI1 - Jacobs, Oram, Fairbanks, et al., 1990 (#6820) RMI1 = ultrasound score (U; 0, 1, 3) × menopausal status (M; 1, 3) × serum CA-125 | 1) RMI1 with cutoff value of 200 | | | | Comments:
#2580 | South London, UK | Mean: 46.8 | NR | RMI1 > 200 indicates malignancy | | Dis+ | Dis- | Tot | —Although study applied reference standard to all test negative women, study included only women already referred for surgery; thus, there is a referral bias in the population.
| Dates: | Range: 20–77 | Detected by exam (n [%]): | 1 point each for: Bilateral lesions Multilocular Ascites Solid areas Intraabdominal metastases | T+ | 17 | 3 | 20 | —Borderlines counted as malignant
| Jul 1997-Sep 1998 | Menopausal status (n [%]): | NR | U = 0 if total is 0 1 if total is 1 and 3 if total is ≥ 2 | T- | 6 | 35 | 41 | Quality assessment:
| Size of population: | Pre (< 45): 36 | Detected by imaging (n [%]): | M: | Tot | 23 | 38 | 61 | Reference standard: +
| 61 women | Post (> 55): 25 | NR | Premenopausal = 1 | | | Lower | Upper | Verification bias: +
| Diagnostic test study | ≥ 1 year amenorrhea or age > 50 if status post hysterectomy | Combination (n [%]): | Postmenopausal = 3 | | Value | 95% CI | 95% CI | Test reliability/variability: -
| Reference standard: | Race/ethnicity (n [%]): | NR | CA-125 in kU/L | Se | 73.9% | 56.0% | 91.9% | Sample size: -
| Histopathological diagnosis | NR | Additional data used for diagnosis: | 2) RMI2 - Tingulstad, Hagen, Skjeldestad, et al., 1996 (#3890) As RMI1 except U = 1 if total is 0 or 1 4 if total ≥ 2; M = 1 or 4 in this model | Sp | 92.1% | 83.5% | 100.0% | Statistical tests: +
| Reference standard applied to all test negatives?: | Risk factors (n [%]): | NR | 3) Tailor model “Ref # 17” LR1 uses age, TAMXV (Doppler), PPS (US): P = 1/(1 + e - z), where z = 0.1273 × age + 0.2794 × TAMXV + 4.4136 × PPS - 14.2046 | PPV | 85.0% | 69.4% | 100.0% | Blinding: -
| Yes | NR | | | NPV | 85.4% | 74.5% | 96.2% | Definition of +/- on screening test: +
| Statistical tests used: | Inclusion criteria: | | | 2) RMI2 with cutoff value of 200 | | | | Explicit validation method?: + (this is a validation of Tailor, Jacobs and Tingulstad)
| Se, Sp | Women with known adnexal masses due to be admitted for surgery | | | | Dis+ | Dis- | Tot
| Blinding: | Exclusion criteria: | | | T+ | 17 | 4 | 21
| None | None | | | T- | 6 | 34 | 40
| Definition of positive and negative on screening test: | | | | Tot | 23 | 38 | 61
| As defined by models used | | | | | | Lower | Upper
| | | | | | Value | 95% CI | 95% CI
| | | | | Se | 73.9% | 56.0% | 91.9%
| | | | | Sp | 89.5% | 79.7% | 99.2%
| | | | | PPV | 81.0% | 64.2% | 97.7%
| | | | | NPV | 85.0% | 73.9% | 96.1%
| | | | | 3) Tailor's model with cutoff value of 50%
| | | | | | Dis+ | Dis- | Tot
| | | | | T+ | 10 | 3 | 13
| | | | | T- | 13 | 35 | 48
| | | | | Tot | 23 | 38 | 61
| | | | | | | Lower | Upper
| | | | | | Value | 95% CI | 95% CI
| | | | | Se | 43.5% | 23.2% | 63.7%
| | | | | Sp | 92.1% | 83.5% | 100.0%
| | | | | PPV | 76.9% | 54.0% | 99.8%
| | | | | NPV | 72.9% | 60.3% | 85.5%
Balbi, Musone, Menditto, et al., 2001 | Geographical location: | Age: | Symptomatic (n [%]): | 1) Logistic regression fitted model: Z = -5.39224 + 2.35132 × US + 2.81806 × PE + 1.58268 × CA-125 + Reference standard: + 0.607183 × CA-72-4 -1.11594 × RI | 1) Logistic regression model prediction | | | | Comments:
#2320 | Naples, Italy | Range: 40–80 | NR | Each variable is “suspicious” (1) or “not suspicious” (0) | | Dis+ | Dis- | Tot | —Exclusion of 18 women with benign exams (not verified)
| Dates: | Menopausal status (n [%]): | Detected by exam (n [%]): | 2) TVUS (with transabdominal imaging if large tumor) Interpreted according to Valentin et al.: unilocular (1); multilocular (2); unilocular solid cyst (3); multilocular solid cyst (4); solid tumor (5) | T+ | 17 | 5 | 22 | —Authors do not state cutoff for positive in their model
| Jan 1996-Mar 2000 | NR | NR | 3) PE physical exam by standard protocol. Examiner was asked to guess benign or malignant. This clinical impression was used in model. No mention of blinding to other data. | T- | 5 | 45 | 50 | Quality assessment:
| Size of population: | Race/ethnicity (n [%]): | Detected by imaging (n [%]): | 4) CA-125 levels > 35 U/ml considered abnormal | Tot | 22 | 50 | 72 | Reference standard: +
| 92 women | NR | NR | 5) CA-72-4 levels > 3 U/ml considered abnormal | | | Lower | Upper | Verification bias: -
| Case series | Risk factors (n [%]): | Combination (n [%]): | 6) Intratumoral resistance index (RI) was evaluated by color Doppler. RI < 0.4 considered abnormal. | | Value | 95% CI | 95% CI | Test reliability/variability: -
| Reference standard: | NR | NR | | Se | 77.3% | 59.8% | 94.8% | Sample size: -
| Histopathological diagnosis | Inclusion criteria | Additional data used for diagnosis: | | Sp | 90.0% | 81.7% | 98.3% | Statistical tests: +
| Reference standard applied to all test negatives?: | Women evaluated for pelvic mass at one institution | None | | PPV | 77.3% | 59.8% | 94.8% | Blinding: -
| No, 18 women with “clearly benign” masses not verified; 2 patients with “clearly malignant” disease (metastases) also excluded | Exclusion criteria: | | | NPV | 90.0% | 81.7% | 98.3% | Definition of +/- on screening test: +
| Statistical tests used: | None | | | Results were reported, but have not been abstracted, for the following combinations: | | | | Explicit validation method?: -
| Se, Sp | | | | Se and Sp were given for individual components (PE, US, CA-125, CA-72-4) as well as various combinations (not clearly defined how these were operationalized - but apparently not with fitted LR models)
| Blinding:
| None
| Definition of positive and negative on screening test:
| Defined
Biagiotti, Desii, Vanzi, et al., 1999 | Geographical location: | Age: | Symptomatic (n [%]): | 1) Logistic regression models built from five training subsets of the data; candidate variables included: age, and 6 US variables: mean diameter of mass (mm), multilocularity, papillary projections, random echogenicity, peak systolic velocity (cm/sec), RI | 1) Logistic regression modelsT+ indicates > 50% probability of malignancy. Analysis based on number of tumors rather than number of patients. | | | | Comments:
#2990 | Florence, Italy | Range: 21–74 | NR | 2) Artificial neural network using the 5 predictor variables identified from forward stepwise selection in LR training set models: age, and 6 US variables: papillary projections, random echogenicity, peak systolic velocity (cm/sec), RI | | Dis+ | Dis- | Tot | —Analysis based on number of tumors rather than number of patients
| Dates: | Menopausal status (n [%]): | Detected by exam (n [%]): | 3) TVUSwith transabdominal US for large masses. Color Doppler imaging used to calculate RI. | T+ | 43 | 6 | 49 | —This study used almost exclusively US predictors; age was the only non-US predictor.
| NR | Pre (< 45): 146 (70.5%) | NR | | T- | 8 | 169 | 177 | —Formula not given for multiple logistic regression model
| Size of population: | Post (> 55): 61 (29.5%) | Detected by imaging (n [%]): | | Tot | 51 | 175 | 226 | Quality assessment:
| 207 women (226 adnexal masses) | Race/ethnicity (n [%]): | NR | | | | Lower | Upper | Reference standard: +
| Case series; diagnostic test study | NR | Combination (n [%]): | | | Value | 95% CI | 95% CI | Verification bias: +
| Reference standard: | Risk factors (n [%]): | NR | | Se | 84.3% | 74.3% | 94.3% | Test reliability/variability: -
| Histopathological diagnosis | 19 patients had bilateral adnexal masses | Additional data used for diagnosis: | | Sp | 96.6% | 93.9% | 99.3% | Sample size: -
| Reference standard applied to all test negatives?: | Inclusion criteria: | NR | | PPV | 87.8% | 78.6% | 96.9% | Statistical tests: +
| Yes | Women undergoing TVUS before surgery for adnexal masses | | | NPV | 95.5% | 92.4% | 98.5% | Blinding: -
| Statistical tests used: | Exclusion criteria: | | | 2) Artificial neural networks Analysis based on number of tumors rather than number of patients. Cutoff > 50%. | | | | Definition of +/- on screening test: -
| Se, Sp | None | | | | Dis+ | Dis- | Tot | Explicit validation method?: + (split sample and bootstrap validation)
| Blinding: | | | | T+ | 49 | 4 | 53
| None | | | | T- | 2 | 171 | 173
| Definition of positive and negative on screening test: | | | | Tot | 51 | 175 | 226
| Determined by model fit | | | | | | Lower | Upper
| | | | | | Value | 95% CI | 95% CI
| | | | | Se | 96.1% | 90.8% | 100.0%
| | | | | Sp | 97.7% | 95.5% | 99.9%
| | | | | PPV | 92.5% | 85.3% | 99.6%
| | | | | NPV | 98.8% | 97.3% | 100.0%
Chou, Chang, Yao, et al., 1994 | Geographical location: | Age: | Symptomatic (n [%]): | 1) TVUS - morphology | 1) RI < 0.5 or CA-125 > 35 U/ml | | | | Comments:
#10930 | Tainan, Taiwan | Mean: 38 | NR | 2) Color Doppler US to visualize intratumoral vessel and flow velocity | | Dis+ | Dis- | Tot | —Poor description of morphologic criteria for positive ultrasound
| Dates: | Range: 11–85 | Detected by exam (n [%]): | 3) RI with cutpoint of 0.5 | T+ | 25 | 2 | 27 | —2×2 tables do not agree with Se, Sp, PPV, and NPV statistics reported; not consistent with rounding error alone
| Jan 1991-Feb 1993 | Menopausal status (n [%]): | NR | 4) Serum CA-125 level with cutpoint of 35 U/ml or 65 U/ml | T- | 0 | 81 | 81 | Quality assessment:
| Size of population: | Pre (< 45): 84 (78%) | Detected by imaging (n [%]): | | Tot | 25 | 83 | 108 | Reference standard: +
| 108 women | Post (> 55): 19 (18%) | 108 (100%) by CT or US | | | | Lower | Upper | Verification bias: +
| Registry | Premenarchal: 5 (4%) | Combination (n [%]): | | | Value | 95% CI | 95% CI | Test reliability/variability: -
| Reference standard: | Race/ethnicity (n [%]): | NR | | Se | 100.0% | 88.0% | 100.0% | Sample size: -
| Histopathology | NR | Additional data used for diagnosis: | | Sp | 97.0% | 93.3% | 100.0% | Statistical tests: +
| Reference standard applied to all test negatives?: | Risk factors (n [%]): | NR | | PPV | 92.6% | 82.7% | 100.0% | Blinding: -
| Yes | NR | | | NPV | 100.0% | 96.3% | 100.0% | Definition of +/- on screening test: -
| Statistical tests used: | Inclusion criteria: | | | 2) RI < 0.5 or CA-125 > 65 U/ml | | | | Explicit validation method?: -
| Se, Sp, PPV, NPV | Women undergoing surgery for adnexal tumors | | | | Dis+ | Dis- | Tot
| Blinding: | Exclusion criteria: | | | T+ | 25 | 0 | 25
| None | NR | | | T- | 0 | 83 | 83
| Definition of positive and negative on screening test: | | | | Tot | 25 | 83 | 108
| See under “Scoring System.”Neither TVUS morphology criteria nor color Doppler US intratumoral vessel criteria were explicitly defined/described. | | | | | | Lower | Upper
| | | | | | Value | 95% CI | 95% CI
| | | | | Se | 100.0% | 88.0% | 100.0%
| | | | | Sp | 100.0% | 96.4% | 100.0%
| | | | | PPV | 100.0% | 88.0% | 100.0%
| | | | | NPV | 100.0% | 96.4% | 100.0%
Davies, Jacobs, Woolas, et al., 1993 | Geographical location: | Age: | Symptomatic (n [%]): | 1) RMI1 of Jacobs, Oram, Fairbanks, et al., 1990 (#6820) RMI = U × M × CA-125 | 1) RMI1 (Jacobs, Oram, Fairbanks, et al., 1990 [#6820]) with cutoff value of 200 for T+ | | | | Comments:
#4720 | London, UK | NR | NR | 2) Menopausal status (M) scored as follows: Postmenopausal (> 1 year of amenorrhea) = 3 Premenopausal =1 | | Dis+ | Dis- | Tot | —Borderlines counted as malignant
| Dates: | Menopausal status (n [%]): | Detected by exam (n [%]): | 3) Serum CA-125 level by RIA kit (CIS Bioindustries, France). Scored as absolute value. | T+ | 33 | 11 | 44 | Quality assessment:
| NR | Pre: 86 (69%) | NR | Pelvic US score (U; transabdominal) based on presence of the following factors: multilocularity (1) solid areas (1) bilaterality (1) ascites (1) extraovarian tumors (1) | T- | 4 | 76 | 80 | Reference standard: - (operative diagnosis accepted in absence of histopathological diagnosis)
| Size of population: | Post: 38 (31%) | Detected by imaging (n [%]): | If total is 0, then U = 0 | Tot | 37 | 87 | 124 | Verification bias: +
| 124 women | ≥ 1 year amenorrhea or age > 50 if status post hysterectomy | NR | If total is 1, then U = 1 | | | Lower | Upper | Test reliability/variability: +/- (intra- and inter-assay coefficients of variation > 10% for CA-125)
| Retrospective series | Race/ethnicity (n [%]): | Combination (n [%]): | If total ≥ 2, then U = 3 | | Value | 95% CI | 95% CI | Sample size: -
| Reference standard: | NR | NR | | Se | 89.0% | 78.9% | 99.1% | Statistical tests: +
| Histopathological or operative report diagnosis | Risk factors (n [%]): | Additional data used for diagnosis: | | Sp | 87.0% | 79.9% | 94.1% | Blinding: -
| Reference standard applied to all test negatives?: | NR | NR | | PPV | 75.0% | 62.2% | 87.8% | Definition of +/- on screening test: -
| Yes | Inclusion criteria: | | | NPV | 95.0% | 90.2% | 99.8% | Explicit validation method?: + (this is a validation study of RMI1)
| Statistical tests used: | Consecutive admissions for surgical exploration of adnexal mass | | | Results were reported, but have not been abstracted, for the following combinations:
| Se, Sp, ROC curves | Exclusion criteria: | | | CA-125 with cutoff values of 30, 50, 70, 90, 120
| Blinding: | None | | | Ultrasound score with cutoff values of 1 and 3
| None | | | | Menopausal status (post vs pre)
| Definition of positive and negative on screening test: | | | | RMI with cutoffs of 25, 50, 75, 100, 150, 250
| Multiple cutoffs tested; measures defined as per Jacobs, Oram, Fairbanks, et al., 1990 (#6820)
Dowd, Quinn, Rome, et al., 1993 | Geographical location: | Age: | Symptomatic (n [%]): | 1) CA-125 Absolute value (capped at 500) | 1) RMI1 (n = 180 patients) | | | | Comments:
#4680 | Melbourne, Australia | Mean: 50.2 | NR | 2) Ultrasound score (U); criteria not described (0, 1, or 3 depending on the presence of particular features) | Se = 70% | | | | —Unable to determine 2×2 table from available information - reported that: “There was sufficient data to use the RMI of Jacobs, Oram, Fairbanks, et al., 1990 (#6820), in 180 patients: the Se was 0.70 and the Sp was 0.94.”
| Dates: | Range: 15–89 | Detected by exam (n [%]): | 3) Menopausal score (M) Postmenopausal (>1 year amenorrhea) = 3 Premenopausal = 1 | Sp = 94% | | | | No singular solution or marginals were reported.
| NR | Menopausal status (n [%]): | NR | RMI1 = U × M × CA-125 (Jacobs, Oram, Fairbanks, et al., 1990 [#6820]); cutoff > 2000 | Can't calculate 2×2 (marginals not reported for this 180-patient subset for whom RMI1 was available). | | | | —Borderlines counted as malignant
| Size of population: | Pre: 121 (46%) | Detected by imaging (n [%]): | | No stratification by age or menopausal status. | | | | Quality assessment:
| 264 women | Post: 143 (54%) | NR | | | | | | Reference standard: +
| Registry | Race/ethnicity (n [%]): | Combination (n [%]): | | | | | | Verification bias: -
| Reference standard: | NR | NR | | | | | | Test reliability/variability: -
| Histopathology | Risk factors (n [%]): | Additional data used for diagnosis: | | | | | | Sample size: -
| Reference standard applied to all test negatives?: | NR | CA-125 | | | | | | Statistical tests: +
| Yes | Inclusion criteria: | Menopausal status | | | | | | Blinding: -
| Statistical tests used: | Serum CA-125 performed for evaluation of pelvic mass | Ultrasound score | | | | | | Definition of +/- on screening test: +
| Se, Sp | Exclusion criteria: | | | | | | | Explicit validation method? + (this is validation study)
| Blinding: | No suspected pelvic mass; CA-125 obtained for screening only; no histopathology
| None
| Definition of positive and negative on screening test:
| RMI > 200
Gadducci, Capriello, Bartolini, et al., 1988 | Geographical location: | Age: | Symptomatic (n [%]): | 1) US score based on: Shape (rounded-0 patients; polycyclic - 2 patients; poorly defined - 4 patients) Ascites (absent - 0 patients; present - 4 patients); Outline (regular - 0 patients; poorly defined - 2 patients; thickened - 4 patients) Structure (anechoic or mildly echogenic - 0 patients; homogeneous echogenic - 1 patient; multilocular - 2 patients; anechoic with echogenic areas - 3 patients; echogenic with anechoic areas - 4 patients) | 1) Combined evaluation of US and CA-125 assay: T+ if either (or both) abnormal; T- if both normal | | | | Comments:
#6650 | Pisa, Italy | NR | NR | Total score determined by summing points for each parameter (range 0–16 patients) | | Dis+ | Dis- | Tot | —Scoring system was likely an afterthought, not formally developed or well defined
| Dates: | Menopausal status (n [%]): | Detected by exam (n [%]): | T- < 10 | T+ | 33 | 5 | 38 | Quality assessment:
| NR | NR | NR | T+ ≥ 10 | T- | 2 | 78 | 80 | Reference standard: +
| Size of population: | Race/ethnicity (n [%]): | Detected by imaging (n [%]): | 2) CA-125 solid phase sandwich radioimmunoassay (Centodor kit) | Tot | 35 | 83 | 118 | Verification bias: +
| 119 patients | NR | NR | T+ ≥ 65 U/ml | | | Lower | Upper | Test reliability/variability: -
| Diagnostic test study among referral series | Risk factors (n [%]): | Combination (n [%]): | T- < 65 U/ml | | Value | 95% CI | 95% CI | Sample size: -
| Reference standard: | NR | NR | | Se | 94.3% | 86.6% | 100.0% | Statistical tests: +
| Histopathology; specimen obtained at laparotomy | Inclusion criteria: | Additional data used for diagnosis: | | Sp | 94.0% | 88.9% | 99.1% | Blinding: -
| Reference standard applied to all test negatives?: | Undergoing laparotomy for adnexal mass | NR | | PPV | 86.8% | 76.1% | 97.6% | Definition of +/- on screening test: +
| Yes | Exclusion criteria: | | | NPV | 97.5% | 94.1% | 100.0% | Explicit validation method?: -
| Statistical tests used: | None
| Se, Sp
| Blinding:
| No
| Definition of positive and negative on screening test:
| NA
Guerriero, Ajossa, Risalvato, et al., 1998 | Geographical location: | Age: | Symptomatic (n [%]): | 1) B-mode TVUS; Morphological criteria defined for benign disorders | 1) CDE and CA-125 ≥ 65 U/ml (all patients - numbers are masses) | | | | Comments:
#3400 | Cagliari, Italy | Mean (SD): 41 (15) | NR | 2) Color Doppler imaging with PI and RI calculated. If no Doppler waveforms were obtained, then the result was considered negative. | | Dis+ | Dis- | Tot | —Study described intra-observer variation for CDE, RI, and PI
| Dates: | Range: 14–77 | Detected by exam (n [%]): | 3) CA-125 (> 35 U/ml or > 65 U/ml) | T+ | 22 | 5 | 27 | Quality assessment:
| Jan 1996-May 1997 | Menopausal status (n [%]): | NR | | T- | 11 | 140 | 151 | Reference standard: +
| Size of population: | Pre: 127 (71%) | Detected by imaging (n [%]): | | Tot | 33 | 145 | 178 | Verification bias: +
| 192 adnexal masses in 178 women from among 240 eligible referred women | Post: 51 (29%) | NR | | | | Lower | Upper | Test reliability/variability: +
| Registry | Race/ethnicity (n [%]): | Combination (n [%]): | | | Value | 95% CI | 95% CI | Sample size: -
| Consecutive | NR | NR | | Se | 66.7% | 50.6% | 82.8% | Statistical tests: +
| Reference standard: | Risk factors (n [%]): | Additional data used for diagnosis: | | Sp | 96.6% | 93.6% | 99.5% | Blinding: -
| Histopathology | NR | NR | | PPV | 81.5% | 66.8% | 96.1% | Definition of +/- on screening test: +/-
| Reference standard applied to all test negatives?: | Inclusion criteria: | | | NPV | 92.7% | 88.6% | 96.9% | Explicit validation method?: -
| Yes | Consecutive women with adnexal mass based on palpation or sonography | | | 2) CDE and CA-125 ≥ 65 U/ml (postmenopausal women only - numbers are masses)
| Statistical tests used: | Exclusion criteria: | | | | Dis+ | Dis- | Tot
| Se, Sp | Pregnant | | | T+ | 17 | 0 | 17
| Blinding: | | | | T- | 9 | 27 | 36
| NR | | | | Tot | 26 | 27 | 53
| Definition of positive and negative on screening test: | | | | | | Lower | Upper
| Yes | | | | | Value | 95% CI | 95% CI
| | | | | Se | 65.4% | 47.1% | 83.7%
| | | | | Sp | 100.0% | 88.9% | 100.0%
| | | | | PPV | 100.0% | 82.4% | 100.0%
| | | | | NPV | 75.0% | 60.9% | 89.1%
| | | | | 3) CDE and CA-125 ≥ 65 U/ml (premenopausal women only - numbers are masses)
| | | | | | Dis+ | Dis- | Tot
| | | | | T+ | 5 | 5 | 10
| | | | | T- | 2 | 113 | 115
| | | | | Tot | 7 | 118 | 125
| | | | | | | Lower | Upper
| | | | | | Value | 95% CI | 95% CI
| | | | | Se | 71.4% | 38.0% | 100.0%
| | | | | Sp | 95.8% | 92.1% | 99.4%
| | | | | PPV | 50.0% | 19.0% | 81.0%
| | | | | 4) CDE and CA-125 ≥ 35 U/ml (postmenopausal women only - numbers are masses)
| | | | | | Dis+ | Dis- | Tot
| | | | | T+ | 21 | 1 | 22
| | | | | T- | 5 | 26 | 31
| | | | | Tot | 26 | 27 | 53
| | | | | | | Lower | Upper
| | | | | | Value | 95% CI | 95% CI
| | | | | Se | 80.8% | 65.6% | 95.9%
| | | | | Sp | 96.3% | 89.2% | 100.0%
| | | | | PPV | 95.5% | 86.8% | 100.0%
| | | | | NPV | 83.9% | 70.9% | 96.8%
| | | | | 5) B-mode and CA-125 ≥ 65 U/ml (postmenopausal women only - numbers are masses)
| | | | | | Dis+ | Dis- | Tot
| | | | | T+ | 17 | 0 | 17
| | | | | T- | 9 | 27 | 36
| | | | | Tot | 26 | 27 | 53
| | | | | | | Lower | Upper
| | | | | | Value | 95% CI | 95% CI
| | | | | Se | 65.4% | 47.1% | 83.7%
| | | | | Sp | 100.0% | 88.9% | 100.0%
| | | | | PPV | 100.0% | 82.4% | 100.0%
| | | | | NPV | 75.0% | 60.9% | 89.1%
| | | | | 6) B-mode and CA-125 ≥ 35 U/ml (postmenopausal women only - numbers are masses)
| | | | | | Dis+ | Dis- | Tot
| | | | | T+ | 21 | 1 | 22
| | | | | T- | 5 | 26 | 31
| | | | | Tot | 26 | 27 | 53
| | | | | | | Lower | Upper
| | | | | | Value | 95% CI | 95% CI
| | | | | Se | 80.8% | 65.6% | 95.9%
| | | | | Sp | 96.3% | 89.2% | 100.0%
| | | | | PPV | 95.5% | 86.8% | 100.0%
| | | | | NPV | 83.9% | 70.9% | 96.8%
Guerriero, Alcazar, Coccia, et al., 2002 | Geographical location: | Age: | Symptomatic (n [%]): | 1) US morphology | 1) B-mode and CA-125 > 35 U/ml (postmenopausal women only - numbers are masses) | | | | Comments:
#2130 | Cagliari, Florence, and Navarra, Italy | Mean (SD): 40 (14) | NR | 2) Color Doppler US | | Dis+ | Dis- | Tot | —19 of 132 ovarian carcinomas were low-malignancy potential tumors;
| Dates: | Range: 14–81 | Detected by exam (n [%]): | 3) CA-125 | T+ | 73 | 6 | 79 | 6 masses were metastases from non-ovarian primaries
| Apr 1997-Jul 2000 | Menopausal status (n [%]): | NR | | T- | 20 | 74 | 94 | Quality assessment:
| Size of population: | Pre: 617 (78%) | Detected by imaging (n [%]): | | Tot | 93 | 80 | 173 | Reference standard: +
| 826 masses in 789 women from a potential study population of 1020 women | Post: 172 (22%) | NR | | | | LowerPost: | Upper | Verification bias: +
| Registry | Race/ethnicity (n [%]): | Combination (n [%]): | | | Value | 95% CI | 95% CI | Test reliability/variability: -
| Reference standard: | NR | NR | | Se | 78.5% | 70.1% | 86.8% | Sample size: -
| Histopathology | Risk factors (n [%]): | Additional data used for diagnosis: | | Sp | 92.5% | 86.7% | 98.3% | Statistical tests: +
| Reference standard applied to all test negatives?: | NR | NR | | PPV | 92.4% | 86.6% | 98.2% | Blinding: -
| Yes | Inclusion criteria: | | | NPV | 78.7% | 70.4% | 87.0% | Definition of +/- on screening test: +
| Statistical tests used: | All women scheduled for surgery for the presence of a persistent adnexal mass | | | 2) Color Doppler and CA-125 > 35 U/ml (postmenopausal women only - numbers are masses) | | | | Explicit validation method?: -
| Se, Sp, PPV, NPV | Exclusion criteria: | | | | Dis+ | Dis- | Tot
| Blinding: | Anechoic unilocular or bilocular cystic mass with a thin regular wall without endocystic vegetation (n = 234) | | | T+ | 71 | 3 | 74
| None | | | | T- | 22 | 76 | 98
| Definition of positive and negative on screening test: | | | | Tot | 93 | 79 | 172
| Yes | | | | | | Lower | Upper
| | | | | | Value | 95% CI | 95% CI
| | | | | Se | 76.3% | 67.7% | 85.0%
| | | | | Sp | 96.2% | 92.0% | 100.0%
| | | | | PPV | 95.9% | 91.5% | 100.0%
| | | | | NPV | 77.6% | 69.3% | 85.8%
| | | | | 3) B-mode and CA-125 > 35 U/ml (all women - numbers are masses)
| | | | | | Dis+ | Dis- | Tot
| | | | | T+ | 113 | 30 | 143
| | | | | T- | 34 | 649 | 683
| | | | | Tot | 147 | 679 | 826
| | | | | | | Lower | Upper
| | | | | | Value | 95% CI | 95% CI
| | | | | Se | 76.9% | 70.1% | 83.7%
| | | | | Sp | 95.6% | 94.0% | 97.1%
| | | | | PPV | 79.0% | 72.3% | 85.7%
| | | | | NPV | 95.0% | 93.4% | 96.7%
| | | | | 4) Color Doppler and CA-125 > 35 U/ml (all women - numbers are masses)
| | | | | | Dis+ | Dis- | Tot
| | | | | T+ | 112 | 10 | 122
| | | | | T- | 35 | 669 | 704
| | | | | Tot | 147 | 679 | 826
| | | | | | | Lower | Upper
| | | | | | Value | 95% CI | 95% CI
| | | | | Se | 76.2% | 69.3% | 83.1%
| | | | | Sp | 98.5% | 97.6% | 99.4%
| | | | | PPV | 91.8% | 86.9% | 96.7%
| | | | | NPV | 95.0% | 93.4% | 96.6%
Jacobs, Oram, Fairbanks, et al., 1990 | Geographical location: | Age: | Symptomatic (n [%]): | RMI1 - clinical prediction rule developed from logistic regression model based on ultrasound, CA-125 and menopausal status | 1) RMI1 with cutoff value of 200 | | | | Comments:
#6820 | London, UK | Mean: 51.8 | NR | RMI1 = U × M × CA-125 | | Dis+ | Dis- | Tot | —Small data set relative to number of predictors examined; no validation; no a priori definition of positive items
| Dates: | Menopausal status (n [%]): | Detected by exam (n [%]): | 1) Ultrasound score (U; transabdominal) - 1 point for each of the following:multilocular cyst, evidence of solid areas, evidence of metastases, presence of ascites, and bilateral lesions | T+ | 35 | 3 | 38 | —Borderlines counted as malignant
| NR | Pre: 61 | NR | U = 0 for US score of 0 | T- | 6 | 95 | 101 | Quality assessment:
| Size of population: | Post: 82 | Detected by imaging (n [%]): | =1 for US score of 1 | Tot | 41 | 98 | 139 | Reference standard: - (when no specimen was sent for histopathology, the surgical diagnosis was assumed to be correct)
| 143 women | > 1 year of amenorrhea or age > 50 if status post hysterectomy | NR | = 3 for US score ≥ 2 | | | Lower | Upper | Verification bias: +
| Unclear whether retrospective or prospective series; diagnostic test study | Race/ethnicity (n [%]): | Combination (n [%]): | 3) Serum CA-125 by RIA (Abbott Labs, Chicago) | | Value | 95% CI | 95% CI | Test reliability/variability: +/- (coefficient of variation < 10% for CA-125)
| Reference standard: | NR | NR | 4) Menopausal status (M): | Se | 85.4% | 74.5% | 96.2% | Sample size: -
| Histopathological or operative report diagnosis | Risk factors (n [%]): | Additional data used for diagnosis: | 1 if premenopausal | Sp | 96.9% | 93.5% | 100.0% | Statistical tests: +
| Reference standard applied to all test negatives?: | NR | NR | 3 if postmenopausal | PPV | 92.1% | 83.5% | 100.0% | Blinding: - (CA-125 only)
| No | Inclusion criteria: | | | NPV | 94.1% | 89.4% | 98.7% | Definition of +/- on screening test: -
| Statistical tests used: | Admitted for elective surgical investigation of an adnexal mass | | | 2) RMI1 with cutoff value of 250 (maximum specificity) | | | | Explicit validation method?: -
| Se, Sp, ROC curves, LR | Exclusion criteria: | | | | Dis+ | Dis- | Tot
| Blinding: | None | | | T+ | 32 | 1 | 33
| Clinical assessment blind only to CA-125 level | | | | T- | 9 | 97 | 106
| Definition of positive and negative on screening test: | | | | Tot | 41 | 98 | 139
| No a priori cutoff | | | | | | Lower | Upper
| | | | | | Value | 95% CI | 95% CI
| | | | | Se | 78.0% | 65.3% | 90.7%
| | | | | Sp | 99.0% | 97.0% | 100.0%
| | | | | PPV | 97.0% | 91.1% | 100.0%
| | | | | NPV | 91.5% | 86.2% | 96.8%
| | | | | 3) RMI1 with cutoff value of 25 (maximum Se)
| | | | | | Dis+ | Dis- | Tot
| | | | | T+ | 41 | 37 | 78
| | | | | T- | 0 | 61 | 61
| | | | | Tot | 41 | 98 | 139
| | | | | | | Lower | Upper
| | | | | | Value | 95% CI | 95% CI
| | | | | Se | 100.0% | 92.7% | 100.0%
| | | | | Sp | 62.2% | 52.6% | 71.8%
| | | | | PPV | 52.6% | 41.5% | 63.6%
| | | | | NPV | 100.0% | 95.1% | 100.0%
| | | | | Results were reported, but have not been abstracted, for the following combinations:
| | | | | RMI 1with cutoff values of 50, 75, 100, 150
| | | | | | Se | Sp
| | | | | 50 | 95.1% | 76.5%
| | | | | 75 | 92.7% | 84.7%
| | | | | 100 | 85.4% | 87.8%
| | | | | 150 | 85.4% | 93.9%
Lu, Van Gestel, Suykens, et al., 2003 | Geographical location: | Age: | Symptomatic (n [%]): | 1) Multivariable models developed using least squares support vector machine (LS-SVM) classifiers in a Bayesian evidence framework. Model built on 265 patient training set; tested on 160-patient test set. | 1) RMI1 with cutoff value of 75 | | | | Comments:
#1730 | Leuven, Belgium | NR | NR | Candidate variables included 27 demographic, serum marker, color Doppler, B-mode US, US morphologic, and US echogenicity variables. Variables were chosen using forward selection. | | Dis+ | Dis- | Tot | —Data from Table 2 (page 296)
| Dates: | Menopausal status (n [%]): | Detected by exam (n [%]): | Six different models were built and tested | T+ | 44 | 27 | 71 | —Models 2–7 parameters not specified
| 1994-1999 | NR | NR | 2) LR1- logistic regression | T- | 10 | 79 | 89 | —This paper written to demonstrate feasibility of new modeling approach and application to ovarian mass; does not provide model for use in clinical decisionmaking
| 1994-1997 (training) | Race/ethnicity (n [%]): | Detected by imaging (n [%]): | 3) LS-SVM1 (Lin) | Tot | 54 | 106 | 160 | Quality assessment:
| 1997-1999 (test) | NR | 525 (100%) | 4) LS-SVM1 (RBF) | | | Lower | Upper | Reference standard: +
| Size of population: | Risk factors (n [%]): | Combination (n [%]): | 5) LR2 | | Value | 95% CI | 95% CI | Verification bias: +
| 525 women | NR | NR | 6) LS-SVM2 (Lin) | Se | 81.5% | 71.1% | 91.8% | Test reliability/variability: -
| 265 (training set) | Inclusion criteria: | Additional data used for diagnosis: | 7) LS-SVM2 (RBF) | Sp | 74.5% | 66.2% | 82.8% | Sample size: +
| 160 (test set) | Women referred for US to single ultrasonographer with persistent extrauterine pelvic mass which was subsequently surgically removed | NR | 8) RMI1 (Jacobs, Oram, Fairbanks, et al., 1990 [#6820]) | PPV | 62.0% | 50.7% | 73.3% | Statistical tests: +
| Retrospective case series | Exclusion criteria: | | | NPV | 88.8% | 82.2% | 95.3% | Blinding: -
| Reference standard: | No preoperative CA-125 assay (n = 100) | | | AUC = 0.8733 (± 0.0298 SE) | | | | Definition of +/- on screening test: -
| Histopathologic diagnosis | | | | 2) RMI1 with cutoff value of 100 | | | | Explicit validation method?: +
| Reference standard applied to all test negatives?: | | | | | Dis+ | Dis- | Tot
| Yes | | | | T+ | 40 | 21 | 61
| Statistical tests used: | | | | T- | 14 | 85 | 99
| Se, Sp, ROC curves | | | | Tot | 54 | 106 | 160
| Blinding: | | | | | | Lower | Upper
| None | | | | | Value | 95% CI | 95% CI
| Definition of positive and negative on screening test: | | | | Se | 74.1% | 62.4% | 85.8%
| | | | | Sp | 80.2% | 72.6% | 87.8%
| | | | | PPV | 65.6% | 53.7% | 77.5%
| | | | | NPV | 85.9% | 79.0% | 92.7%
| | | | | Results were reported, but have not been abstracted, for the following combinations:
| | | | | Models 2–7 have Se, Sp, PPV and NPV for 3 to 4 cutoff values each and AUC reported. Each performs better than RMI1.
Ma, Shen, and Lang, 2003 | Geographical location: | Age: | Symptomatic (n [%]): | 1) RMI2 (Tingulstad, Hagen, Skjeldestad, et al., 1996 [#3890]) - clinical prediction rule developed from logistic regression model based on ultrasound (U), CA-125, and menopausal status (M) | 1) RMI2 cutoff value 200 | | | | Comments:
#1900 | Beijing, China | Range: 30 - NR | NR | RMI2 = U × M × CA-125 | | Dis+ | Dis- | Tot | —Relatively poor quality of reporting
| Dates: | Menopausal status (n [%]): | Detected by exam (n [%]): | 2) Ultrasound (U; transabdominal) scored 1 point for each of the following characteristics:multilocular cyst, evidence of solid areas, evidence of metastases, presence of ascites, and bilateral lesions. | T+ | 55 | 12 | 67 | Quality assessment:
| Jan 1998-Jun 1999 | Pre: 89 (64%) | NR | U = | T- | 8 | 65 | 73 | Reference standard: +/-
| Size of population: | Post: 51 (36%) | Detected by imaging (n [%]): | 1 for total score of 0–1 | Tot | 63 | 77 | 140 | Verification bias: +
| 140 women | > 1 year of amenorrhea or age > 50 if status post hysterectomy | NR | 4 for total score ≥ 2 | | | Lower | Upper | Test reliability/variability: -
| Single-institution retrospective case series | Race/ethnicity (n [%]): | Combination (n [%]): | 3) Serum CA-125 | | Value | 95% CI | 95% CI | Sample size: -
| Reference standard: | NR | NR | 4) Menopausal status (M): | Se | 87.3% | 79.1% | 95.5% | Statistical tests: +
| Not stated explicitly, but implied that all patients had pathological classification | Risk factors (n [%]): | Additional data used for diagnosis: | 1 if premenopausal | Sp | 84.4% | 76.3% | 92.5% | Blinding: -
| Reference standard applied to all test negatives?: | NR | NR | 4 if postmenopausal | PPV | 82.1% | 72.9% | 91.3% | Definition of +/- on screening test: -
| Yes, presumably | Inclusion criteria: | | | NPV | 89.0% | 81.9% | 96.2% | Explicit validation method?: + (this is a validation study of RMI2)
| Statistical tests used: | “Ovarian neoplasm” patients over 30 years admitted to a single institution | | | 2) RMI2 cutoff value 100
| Se, Sp, PPV | Exclusion criteria: | | | | Dis+ | Dis- | Tot
| Blinding: | NR | | | T+ | 59 | 21 | 80
| None | | | | T- | 4 | 56 | 60
| Definition of positive and negative on screening test: | | | | Tot | 63 | 77 | 140
| Used definitions of Tingulstad, Hagen, Skjeldestad, et al., 1996 (#3890), but analyzed multiple cutoff values | | | | | | Lower | Upper
| | | | | | Value | 95% CI | 95% CI
| | | | | Se | 93.7% | 87.7% | 99.7%
| | | | | Sp | 72.3% | 62.3% | 82.3%
| | | | | PPV | 73.8% | 64.1% | 83.4%
| | | | | NPV | 93.3% | 87.0% | 99.6%
| | | | | Results were reported, but have not been abstracted, for the following combinations:
| | | | | RMI2 with cutoff of 50, 400, 1000
Maggino, Gadducci, D'Addario, et al., 1994 | Geographical location: | Age: | Symptomatic (n [%]): | 1) Gynecologic examination | 1) Combined US (Gr IIIpossibly malignant) or CA-125 (> 65 U/ml) as T+; else, T- | | | | Comments:
#4500 | Italy | Mean: 61.9 | 209 (72%) | 2) US (transabdominal) | Analysis limited to ovarian tumors | | | | —Transabdominal US only; no endovaginal scanning done
| Dates: | Range: 40–91 | Detected by exam (n [%]): | Classified as: | | Dis+ | Dis- | Tot | —Note typographical errors in Table 10:Se 93.34 should be 94.34 and 65.70 should be 95.70
| Mar 1991-Mar 1992 | Menopausal status (n [%]): | All patients | Benign if size < 5 cm; wall clear, thin; non-echogenous content; no septa or ≤ 3 thin septa; no free liquid in pouch of Douglas; | T+ | 100 | 36 | 136 | —Limiting analysis to cases in which both tests (CA-125 and US) are concordant is not clinically useful, and Se, Sp, PPV, and NPV from this table should be ignored
| Size of population: | Post: 290 (100%) | Detected by imaging (n [%]): | Equivocal if size 5–10 cm; wall clear, smooth, thick; hypoechogenic liquid content or solild homogeneous content; >3 thin septa; thick but regular septa; absence of endocystic vegetation; absence of free peritoneal fluid; | T- | 6 | 98 | 104 | Quality assessment:
| 383 women | Race/ethnicity (n [%]): | NR | Malignant if none of above features observed | Tot | 106 | 134 | 240 | Reference standard: +
| 48 excluded for inadequate data | NR | Combination (n [%]): | 3) CA-125: | | | Lower | Upper | Verification bias: - (45 women not verified, but were followup with US and clinical exam)
| 335 evaluable | Risk factors (n [%]): | NR | T- < 35 U/ml | | Value | 95% CI | 95% CI | Test reliability/variability: -
| 45 benign cysts | NR | Additional data used for diagnosis: | Borderline 35–65 U/ml | Se | 94.3% | 89.9% | 98.7% | Sample size: -
| 290 surgical cases | Inclusion criteria: | NR | T+ > 65 U/ml | Sp | 73.1% | 65.6% | 80.6% | Statistical tests: - (misguided statistical analysis)
| Case series | Postmenopausal women with pelvic mass (intra-or extra-adnexal) | | 4) Combination of US and CA-125 | PPV | 73.5% | 66.1% | 80.9% | Blinding: -
| Reference standard: | Exclusion criteria: | | T+ if either individual test abnormal | NPV | 94.2% | 89.7% | 98.7% | Definition of +/- on screening test: -
| Histopathological diagnosis in 290 women; clinical and US followup in 45 patients with benign-appearing cysts | Premenopause; previous malignant neoplasia (except breast cancer); previous bilateral adnexectomy; if > 55 years of age, previous hysterectomy for non-tumoral disease | | T- if neither test abnormal | 2) Combined US (Gr IIIpossibly malignant) or CA-125 (> 35 U/ml) as T+; else, T- | | | | Explicit validation method?: -
| Reference standard applied to all test negatives?: | | | | Analysis limited to ovarian tumors
| 45 women with US findings indicating benign cyst and CA-125 < 35 U/ml not verified | | | | | Dis+ | Dis- | Tot
| Statistical tests used: | | | | T+ | 102 | 45 | 147
| Se, Sp, PPV, NPV | | | | T- | 4 | 89 | 93
| Blinding: | | | | Tot | 106 | 134 | 240
| None | | | | | | Lower | Upper
| Definition of positive and negative on screening test: | | | | | Value | 95% CI | 95% CI
| Yes | | | | Se | 96.2% | 92.6% | 99.9%
| | | | | Sp | 66.4% | 58.4% | 74.4%
| | | | | PPV | 69.4% | 61.9% | 76.8%
| | | | | NPV | 95.7% | 91.6% | 99.8%
| | | | | 3) Combined US (Gr II-IIIpossibly malignant or borderline) or CA-125 (> 65 U/ml) as T+; else, T-
| | | | | Analysis limited to ovarian tumors
| | | | | | Dis+ | Dis- | Tot
| | | | | T+ | 106 | 77 | 183
| | | | | T- | 0 | 57 | 57
| | | | | Tot | 106 | 134 | 240
| | | | | | | Lower | Upper
| | | | | | Value | 95% CI | 95% CI
| | | | | Se | 100.0% | 97.2% | 100.0%
| | | | | Sp | 42.5% | 34.2% | 50.9%
| | | | | PPV | 57.9% | 50.8% | 65.1%
| | | | | NPV | 100.0% | 94.7% | 100.0%
| | | | | 4) Combined US (Gr II-IIIpossibly malignant or borderline) or CA-125 (>35 U/ml) as T+; else, T-
| | | | | Analysis limited to ovarian tumors
| | | | | | Dis+ | Dis- | Tot
| | | | | T+ | 106 | 82 | 188
| | | | | T- | 0 | 52 | 52
| | | | | Tot | 106 | 134 | 240
| | | | | | | Lower | Upper
| | | | | | Value | 95% CI | 95% CI
| | | | | Se | 100.0% | 97.2% | 100.0%
| | | | | Sp | 38.8% | 30.6% | 47.1%
| | | | | PPV | 56.4% | 49.3% | 63.5%
| | | | | NPV | 100.0% | 94.2% | 100.0%
| | | | | 5) CA-125 > 65
| | | | | | Dis+ | Dis- | Tot
| | | | | T+ | 76 | 10 | 86
| | | | | T- | 30 | 124 | 154
| | | | | Tot | 106 | 134 | 240
| | | | | | | Lower | Upper
| | | | | | Value | 95% CI | 95% CI
| | | | | Se | 71.7% | 63.1% | 80.3%
| | | | | Sp | 92.5% | 88.1% | 97.0%
| | | | | PPV | 88.4% | 81.6% | 95.1%
| | | | | NPV | 80.5% | 74.3% | 86.8%
| | | | | 6) US
| | | | | T+ Class III (possibly malignant) analysis limited to ovarian tumors (non-ovarian tumors excluded)
| | | | | | Dis+ | Dis- | Tot
| | | | | T+ | 90 | 30 | 120
| | | | | T- | 16 | 104 | 120
| | | | | Tot | 106 | 134 | 240
| | | | | | | Lower | Upper
| | | | | | Value | 95% CI | 95% CI
| | | | | Se | 84.9% | 78.1% | 91.7%
| | | | | Sp | 77.6% | 70.6% | 84.7%
| | | | | PPV | 75.0% | 67.3% | 82.7%
| | | | | NPV | 86.7% | 80.6% | 92.7%
| | | | | Results were reported, but have not been abstracted, for the following combinations:
| | | | | No other combinations, but the following individual tests:
| | | | | US (Class II-II possibly malignant or borderline as positive)
| | | | | CA-125 (> 35 U/ml as positive)
Mancuso, De Vivo, Triolo, et al., 2004 | Geographical location: | Age: | Symptomatic (n [%]): | 1) US (transvaginal) Positive if:solid structure or cystic but complex; irregular walls, endocystic vegetations, thick septa; bilateral lesions; ascites | 1) Combination of US + age > 50 | | | | Comments:
#1610 | Messina, Italy | Mean: 42.2 | Pain 68 (54%) | 2) CA-125 positive if > 35 U/ml | | Dis+ | Dis- | Tot | —2×2 cell numbers do not result in exact figures for PPV as reported in Table 4
| Dates: | Range: 18–82 | Menstrual disorder 22 (18%) | 3) Combinations of US, age (> 50 years), CA-125, menopause (post) | T+ | 13 | 10 | 23 | Quality assessment:
| NR | Menopausal status (n [%]): | Urinary/intestinal 5 (4%) | | T- | 1 | 101 | 102 | Reference standard: +
| Size of population: | Pre: 76 (61%) | Asymptomatic 30 (24%) | | Tot | 14 | 111 | 125 | Verification bias: +
| 125 women | Post: 49 (39%) | Detected by exam (n [%]): | | | | Lower | Upper | Test reliability/variability: -
| Case series | Race/ethnicity (n [%]): | NR | | | Value | 95% CI | 95% CI | Sample size: -
| Reference standard: | NR | Detected by imaging (n [%]): | | Se | 92.9% | 79.4% | 100.0% | Statistical tests: +
| Histopathological diagnosis | Risk factors (n [%]): | NR | | Sp | 91.0% | 85.7% | 96.3% | Blinding: -
| Reference standard applied to all test negatives?: | Nulliparous: 62 (50%) | Combination (n [%]): | | PPV | 56.5% | 36.3% | 76.8% | Definition of +/- on screening test: +
| Yes | Multiparous: 63 (50%) | NR | | NPV | 99.0% | 97.1% | 100.0% | Explicit validation method?: -
| Statistical tests used: | Inclusion criteria: | Additional data used for diagnosis: | | 2) Combination of CA-125 + age > 50
| Se, Sp, PPV, NPV | Women admitted for adnexal mass | NR | | | Dis+ | Dis- | Tot
| Blinding: | Exclusion criteria: | | | T+ | 13 | 4 | 17
| None | None | | | T- | 1 | 107 | 108
| Definition of positive and negative on screening test: | | | | Tot | 14 | 111 | 125
| CA-125 - >35 U/ml | | | | | | Lower | Upper
| US, defined | | | | | Value | 95% CI | 95% CI
| | | | | Se | 91.0% | 76.0% | 100.0%
| | | | | Sp | 96.6% | 93.2% | 100.0%
| | | | | PPV | 76.5% | 56.3% | 96.6%
| | | | | NPV | 99.1% | 97.3% | 100.0%
| | | | | 3) Combination of US + menopause
| | | | | | Dis+ | Dis- | Tot
| | | | | T+ | 14 | 13 | 27
| | | | | T- | 0 | 98 | 98
| | | | | Tot | 14 | 111 | 125
| | | | | | | Lower | Upper
| | | | | | Value | 95% CI | 95% CI
| | | | | Se | 100.0% | 78.6% | 100.0%
| | | | | Sp | 88.7% | 82.8% | 94.6%
| | | | | PPV | 51.9% | 33.0% | 70.7%
| | | | | NPV | 100.0% | 96.9% | 100.0%
| | | | | 4) Combination of CA-125 + menopause
| | | | | | Dis+ | Dis- | Tot
| | | | | T+ | 14 | 4 | 18
| | | | | T- | 0 | 107 | 107
| | | | | Tot | 14 | 111 | 125
| | | | | | | Lower | Upper
| | | | | | Value | 95% CI | 95% CI
| | | | | Se | 100.0% | 78.6% | 100.0%
| | | | | Sp | 96.6% | 93.2% | 100.0%
| | | | | PPV | 77.8% | 58.6% | 97.0%
| | | | | NPV | 100.0% | 97.2% | 100.0%
| | | | | 5) Combination of CA-125 + US
| | | | | | Dis+ | Dis- | Tot
| | | | | T+ | 14 | 6 | 20
| | | | | T- | 0 | 105 | 105
| | | | | Tot | 14 | 111 | 125
| | | | | | | Lower | Upper
| | | | | | Value | 95% CI | 95% CI
| | | | | Se | 100.0% | 78.6% | 100.0%
| | | | | Sp | 94.4% | 90.1% | 98.7%
| | | | | PPV | 70.0% | 49.9% | 90.1%
| | | | | NPV | 100.0% | 97.1% | 100.0%
Manjunath, Pratap-kumar, Sujatha, et al., 2001 | Geographical location: | Age: | Symptomatic (n [%]): | 1) Ultrasound score (U) 1 point each for:multilocular, solid areas, ascites, bilateral, and intra-abdominal metastases | Note: Borderline tumors not counted, so n = 148 (appropriate) | | | | Quality assessment:
#2510 | Manipal, India | NR | NR | 2) CA-125 | Note: Results are given for 11 different cutoff scores. The authors recommend cutoff of 200 for all 3 RMIs to minimize false positives. | | | | Reference standard: +
| Dates: | Menopausal status (n [%]): | Detected by exam (n [%]): | 3) Menopausal status | 1) RMI1 (cutoff 200) | | | | Verification bias: +
| Jan 97-Aug 99 | Pre: 84 (57%) | NR | 4) RMI1 (Jacobs, Oram, Fairbanks, et al., 1990 [#6820]) RMI1 = U × M × CA-125, where M = 1 or 3 (pre or post) and U = 0 (no points), 1 (one point) or 3 (2 or more points on ultrasound) | | Dis+ | Dis- | Tot | Test reliability/variability: -
| Size of population: | Post: 64 (43%) | Detected by imaging (n [%]): | 5) RMI2 (Tingulstad, Hagen, Skjeldestad, et al., 1996 [#3890]) RMI2 = U × M × CA-125, where M = 1 or 4 (pre or post) and U = 1 (score 0 or 1) or 4 (score 2 or more) | T+ | 68 | 5 | 73 | Sample size: -
| 152 | Race/ethnicity (n [%]): | NR | 6) RMI3 (Tingulstad et al 1999) RMI3 = U × M × CA-125, where M = 1 or 3 (pre or post), U = 1 (score 0 or 1) or 3 (score at least 2) | T- | 25 | 50 | 75 | Statistical tests: +
| Registry | NR | Combination (n [%]): | | Tot | 93 | 55 | 148 | Blinding: -
| Reference standard: | Risk factors (n [%]): | NR | | | | Lower | Upper | Definition of +/- on screening test: +/- (no a priori cutoff)
| Pathology | NR | Additional data used for diagnosis: | | | Value | 95% CI | 95% CI | Explicit validation method?: + (validation of prior reports on the RMI)
| Reference standard applied to all test negatives?: | Inclusion criteria: | NR | | Se | 73.0% | 64.0% | 82.0%
| Yes - applied to all in population regardless of RMI score | Patients who underwent surgery for a pelvic mass | | | Sp | 91.0% | 83.4% | 98.6%
| Statistical tests used: | Exclusion criteria: | | | PPV | 93.2% | 87.4% | 98.9%
| Chi-square, Se, Sp, PPV, NPV | NR | | | NPV | 66.7% | 56.0% | 77.3%
| Blinding: | | | | 2) RMI2 (cutoff 200)
| NR | | | | | Dis+ | Dis- | Tot
| Definition of positive and negative on screening test: | | | | T+ | 71 | 10 | 81
| Ultrasound: 1 point each for:multilocular, solid areas, ascites, bilateral, and intra-abdominal metastases | | | | T- | 22 | 45 | 67
| Menopausal status:> 1 yr amenorrhea or age > 50 | | | | Tot | 93 | 55 | 148
| | | | | | | Lower | Upper
| | | | | | Value | 95% CI | 95% CI
| | | | | Se | 76.0% | 67.3% | 84.7%
| | | | | Sp | 82.0% | 71.8% | 92.2%
| | | | | PPV | 87.7% | 80.5% | 94.8%
| | | | | NPV | 67.2% | 55.9% | 78.4%
| | | | | 3) RMI3 (cutoff 125)
| | | | | | Dis+ | Dis- | Tot
| | | | | T+ | 74 | 11 | 85
| | | | | T- | 19 | 44 | 63
| | | | | Tot | 93 | 55 | 148
| | | | | | | Lower | Upper
| | | | | | Value | 95% CI | 95% CI
| | | | | Se | 80.0% | 71.9% | 88.1%
| | | | | Sp | 80.0% | 69.4% | 90.6%
| | | | | PPV | 87.1% | 79.9% | 94.2%
| | | | | NPV | 69.8% | 58.5% | 81.2%
| | | | | 4) RMI3 (cutoff 200)
| | | | | | Dis+ | Dis- | Tot
| | | | | T+ | 69 | 5 | 74
| | | | | T- | 24 | 50 | 74
| | | | | Tot | 93 | 55 | 148
| | | | | | | Lower | Upper
| | | | | | Value | 95% CI | 95% CI
| | | | | Se | 74.0% | 65.1% | 82.9%
| | | | | Sp | 91.0% | 83.4% | 98.6%
| | | | | PPV | 93.2% | 87.5% | 99.0%
| | | | | NPV | 67.6% | 56.9% | 78.2%
Mol, Boll, De Kanter, et al., 2001 | Geographical location: | Age: | Symptomatic (n [%]): | 1) Tailor 1997 ref 19 US, Doppler, age, AUC 0.81 | 1) Tailor et al., 1997 model sonography, color Doppler, age | | | | Quality assessment:
#5780 | Utrecht, the Netherlands | Mean: 46.6 | NR | 2) Prompeler 1997 ref 22, AUC 0.73 US, menopausal status | | Dis+ | Dis- | Tot | Reference standard: +
| Dates: | Range: 20–89 | Detected by exam (n [%]): | 3) Jacobs 1990 ref 13 menopause, US, CA-125, AUC 0.83 | T+ | 27 | 77 | 104 | Verification bias: +
| 1991-1998 | Menopausal status (n [%]): | NR | 4) Jacobs 1993 ref 23 menopause, US CA-125, AUC 0.86 | T- | 3 | 63 | 66 | Test reliability/variability: - (this study is testing the models' reliability)
| Size of population: | Pre: 109 (64%) | Detected by imaging (n [%]): | 5) Tingulstad 1996 ref 12 menopause, US, CA-125, AUC 0.83 | Tot | 30 | 140 | 170 | Sample size: +
| 170 women | Post: 61 (36%) | NR | 6) Timmerman 1999 ref 9 menopause, US, Doppler, CA-125 (neural network), AUC 0.84 | | | Lower | Upper | Statistical tests: +
| Registry | Race/ethnicity (n [%]): | Combination (n [%]): | 7) Timmerman 1999 ref 9 Menopause, US, CA-125 (neural network), AUC 0.85 | | Value | 95% CI | 95% CI | Blinding: - (NR)
| Reference standard: | NR | NR | 8) Timmerman 1999 ref 9 menopause, US, Doppler, CA-125 (logistic regression), AUC 0.85 | Se | 90.0% | 79.3% | 100.0% | Definition of +/- on screening test: +
| Pathology | Risk factors (n [%]): | Additional data used for diagnosis: | | Sp | 45.0% | 36.80% | 53.2% | Explicit validation method?: + (this is a validation study)
| Reference standard applied to all test negatives?: | NR | NR | | PPV | 26.0% | 17.5% | 34.4%
| Yes | Inclusion criteria: | | | NPV | 95.5% | 90.4% | 100.0%
| Statistical tests used: | Surgery for an adnexal mass | | | 2) Prompeler 1997 ref 22, AUC 0.73 U/S, menopausal status
| ROC curves | Exclusion criteria: | | | | Dis+ | Dis- | Tot
| Blinding: | NR | | | T+ | 27 | 91 | 118
| NR | | | | T- | 3 | 49 | 52
| Definition of positive and negative on screening test: | | | | Tot | 30 | 140 | 170
| Per the original reports of the models (cutoffs not specified here) | | | | | | Lower | Upper
| | | | | | Value | 95% CI | 95% CI
| | | | | Se | 90.0% | 79.3% | 100.0%
| | | | | Sp | 35.0% | 27.1% | 42.9%
| | | | | PPV | 22.9% | 15.3% | 30.5%
| | | | | NPV | 94.2% | 87.9% | 100.0%
| | | | | 3) Jacobs 1990 ref 13 menopause, U/S, CA-125, AUC 0.83
| | | | | | Dis+ | Dis- | Tot
| | | | | T+ | 27 | 69 | 96
| | | | | T- | 3 | 71 | 74
| | | | | Tot | 30 | 140 | 170
| | | | | | | Lower | Upper
| | | | | | Value | 95% CI | 95% CI
| | | | | Se | 90.0% | 79.3% | 100.0%
| | | | | Sp | 51.0% | 42.7% | 59.3%
| | | | | PPV | 28.1% | 19.1% | 37.1%
| | | | | NPV | 95.9% | 91.5% | 100.0%
| | | | | 4) Jacobs 1993 ref 23 menopause, U/S CA-125, AUC 0.86
| | | | | | Dis+ | Dis- | Tot
| | | | | T+ | 27 | 55 | 82
| | | | | T- | 3 | 85 | 88
| | | | | Tot | 30 | 140 | 170
| | | | | | | Lower | Upper
| | | | | | Value | 95% CI | 95% CI
| | | | | Se | 90.0% | 79.3% | 100.0%
| | | | | Sp | 61.0% | 52.9% | 69.1%
| | | | | PPV | 32.9% | 22.8% | 43.1%
| | | | | NPV | 96.6% | 92.8% | 100.0%
| | | | | 5) Tingulstad 1996 ref 12 menopause, U/S, CA-125, AUC 0.83
| | | | | | Dis+ | Dis- | Tot
| | | | | T+ | 27 | 69 | 96
| | | | | T- | 3 | 71 | 74
| | | | | Tot | 30 | 140 | 170
| | | | | | | Lower | Upper
| | | | | | Value | 95% CI | 95% CI
| | | | | Se | 90.0% | 79.3% | 100.0%
| | | | | Sp | 51.0% | 42.7% | 59.3%
| | | | | PPV | 28.1% | 19.1% | 37.1%
| | | | | NPV | 95.90% | 91.5% | 100.0%
| | | | | 6) Timmerman 1999 ref 9 menopause, U/S, Doppler, CA-125 (neural network), AUC 0.84
| | | | | | Dis+ | Dis- | Tot
| | | | | T+ | 27 | 56 | 83
| | | | | T- | 3 | 84 | 87
| | | | | Tot | 30 | 140 | 170
| | | | | | | Lower | Upper
| | | | | | Value | 95% CI | 95% CI
| | | | | Se | 90.0% | 79.3% | 100.0%
| | | | | Sp | 60.0% | 51.9% | 68.1%
| | | | | PPV | 32.5% | 22.5% | 42.6%
| | | | | NPV | 96.6% | 92.7% | 100.0%
| | | | | 7) Timmerman 1999 ref 9 Menopause, U/S, CA-125 (neural network), AUC 0.85
| | | | | | Dis+ | Dis- | Tot
| | | | | T+ | 27 | 76 | 103
| | | | | T- | 3 | 64 | 67
| | | | | Tot | 30 | 140 | 170
| | | | | | | Lower | Upper
| | | | | | Value | 95% CI | 95% CI
| | | | | Se | 90.0% | 79.3% | 100.0%
| | | | | Sp | 46.0% | 37.7% | 54.3%
| | | | | PPV | 26.2% | 17.7% | 34.7%
| | | | | NPV | 95.5% | 90.6% | 100.0%
| | | | | 8) Timmerman 1999 ref 9 menopause, U/S, Doppler, CA-125 (logistic regression), AUC 0.85
| | | | | | Dis+ | Dis- | Tot
| | | | | T+ | 27 | 62 | 89
| | | | | T- | 3 | 78 | 81
| | | | | Tot | 30 | 140 | 170
| | | | | | | Lower | Upper
| | | | | | Value | 95% CI | 95% CI
| | | | | Se | 90.0% | 79.3% | 100.0%
| | | | | Sp | 56.0% | 47.8% | 64.2%
| | | | | PPV | 30.3% | 20.8% | 39.9%
| | | | | NPV | 96.3% | 92.2% | 100.0%
Morgante, la Marca, Ditto, et al., 1999 | Geographical location: | Age: | Symptomatic (n [%]): | 1) CA-125 | 1) RMI1 (cutoff 80): | | | | Comments:
#2900 | Siena, Italy | Mean NR | NR | 2) Menopausal status (M): age 50 if prior hysterectomyor > 1 yr amenorrhea | | Dis+ | Dis- | Tot | —2 borderline tumors were treated as malignant, which is not exactly correct and may alter results
| Dates: | Age reported as categorical variable | Detected by exam (n [%]): | 3) Ultrasound (U; 1 point each for multilocular, solid, bilateral, ascites, intra-abdominal mets) | T+ | 25 | 19 | 44 | —RMI2 outperformed RMI1 at all cutoff values between 80 and 250
| Jan 1995-Dec 1997 | Menopausal status (n [%]): | NR | RMI1 (Jacobs, Oram, Fairbanks, et al., 1990 [#6820]) RMI1 = U × M × CA-125, where U = 0 if score = 0, U = 1 if score = 1, U = 3 if score at least 2; M = 1 if premenopausal, M = 3 if postmenopausal | T- | 6 | 74 | 80 | Quality assessment:
| Size of population: | Pre: 69 (56%) | Detected by imaging (n [%]): | RMI2 (Tingulstad, Hagen, Skjeldestad, et al., 1996 [#3890]) RMI2 = U × M × CA-125, where U = 1 if score = 0 or 1, U = 4 if score at least 2; M = 1 if premenopausal, M = 4 if postmenopausal | Tot | 31 | 93 | 124 | Reference standard: +
| 124 women | Post: 55 (44%) | NR | | | | Lower | Upper | Verification bias: - (potentially there are patients who did not have surgery whose US findings were less concerning, and we don't have any knowledge of their pathology)
| Registry | (amenorrhea > 1 yr or age > 50 if status post hysterectomy) | Combination (n [%]): | | | Value | 95% CI | 95% CI | Test reliability/variability: +
| Reference standard: | Race/ethnicity (n [%]): | NR | | Se | 81.0% | 67.2% | 94.8% | Sample size: +
| Pathology | NR | Additional data used for diagnosis: | | Sp | 80.0% | 71.9% | 88.1% | Statistical tests: +
| Reference standard applied to all test negatives?: | Risk factors (n [%]): | NR | | PPV | 56.8% | 42.2% | 71.5% | Blinding: -
| Yes | NR | | | NPV | 92.5% | 86.7% | 98.3% | Definition of +/- on screening test: + (tested different cutoffs)
| Statistical tests used: | Inclusion criteria: | | | 2) RMI1 (cutoff 200): | | | | Explicit validation method?: + (this is a validation study)
| Sn, Sp, PPV, NPV, chi-square, ROC curves, Mann-Whitney U, McNemar's | Age > 30, admitted for surgical evaluation of ovarian mass | | | | Dis+ | Dis- | Tot
| Blinding: | Exclusion criteria: | | | T+ | 18 | 5 | 23
| NR | Age < 30, no surgery | | | T- | 13 | 88 | 101
| Definition of positive and negative on screening test: | | | | Tot | 31 | 93 | 124
| Different cutoffs are reported for RMI1 and RMI2 | | | | | | Lower | Upper
| | | | | | Value | 95% CI | 95% CI
| | | | | Se | 58.0% | 40.6% | 75.4%
| | | | | Sp | 95.0% | 90.6% | 99.4%
| | | | | PPV | 78.3% | 61.4% | 95.1%
| | | | | NPV | 87.1% | 80.6% | 93.7%
| | | | | 3) RMI2 (cutoff 125):
| | | | | | Dis+ | Dis- | Tot
| | | | | T+ | 25 | 9 | 34
| | | | | T- | 6 | 84 | 90
| | | | | Tot | 31 | 93 | 124
| | | | | | | Lower | Upper
| | | | | | Value | 95% CI | 95% CI
| | | | | Se | 81.0% | 67.2% | 94.8%
| | | | | Sp | 90.0% | 83.9% | 96.1%
| | | | | PPV | 73.5% | 58.7% | 88.4%
| | | | | NPV | 93.3% | 88.2% | 98.5%
| | | | | 4) RMI2 (cutoff 200):
| | | | | | Dis+ | Dis- | Tot
| | | | | T+ | 23 | 7 | 30
| | | | | T- | 8 | 86 | 94
| | | | | Tot | 31 | 93 | 124
| | | | | | | Lower | Upper
| | | | | | Value | 95% CI | 95% CI
| | | | | Se | 74.0% | 58.6% | 89.4%
| | | | | Sp | 93.0% | 87.8% | 98.2%
| | | | | PPV | 76.7% | 61.5% | 91.8%
| | | | | NPV | 91.5% | 85.8% | 97.1%
| | | | | Results were reported, but have not been abstracted, for the following combinations:
| | | | | RMI1 and RMI2 at following cutoffs: 25, 50, 80, 100, 125, 150, 200, 250
Obeidat, Amarin, Latimer, et al., 2004 | Geographical location: | Age: | Symptomatic (n [%]): | 1) Menopausal status (M = 1 for pre, M = 3 for post) ; menopause defined as 1 year amenorrhea, or 50 years old for patients with prior hysterectomy | 1) RMI1, cutoff 100: | | | | Comments:
#1500 | Cambridge, England | Range: 30-NR | NR | 2) Ultrasound score (U): 1 point for each:multilocular, solid, bilateral, ascites, intra-abdominal metastases; U = 0 for score 0, U = 1 for score 1, U = 3 for score ≥ 2 | | Dis+ | Dis- | Tot | —16 borderline tumors were counted as malignant - not strictly true as these are less aggressive tumors which are not treated the same. May bias results.
| Dates: | Menopausal status (n [%]): | Detected by exam (n [%]): | 3) CA-125 | T+ | 69 | 17 | 86 | —72% had malignancy. This is a very high prevalence compared to the population that usually presents with a pelvic mass for surgery (usually would be < 10%). Think this may falsely elevate the estimated PPV of the test.
| Jan 2000-Dec 2001 | Pre: 27 (27%) | NR | RMI1 (Jacobs, Oram, Fairbanks, et al., 1990 [#6820]) RMI1 = M × U × CA-125 | T- | 3 | 11 | 14 | Quality assessment:
| Size of population: | Post: 73 (73%) | Detected by imaging (n [%]): | | Tot | 72 | 28 | 100 | Reference standard: +
| 100 | Race/ethnicity (n [%]): | 100 (100%) | | | | Lower | Upper | Verification bias: - (possible bias since only patients who had surgery are reported here)
| Registry | NR | Combination (n [%]): | | | Value | 95% CI | 95% CI | Test reliability/variability: +
| Reference standard: | Risk factors (n [%]):NR | NR | | Se | 96.0% | 91.5% | 100% | Sample size: -
| Pathology | Inclusion criteria: | Additional data used for diagnosis: | | Sp | 39.0% | 20.9% | 57.1% | Statistical tests: -
| Reference standard applied to all test negatives?: | 100 consecutive women with a pelvic mass who were admitted for laparotomy; age > 30 | NR | | PPV | 80.2% | 71.8% | 88.6% | Blinding: -
| Yes | Exclusion criteria: | | | NPV | 78.6% | 57.1% | 100% | Definition of +/- on screening test: + (several cutoffs tested)
| Statistical tests used: | NR | | | 2) RMI1, cutoff 150: | | | | Explicit validation method?: + (this is a validation study)
| Chi-square, Mann-Whitney U | | | | | Dis+ | Dis- | Tot
| Blinding: | | | | T+ | 68 | 9 | 77
| NR | | | | T- | 4 | 19 | 23
| Definition of positive and negative on screening test: | | | | Tot | 72 | 28 | 100
| RMI of Jacobs, Oram, Fairbanks, et al., 1990 (#6820) - 4 cutoffs tested: 100, 150, 200, 250 | | | | | | Lower | Upper
| | | | | | Value | 95% CI | 95% CI
| | | | | Se | 95.0% | 90.0% | 100.0%
| | | | | Sp | 68.0% | 50.7% | 85.3%
| | | | | PPV | 88.3% | 81.1% | 95.5%
| | | | | NPV | 82.6% | 67.1% | 98.1%
| | | | | 3) RMI1, cutoff 200:
| | | | | | Dis+ | Dis- | Tot
| | | | | T+ | 65 | 3 | 68
| | | | | T- | 7 | 25 | 32
| | | | | Tot | 72 | 28 | 100
| | | | | | | Lower | Upper
| | | | | | Value | 95% CI | 95% CI
| | | | | Se | 90.0% | 83.1% | 96.9%
| | | | | Sp | 89.0% | 77.4% | 100%
| | | | | PPV | 95.6% | 90.7% | 100%
| | | | | NPV | 78.1% | 63.8% | 92.4%
| | | | | 4) RMI1 cutoff 250:
| | | | | | Dis+ | Dis- | Tot
| | | | | T+ | 62 | 3 | 65
| | | | | T- | 10 | 25 | 35
| | | | | Tot | 72 | 28 | 100
| | | | | | | Lower | Upper
| | | | | | Value | 95% CI | 95% CI
| | | | | Se | 86.0% | 78.0% | 94.0%
| | | | | Sp | 89.0% | 77.4% | 100.0%
| | | | | PPV | 95.4% | 90.3% | 100.0%
| | | | | NPV | 71.4% | 56.5% | 86.4%
| | | | | Results were reported, but have not been abstracted, for the following combinations:
| | | | | “AUC = 0.91”
Roman, Muder-spach, Stein, et al., 1997 | Geographical location: | Age: | Symptomatic (n [%]): | 1) Pelvic exam; fixed, irregular or associated with ascites = suspicious | 1) Pelvic exam, serum tumor marker, or US positive; postmenopausal women only; low malignant potential tumors counted as Disease + | | | | Quality assessment:
#6160 | Los Angeles, CA | NR | NR | 2) CA-125 > 35 U/ml | | Dis+ | Dis- | Tot | Reference standard: +
| Dates: | Menopausal status (n [%]): | Detected by exam (n [%]): | 3) AFP > 10 ng/ml in non-pregnant patient | T+ | 15 | 15 | 30 | Verification bias: +
| Jul 1992-Mar 1994 | Pre: 181 (80%) | NR | 4) LDH > 350 U/l | T- | 0 | 13 | 13 | Test reliability/variability:? (references given for individual tests, not combinations)
| Size of population: | Post: 45 (20%) | Detected by imaging (n [%]): | 5) TVUS; suspicious masses are those which are cystic with one large or multiple nodules or cystic/solid, and solid masses not arising from the uterus | Tot | 15 | 28 | 43 | Sample size: +/- (only 45 menopausal)
| 226 women (nonconsecutive) | Race/ethnicity (n [%]): | NR | 6) Doppler; pulsatility index less than 1.0 or resistance index ≤ 0.4 are suspicious | | | Lower | Upper | Statistical tests: +
| Registry | NR | Combination (n [%]): | 7) HCG >15 mIU/ml in a non-pregnant patient | | Value | 95% CI | 95% CI | Blinding: -
| Reference standard: | Risk factors (n [%]): | NR | | Se | 100.0% | 80.0% | 100.0% | Definition of +/- on screening test: +
| Pathology | NR | Additional data used for diagnosis: | | Sp | 46.4% | 28.0% | 64.9% | Explicit validation method?: -
| Reference standard applied to all test negatives?: | Inclusion criteria: | NR | | PPV | 50.0% | 32.1% | 67.9%
| Statistical tests used: | Operative intervention for presumed adnexal mass | | | NPV | 100.0% | 76.9% | 100.0%
| Chi-square, logistic regression | Exclusion criteria: | | | 2) Serum tumor markers and ultrasound, T+ if serum markers above threshold or US “suspicious” postmenopausal women only
| Blinding: | Emergency surgery, clinical or radiographic evidence of metastatic disease | | | | Dis+ | Dis- | Tot
| NR | | | | T+ | 15 | 11 | 26
| Definition of positive and negative on screening test: | | | | T- | 1 | 18 | 19
| See Scoring column | | | | Tot | 16 | 29 | 45
| | | | | | | Lower | Upper
| | | | | | Value | 95% CI | 95% CI
| | | | | Se | 93.8% | 81.9% | 100.0%
| | | | | Sp | 62.1% | 44.4% | 79.7%
| | | | | PPV | 57.7% | 38.7% | 76.7%
| | | | | NPV | 94.7% | 84.7% | 100.0%
| | | | | 3) Fitted LR model using tumor markers and ultrasound, cut off probability of malignancy = 0.50; postmenopausal women only Same 2×2 table as #2 above
| | | | | Results were reported, but have not been abstracted, for the following combinations:
| | | | | PE + US (Premenopausal and all)
| | | | | PE, tumor markers + US
| | | | | PE + tumor markers
| | | | | Tumor markers + US
| | | | | Postmenopausal women
Schutter, Kenemans, Sohn, et al., 1994 | Geographical location: | Age: | Symptomatic (n [%]): | 1) Pelvic examination: abnormal if a mass distinguishable from the uterus was identified. Clinician was asked to characterize mass as benign (0) or malignant (1) | 1) Physical exam, TVUS, and CA-125 all positive defines malignancy | | | | Comments:
#940 | Amsterdam, The Netherlands | NR | NR | 2) TVUS; used Finkler scoring system (ref#3, Table 3). A score of 7 or more was considered positive for malignancy (1). | | Dis+ | Dis- | Tot | —Borderline tumors were excluded from 2×2 tables (included neither as benign nor malignant).
| Dates: | Menopausal status (n [%]): | Detected by exam (n [%]): | 3) Serum CA-125 >35 (1) is “malignant” | T+ | 19 | 3 | 22 | —No specific cutoff is given or suggested using the new logistic regression model.
| Nov 1990-Dec 1992 | Post: 228 (100%) | 199/228 (87%) | | T- | 11 | 36 | 47 | —Reported values for N, Se, Sp, PPV, and NPV do not correspond precisely to 2×2 tables presented, presumably due to rounding error.
| Size of population: | Race/ethnicity (n [%]): | Detected by imaging (n [%]): | | Tot | 30 | 39 | 69 | Quality assessment:
| 276→ excluded 48 who did not meet inclusion criteria→ 228 | NR | 28/228 (12%) | | | | Lower | Upper | Reference standard: +
| Registry | Risk factors (n [%]): | Combination (n [%]): | | | Value | 95% CI | 95% CI | Verification bias: +
| Reference standard: | NR | NR | | Se | 62.0% | 44.6% | 79.4% | Test reliability/variability:? (unclear for physical exam; the other parameters used accepted/defined criteria)
| Pathology | Inclusion criteria: | Additional data used for diagnosis: | | Sp | 92.0% | 83.5% | 100.0% | Sample size: +
| Reference standard applied to all test negatives?: | Pelvic mass; age > 45; amenorrhea > 12 months; scheduled for surgery with biopsy or excision of mass; no history of BSO; no history of malignancy | NR | | PPV | 86.4% | 72.0% | 100.0% | Statistical tests: +
| Yes | Exclusion criteria: | | | NPV | 76.6% | 64.5% | 88.7% | Blinding: -
| Statistical tests used: | Age ≥ 45; amenor-rhea < 12 months; additional malign-nancy; physical exam “indeterminate;” no pre-operative CA-125 | | | 2) Physical exam and TVUS both positive defines malignancy | | | | Definition of +/- on screening test: +
| Se, Sp, PPV, NPV, chi-square, Fishers exact, ROC curves, logistic regression | | | | | Dis+ | Dis- | Tot | Explicit validation method?: -
| Blinding: | | | | T+ | 38 | 13 | 51
| NR | | | | T- | 8 | 47 | 55
| Definition of positive and negative on screening test: | | | | Tot | 46 | 60 | 106
| Logistic regression model: | | | | | | Lower | Upper
| Exam: benign (0) or malignant (1) | | | | | Value | 95% CI | 95% CI
| CA-125 ≤ 35 U/ml (0) or > 35 (1) | | | | Se | 83.0% | 72.1% | 93.9%
| Ultrasound score < 7 (0) or ≥ 7 (1) | | | | Sp | 79.0% | 68.7% | 89.3%
| | | | | PPV | 74.5% | 62.5% | 86.5%
| | | | | NPV | 85.5% | 76.1% | 94.8%
| | | | | 3) TVUS and CA-125 positive defines malignancy
| | | | | | Dis+ | Dis- | Tot
| | | | | T+ | 20 | 5 | 25
| | | | | T- | 12 | 38 | 50
| | | | | Tot | 32 | 43 | 75
| | | | | | | Lower | Upper
| | | | | | Value | 95% CI | 95% CI
| | | | | Se | 64.0% | 47.4% | 80.6%
| | | | | Sp | 89.0% | 79.6% | 98.4%
| | | | | PPV | 80.0% | 64.3% | 95.7%
| | | | | NPV | 76.0% | 64.2% | 87.8%
| | | | | 4) Logistic regression model Z = -9.2378 + 2.2506(PE) + 1.6025(US) + 1.7293(CA-125). Probability of malignancy is 1/1+e exp(-z).
| | | | | “The ability to predict malignancy or benignancy of the pelvic mass appeared to be 81.5%”. No AUC given.
| | | | | Results were reported, but have not been abstracted, for the following combinations:
| | | | | All possible combinations of ultrasound, CA-125, and exam findings.
Schutter, Sohn, Kristen, et al., 1998 | Geographical location: | Age: | Symptomatic (n [%]): | 1) Physical exam: malignant or benign | 1) PE/US/CA-125/CA-72-4: | | | | Comments:
#730 | The Netherlands | NR | NR | 2) Ultrasound: Finkler score* 7–10 positive, 1–6 negative | | Dis+ | Dis- | Tot | —Borderline tumors not included (this is good)
| Dates: | Menopausal status (n [%]): | Detected by exam (n [%]): | 3) CA-125:≥ 35 positive | T+ | 27 | 0 | 27 | Quality assessment:
| Nov 1990-Dec 1992 | Post: 155 (100%) | NR | 4) CA72-4:≥ 3 positive | T- | 32 | 92 | 124 | Reference standard: +
| Size of population: | Race/ethnicity (n [%]): | Detected by imaging (n [%]): | *Finkler score (Finkler et al 1988, ref #25) | Tot | 59 | 92 | 151 | Verification bias: - (unclear how many negatives didn't have surgery)
| 155 (151 could be classified as malignant or benign; 4 borderlines not included in analysis) | NR | NR | 1-cyst/smooth borders | | | Lower | Upper | Test reliability/variability: + (US scoring system)
| Registry | Risk factors (n [%]): | Combination (n [%]): | 2-cyst/irregular borders | | Value | 95% CI | 95% CI | Sample size: -
| Reference standard: | NR | NR | 3-cyst/echoes and irregular borders | Se | 46.0% | 33.3% | 58.7% | Statistical tests: -
| Histopathology | Inclusion criteria: | Additional data used for diagnosis: | 4–6-equivocal | Sp | 100.0% | 96.7% | 100.0% | Blinding: -
| Reference standard applied to all test negatives?: | Patients presenting with a pelvic mass who underwent surgery | NR | 7–9-multiseptated or irregular cystic mass | PPV | 100.0% | 88.9% | 100.0% | Definition of +/- on screening test: +
| Yes | Exclusion criteria: | | 10-pelvic mass with ascites | NPV | 74.2% | 66.5% | 81.9% | Explicit validation method?: -
| Statistical tests used: | Storage problems making sera unusable | | | 2) PE/US:
| Se, Sp, PPV, NPV, ROC curves, logistic regression | | | | | Dis+ | Dis- | Tot
| Blinding: | | | | T+ | 47 | 12 | 59
| NR | | | | T- | 12 | 80 | 92
| Definition of positive and negative on screening test: | | | | Tot | 59 | 92 | 151
| See Scoring column for individual tests. See Results column for logistic regression equation | | | | | | Lower | Upper
| | | | | | Value | 95% CI | 95% CI
| | | | | Se | 80.0% | 69.8% | 90.2%
| | | | | Sp | 87.0% | 80.1% | 93.9%
| | | | | PPV | 79.7% | 69.4% | 89.9%
| | | | | NPV | 87.0% | 80.1% | 93.8%
| | | | | 3) Logistic regression model: 1/(1+e^-z^) where Z = -5.6816+2.2677*(US) -2.4928*(PE) +1.6057*(CA-125) +1.5866*(CA72-4)
| | | | | | Dis+ | Dis- | Tot
| | | | | T+ | 48 | 9 | 57
| | | | | T- | 11 | 83 | 94
| | | | | Tot | 59 | 92 | 151
| | | | | | | Lower | Upper
| | | | | | Value | 95% CI | 95% CI
| | | | | Se | 81.4% | 71.4% | 91.3%
| | | | | Sp | 90.2% | 84.1% | 96.3%
| | | | | PPV | 84.2% | 74.7% | 93.7%
| | | | | NPV | 88.3% | 81.8% | 94.8%
| | | | | 4) US/CA-125/CA-72-4:
| | | | | | Dis+ | Dis- | Tot
| | | | | T+ | 28 | 1 | 29
| | | | | T- | 31 | 91 | 122
| | | | | Tot | 59 | 92 | 151
| | | | | | | Lower | Upper
| | | | | | Value | 95% CI | 95% CI
| | | | | Se | 47.0% | 34.3% | 59.7%
| | | | | Sp | 99.0% | 97.0% | 100.0%
| | | | | PPV | 96.6% | 89.9% | 100.0%
| | | | | NPV | 74.6% | 66.9% | 82.3%
| | | | | 5) PE/US/CA-125:
| | | | | | Dis+ | Dis- | Tot
| | | | | T+ | 34 | 5 | 39
| | | | | T- | 25 | 87 | 112
| | | | | Tot | 59 | 92 | 151
| | | | | | | Lower | Upper
| | | | | | Value | 95% CI | 95% CI
| | | | | Se | 57.6% | 45.0% | 70.2%
| | | | | Sp | 94.6% | 89.9% | 99.2%
| | | | | PPV | 87.2% | 76.7% | 97.7%
| | | | | NPV | 77.7% | 70.0% | 85.4%
| | | | | Results were reported, but have not been abstracted, for the following combinations:
| | | | | PE/US/CA-72-4
| | | | | CA-125/CA-72-4
| | | | | PE/CA-125/CA-72-4
| | | | | PE/CA-125
| | | | | PE/CA-72-4
| | | | | US/CA-125
| | | | | US/CA-72-4
Strigini, Gadducci, Del Bravo, et al., 1996 | Geographical location: | Age: | Symptomatic (n [%]): | 1) Transvaginal ultrasound (TVUS) | 1) TVUS or CA-125 /postmenopausal only | | | | Comments:
#4000 | Pisa, Italy | Median: 43 | NR | Classified masses as probably benign or malignant. | | Dis+ | Dis- | Tot | —Definition of suspicious TVUS is fairly vague, subjective - no previously published standard is used
| Dates: | Range: 18–80 | Detected by exam (n [%]): | Malignancy was defined as “solid portions with irregular structure, thick septae or papillae, irregular margins” | T+ | 12 | 3 | 15 | —CA-125 > 65 U/ml also is not the usual cutoff, but a reference is given
| Jan 1993-Jun 1994 | Menopausal status (n [%]): | NR | 2) Doppler:pulsatility index < 1 was considered abnormal (reference #5 Kurjak). If no color flow was detected in the mass the Doppler was considered negative (benign). | T- | 1 | 18 | 19 | Quality assessment:
| Size of population: | Post: 34 (31%) | Detected by imaging (n [%]): | 3) CA-125 > 65 U/ml reference #11) | Tot | 13 | 21 | 34 | Reference standard: +
| 109 total→ 34 postmenopausal are reported here | Race/ethnicity (n [%]): | NR | | | | Lower | Upper | Verification bias: +
| Registry | NR | Combination (n [%]): | | | Value | 95% CI | 95% CI | Test reliability/variability: - (TVUS criteria vague)
| Reference standard: | Risk factors (n [%]): | NR | | Se | 92.0% | 77.3% | 100.0% | Sample size: - (only 34 postmenopausal women)
| Pathology | NR | Additional data used for diagnosis: | | Sp | 86.0% | 71.2% | 100.0% | Statistical tests: +
| Reference standard applied to all test negatives?: | Inclusion criteria: | NR | | PPV | 80.0% | 59.8% | 100.0% | Blinding: -
| Yes | Surgery scheduled for an adnexal mass | | | NPV | 94.7% | 84.7% | 100.0% | Definition of +/- on screening test: +/- (TVUS criteria fairly vague)
| Statistical tests used: | Exclusion criteria: | | | 2) TVUS and CA-125/postmenopausal only | | | | Explicit validation method?: -
| Se, Sp | NR | | | | Dis+ | Dis- | Tot
| Blinding: | | | | T+ | 6 | 1 | 7
| NR | | | | T- | 7 | 20 | 27
| Definition of positive and negative on screening test: | | | | Tot | 13 | 21 | 34
| See Scoring column | | | | | | Lower | Upper
| | | | | | Value | 95% CI | 95% CI
| | | | | Se | 46.0% | 18.9% | 73.1%
| | | | | Sp | 95.0% | 85.7% | 100.0%
| | | | | PPV | 85.7% | 59.8% | 100.0%
| | | | | NPV | 74.1% | 57.5% | 90.6%
| | | | | 3) TVUS or PI/postmenopausal only
| | | | | | Dis+ | Dis- | Tot
| | | | | T+ | 12 | 5 | 17
| | | | | T- | 1 | 16 | 17
| | | | | Tot | 13 | 21 | 34
| | | | | | | Lower | Upper
| | | | | | Value | 95% CI | 95% CI
| | | | | Se | 92.0% | 77.3% | 100.0%
| | | | | Sp | 76.0% | 57.7% | 94.3%
| | | | | PPV | 70.6% | 48.9% | 92.2%
| | | | | NPV | 94.1% | 82.9% | 100.0%
| | | | | 4) TVUS and PI/postmenopausal only
| | | | | | Dis+ | Dis- | Tot
| | | | | T+ | 9 | 1 | 10
| | | | | T- | 4 | 20 | 24
| | | | | Tot | 13 | 21 | 34
| | | | | | | Lower | Upper
| | | | | | Value | 95% CI | 95% CI
| | | | | Se | 69.0% | 43.9% | 94.1%
| | | | | Sp | 95.0% | 85.7% | 100.0%
| | | | | PPV | 90.0% | 71.4% | 100.0%
| | | | | NPV | 83.3% | 68.4% | 98.2%
Tailor, Jurkovic, Bourne, et al., 1999 | Geographical location: | Age: | Symptomatic (n [%]): | 1) Age | 1) Neural network “best model” (entire data set) ; ROC AUC = 0.9987: | | | | Comments:
#2910 | London, UK | Mean: 39.6 | NR | 2) Menopausal status | | Dis+ | Dis- | Tot | —Borderlines classified as malignant (not strictly true)
| Dates: | Premenopausal (n = 45): mean age 38, range 20–52 | Detected by exam (n [%]): | 3) Tumor diameter | T+ | 14 | 0 | 14 | —Very small sample size for modeling (n = 15 malignant cases in entire set)
| NR | Postmenopausal (n = 22): mean age 61, range 48–76 | NR | 4) Tumor volume | T- | 1 | 52 | 53 | Quality assessment:
| Size of population: | Menopausal status (n [%]): | Detected by imaging (n [%]): | 5) Locularity | Tot | 15 | 52 | 67 | Reference standard: -
| 67 | Pre (< 45): 45 (67%) | NR | 6) Presence of papillations | | | Lower | Upper | Verification bias: - (patients excluded who didn't have a pathology result [these could have been benign cases])
| Registry | Post (> 55): 22 (33%) | Combination (n [%]): | 7) Echogenicity | | Value | 95% CI | 95% CI | Test reliability/variability: - (don't know, other than small validation set)
| Reference standard: | Race/ethnicity (n [%]): | NR | 8) Blood flow velocity waveforms | Se | 93.3% | 80.6% | 100.0% | Sample size: +
| Pathology | NR | Additional data used for diagnosis: | 9) Peak systolic velocity | Sp | 100.0% | 94.2% | 100.0% | Statistical tests: +
| Reference standard applied to all test negatives?: | Risk factors (n [%]): | NR | 10) Time-average maximum velocity (TAMXV) | PPV | 100.0% | 78.6% | 100.0% | Blinding: -
| Yes | NR | | 11) Pulsatility index | NPV | 98.1% | 94.5% | 100.0% | Definition of +/- on screening test: +
| Statistical tests used: | Inclusion criteria: | | 12) Resistance index | Training set n = 52 | | | | Explicit validation method?: + (authors used 15 patients for validation of the model found using the first 52)
| ROC curves, logistic regression model using the network output gives probability of malignancy | Pelvic mass and scheduled for surgery | | Note: “best model” uses the following variables: age, maximum diameter, papillary projections, TAMXV | Test set n = 15
| Blinding: | Exclusion criteria: | | | Data shown are for all cases, including training set
| NR | No histologic specimen obtained
| Definition of positive and negative on screening test:
| Logistic regression model using the neural network output gives the probability of malignancy
Timmerman, Bourne, Tailor, et al., 1999 | Geographical location: | Age: | Symptomatic (n [%]): | (A) RMI1: calculated per Jacobs, Oram, Fairbanks, et al., 1990 (#6820) using US, menopausal status, and CA-125 | 1) RMI1 with cutoff of 200; AUC = 0.882 | | | | Comments:
#2930 | Belgium and UK | Mean: 51.4 | NR | (B) Variables included in the final multivariable model: | | Dis+ | Dis- | Tot | —5 borderline tumors were counted as malignant
| Dates: | Benign (n = 140): mean (SD) = 49 (16) | Detected by exam (n [%]): | 1) Papillary structures in mass > 3 mm | T+ | 33 | 11 | 44 | Quality assessment:
| Aug 1994-Jul 1996 | Malignant (n = 51): mean (SD) = 58 (14) | NR | 2) Serum CA-125 | T- | 16 | 113 | 129 | Reference standard: +
| Size of population: | Menopausal status (n [%]): | Detected by imaging (n [%]): | 3) Color score (subjective from 1–4 depending on amount of blood flow) | Tot | 49 | 124 | 173 | Verification bias: +
| 191 | Pre: 99 (51.8%) | NR | 4) Menopausal score (can't find exact criteria - unclear if same as criteria used for RMI1) | | | Lower | Upper | Test reliability/variability: +
| Prospective study of patients with a mass sent for U/S (consented prior to ultrasound and surgery) | Post: 92 (48.2%) | Combination (n [%]): | Multivariate model:Probability of malignancy = 1/(1-e-z) Where z=(2.6369 × color score) + (0.0225 × CA-125) + (7.1062 × papillations > 3 mm score) + (2.6423 × postmenopausal score) - 13.6796 | | Value | 95% CI | 95% CI | Sample size: +
| Reference standard: | Benign (n = 140): 40% postmenopausal | NR | (C) Morphologic Scoring system (Lerner, ref#18) -details not given on how it was calculated | Se | 67.3% | 54.2% | 80.4% | Statistical tests: +
| Pathology | Malignant (n = 51): 71% postmenopausal | Additional data used for diagnosis: | | Sp | 91.1% | 86.1% | 96.1% | Blinding: - (NR)
| Reference standard applied to all test negatives?: | Race/ethnicity (n [%]): | NR | | PPV | 75.0% | 62.2% | 87.8% | Definition of +/- on screening test: +
| Yes | NR | | | NPV | 87.6% | 81.9% | 93.3% | Explicit validation method?: +
| Statistical tests used: | Risk factors (n [%]): | | | 2) Logistic regression model, n = 173 cutoff > 25% probability of malignancy; AUC = 0.967:
| Multivariate logistic regression, ROC curves/AUC, Mann-Whitney U, student t, chi-square, Fisher exact | NR | | | | Dis+ | Dis- | Tot
| Blinding: | Inclusion criteria: | | | T+ | 47 | 16 | 63
| NR, but prospective | At least 1 adnexal mass; performance of TVUS with color Doppler; surgical removal of mass | | | T- | 2 | 108 | 110
| Definition of positive and negative on screening test: | Exclusion criteria: | | | Tot | 49 | 124 | 173
| | Surgery not done | | | | | Lower | Upper
| | | | | | Value | 95% CI | 95% CI
| | | | | Se | 95.9% | 90.4% | 100.0%
| | | | | Sp | 87.1% | 81.2% | 93.0%
| | | | | PPV | 74.6% | 63.9% | 85.4%
| | | | | NPV | 98.2% | 95.7% | 100.0%
| | | | | 3) Logistic regression model, n = 173, cutoff > 50% probability of malignancy, AUC = 0.967:
| | | | | | Dis+ | Dis- | Tot
| | | | | T+ | 43 | 10 | 53
| | | | | T- | 6 | 114 | 120
| | | | | Tot | 49 | 124 | 173
| | | | | | | Lower | Upper
| | | | | | Value | 95% CI | 95% CI
| | | | | Se | 87.8% | 78.6% | 96.9%
| | | | | Sp | 91.9% | 87.1% | 96.7%
| | | | | PPV | 81.1% | 70.6% | 91.7%
| | | | | NPV | 95.0% | 91.1% | 98.9%
| | | | | 4) Morphologic Index of Lerner (ref #18), AUC = 0.840:
| | | | | | Dis+ | Dis- | Tot
| | | | | T+ | 49 | 55 | 104
| | | | | T- | 2 | 85 | 87
| | | | | Tot | 51 | 140 | 191
| | | | | | | Lower | Upper
| | | | | | Value | 95% CI | 95% CI
| | | | | Se | 96.1% | 90.8% | 100.0%
| | | | | Sp | 60.7% | 52.6% | 68.8%
| | | | | PPV | 47.1% | 37.5% | 56.7%
| | | | | NPV | 97.7% | 94.6% | 100.0%
| | | | | Results were reported, but have not been abstracted, for the following combinations:
| | | | | RMI1 for cutoffs of 50, 75, 100, 150 (n = 173 patients who had CA-125 available AUC = 0.882)
| | | | | Timmerman model for training set (n = 116) and testing set (n = 57) but numbers NR for these subgroups
Timmerman, Verrelst, Bourne, et al., 1999 | Geographical location: | Age: | Symptomatic (n [%]): | 1) Neural Network 1 uses: menopause score (0 or 1), color score (1–4 subjective), papillations score (0 or 1), CA-125 | 1) Neural Network 1 (AUC = 0.971) cutoff 45% probability of malignancy | | | | Comments:
#5940 | Leuven, Belgium | Mean: 53 | NR | 2) Neural Network 2 uses: menopausal score (0 or 1), CA-125, ascites (0 or 1), unilocularity (0 or 1), papillations score (0 or 1), smooth walls score (0 or 1), bilaterality score (0 or 1), unilocular score (0 or 1) | | Dis+ | Dis- | Tot | —5 borderlines were counted as malignant
| Dates: | Range: 22–93 | Detected by exam (n [%]): | 3) Logistic Regression 2 uses:menopausal score (0 or 1), CA-125, ascites (0 or 1), unilocularity (0 or 1), smoothe walls (0 or 1), papillations (0 or 1), bilaterality (0 or 1) | T+ | 46 | 12 | 58 | Quality assessment:
| Aug 1994-Aug 1996 | Menopausal status (n [%]): | NR | z=0.5948 meno + 0.0205CA-125 + 0.5446ascites - 0.762unilocular -1.1606smoothe + 1.5049papillations + 0.7633bilateral - 1.0889 | T- | 3 | 112 | 115 | Reference standard: +
| Size of population: | Pre (< 45): 83 (48%) | Detected by imaging (n [%]): | 4) RMI1 (Jacobs, Oram, Fairbanks, et al., 1990 [#6820]) uses:menopausal score, ultrasound score, CA-125 | Tot | 49 | 124 | 173 | Verification bias: - (only patients who had surgery are evaluated)
| 173 | Post (> 55): 90 (52%) | NR | | | | Lower | Upper | Test reliability/variability: -
| Registry | Race/ethnicity (n [%]): | Combination (n [%]): | | | Value | 95% CI | 95% CI | Sample size: -
| Reference standard: | NR | NR | | Se | 93.9% | 87.2% | 100.0% | Statistical tests: -
| Pathology | Risk factors (n [%]): | Additional data used for diagnosis: | | Sp | 90.3% | 85.1% | 95.5% | Blinding: - (NR)
| Reference standard applied to all test negatives?: | NR | NR | | PPV | 79.3% | 68.9% | 89.7% | Definition of +/- on screening test: +
| Yes | Inclusion criteria: | | | NPV | 97.4% | 94.5% | 100.0% | Explicit validation method?: +
| Statistical tests used: | Adnexal mass; scheduled for surgery; had a CA-125 | | | 2) Neural Network 2 (AUC = 0.979) cutoff 60% probability of malignancy
| Logistic regression model, ROC curves/AUC | Exclusion criteria: | | | | Dis+ | Dis- | Tot
| Blinding: | No CA-125 | | | T+ | 47 | 8 | 55
| NR | | | | T- | 2 | 116 | 118
| Definition of positive and negative on screening test: | | | | Tot | 49 | 124 | 173
| | | | | | | Lower | Upper
| | | | | | Value | 95% CI | 95% CI
| | | | | Se | 95.9% | 90.3% | 100.0%
| | | | | Sp | 93.5% | 89.2% | 97.8%
| | | | | PPV | 85.5% | 76.1% | 94.8%
| | | | | NPV | 98.3% | 96.0% | 100.0%
| | | | | 3) Logistic Regression 2 (AUC = 0.956) cutoff 60% probability of malignancy
| | | | | | Dis+ | Dis- | Tot
| | | | | T+ | 47 | 18 | 65
| | | | | T- | 2 | 106 | 108
| | | | | Tot | 49 | 124 | 173
| | | | | | | Lower | Upper
| | | | | | Value | 95% CI | 95% CI
| | | | | Se | 95.9% | 90.3% | 100.0%
| | | | | Sp | 85.5% | 79.3% | 91.7%
| | | | | PPV | 72.3% | 61.4% | 83.2%
| | | | | NPV | 98.1% | 95.6% | 100.0%
Tingulstad, Hagen, Skjeldestad, et al., 1996 | Geographical location: | Age: | Symptomatic (n [%]): | 1) Ultrasound score (U) Based on presence of multilocular cystic lesions, solid areas, bilateral lesions, ascites, and intra-abdominal metastases scored 1 point each: If score = 0, then U = 0 If score = 1, then U = 1 If score ≥ 2, the U = 3 | 1) RMI1 cutoff 50: | | | | Comments:
#3890 | Trondheim, Norway | NR | NR | 2) Menopause score (M): | | Dis+ | Dis- | Tot | —Borderline tumors counted as malignant
| Dates: | Menopausal status (n [%]): | Detected by exam (n [%]): | Premenopausal = 1 | T+ | 49 | 22 | 71 | Quality assessment:
| Feb 1992-Feb 1994 | Pre (< 45): 82 (47%) | NR | Postmenopausal = 3 | T- | 7 | 95 | 102 | Reference standard: +
| Size of population: | Post (> 55): 91 (53%) | Detected by imaging (n [%]): | 3) CA-125 in kU/L | Tot | 56 | 117 | 173 | Verification bias: -
| 173 | Race/ethnicity (n [%]): | NR | RMI1 (Jacobs, Oram, Fairbanks, et al., 1990 [#6820]) RMI1 = M × U × CA-125 | | | Lower | Upper | Test reliability/variability: +
| Registry | NR | Combination (n [%]): | RMI2 (Tingulstad, Hagen, Skjeldestad, et al., 1996 [#3890]) RMI2 = M × U × CA-124 as RMI1 except U = 1 if total is 0 or 1 4 if total ≥ 2; M = 1 or 4 | | Value | 95% CI | 95% CI | Sample size: +
| Reference standard: | Risk factors (n [%]): | NR | | Se | 88.0% | 79.5% | 96.5% | Statistical tests: +
| Pathology | NR | Additional data used for diagnosis: | | Sp | 81.0% | 73.9% | 88.1% | Blinding: -
| Reference standard applied to all test negatives?: | Inclusion criteria: | NR | | PPV | 69.0% | 58.3% | 79.8% | Definition of +/- on screening test: +
| Yes | Admitted for surgery for a pelvic mass | | | NPV | 93.1% | 88.2% | 98.0% | Explicit validation method?: - (not for RMI2; this is a validation study of RMI1)
| Statistical tests used: | Exclusion criteria: | | | 2) RMI1 cutoff 100:
| Se, Sp, chi-square, ROC curves | NR | | | | Dis+ | Dis- | Tot
| Blinding: | | | | T+ | 44 | 9 | 53
| NR | | | | T- | 12 | 108 | 120
| Definition of positive and negative on screening test: | | | | Tot | 56 | 117 | 173
| RMI1 = U × M × CA-125, where U = 0, 1, or 3; M = 1 or 3 | | | | | | Lower | Upper
| RMI2 = U × M × CA-125, where U = 0, 1, or 4; M = 1 or 4 | | | | | Value | 95% CI | 95% CI
| | | | | Se | 79.0% | 68.3% | 89.7%
| | | | | Sp | 92.0% | 87.1% | 96.9%
| | | | | PPV | 83.0% | 72.9% | 93.1%
| | | | | NPV | 90.0% | 84.6% | 95.4%
| | | | | 3) RMI1 cutoff 200:
| | | | | | Dis+ | Dis- | Tot
| | | | | T+ | 40 | 5 | 45
| | | | | T- | 16 | 112 | 128
| | | | | Tot | 56 | 117 | 173
| | | | | | | Lower | Upper
| | | | | | Value | 95% CI | 95% CI
| | | | | Se | 71.0% | 59.1% | 82.9%
| | | | | Sp | 96.0% | 92.4% | 99.6%
| | | | | PPV | 88.9% | 79.7% | 98.1%
| | | | | NPV | 87.5% | 81.8% | 93.2%
| | | | | 4) RMI2 cutoff 100:
| | | | | | Dis+ | Dis- | Tot
| | | | | T+ | 47 | 21 | 68
| | | | | T- | 9 | 96 | 105
| | | | | Tot | 56 | 117 | 173
| | | | | | | Lower | Upper
| | | | | | Value | 95% CI | 95% CI
| | | | | Se | 84.0% | 74.4% | 93.6%
| | | | | Sp | 82.0% | 75.0% | 89.0%
| | | | | PPV | 69.1% | 58.1% | 80.1%
| | | | | NPV | 91.4% | 86.1% | 96.8%
| | | | | 5) RMI2 cutoff 200:
| | | | | | Dis+ | Dis- | Tot
| | | | | T+ | 45 | 9 | 54
| | | | | T- | 11 | 108 | 119
| | | | | Tot | 56 | 117 | 173
| | | | | | | Lower | Upper
| | | | | | Value | 95% CI | 95% CI
| | | | | Se | 80.0% | 69.5% | 90.5%
| | | | | Sp | 92.0% | 87.1% | 96.9%
| | | | | PPV | 83.3% | 73.4% | 93.3%
| | | | | NPV | 90.8% | 85.6% | 96.0%
| | | | | Results were reported, but have not been abstracted, for the following combinations:
| | | | | RMI1 and RMI 2 at the following cutoffs: 25, 50, 80, 100, 125, 150, 250
Tingulstad, Hagen, Skjeldestad, et al., 1999 | Geographical location: | Age: NR | Symptomatic (n [%]): | 1) Menopause score, (1 or 3) | 1) RMI2 cutoff 100: | | | | Comments:
#5950 | Trondheim, Norway | Menopausal status (n [%]): | NR | 2) Ultrasoundscore (1 or 3). Incorporates the following:multilocular, solid, bilateral, ascites, metastases | | Dis+ | Dis- | Tot | —Borderline tumors counted as malignant
| Dates: | Pre (< 45): 193 (53%) | Detected by exam (n [%]): | 3) CA-125 | T+ | 58 | 61 | 119 | Quality assessment:
| Feb 1995-Jan 1997 | Post (> 55): 172 (47%) | NR | DOUG: ABOVE LOOKS LIKE A DESCRIPTION OF RMI1???? | T- | 17 | 229 | 246 | Reference standard: +
| Size of population: | Race/ethnicity (n [%]): | Detected by imaging (n [%]): | | Tot | 75 | 290 | 365 | Verification bias: -
| 365 | NR | NR | | | | Lower | Upper | Test reliability/variability: +
| Registry | Risk factors (n [%]): | Combination (n [%]): | | | Value | 95% CI | 95% CI | Sample size: +
| Reference standard: | NR | NR | | Se | 77.0% | 67.5% | 86.5% | Statistical tests: +
| Pathology | Inclusion criteria: | Additional data used for diagnosis: | | Sp | 79.0% | 74.3% | 83.7% | Blinding: -
| Reference standard applied to all test negatives?: | Age ≥ 30with pelvic masses, scheduled for surgery | NR | | PPV | 48.7% | 39.8% | 57.7% | Definition of +/- on screening test: +
| Statistical tests used: | Exclusion criteria: | | | NPV | 93.1% | 89.9% | 96.3% | Explicit validation method?: + (this is a validation study)
| Chi-square, Mann-Whitney U, Se, Sp | NR | | | 2) RMI2 cutoff 150:
| Blinding: | | | | | Dis+ | Dis- | Tot
| NR | | | | T+ | 54 | 38 | 92
| Definition of positive and negative on screening test: | | | | T- | 21 | 252 | 273
| RMI2 = M × U × CA-125, where U = 1 or 3; M = 1 or 3 | | | | Tot | 75 | 290 | 365
| | | | | | | Lower | Upper
| | | | | | Value | 95% CI | 95% CI
| | | | | Se | 72.0% | 61.8% | 82.2%
| | | | | Sp | 87.0% | 83.1% | 90.9%
| | | | | PPV | 58.7% | 48.6% | 68.8%
| | | | | NPV | 92.3% | 89.1% | 95.5%
| | | | | 3) RMI2 cutoff 200:
| | | | | | Dis+ | Dis- | Tot
| | | | | T+ | 53 | 23 | 76
| | | | | T- | 22 | 267 | 289
| | | | | Tot | 75 | 290 | 365
| | | | | | | Lower | Upper
| | | | | | Value | 95% CI | 95% CI
| | | | | Se | 71.0% | 60.7% | 81.3%
| | | | | Sp | 92.0% | 88.9% | 95.1%
| | | | | PPV | 69.7% | 59.4% | 80.1%
| | | | | NPV | 92.4% | 89.3% | 95.4%
| | | | | 4) RMI2 cutoff 250:
| | | | | | Dis+ | Dis- | Tot
| | | | | T+ | 53 | 20 | 73
| | | | | T- | 23 | 270 | 293
| | | | | Tot | 75 | 290 | 366
| | | | | | | Lower | Upper
| | | | | | Value | 95% CI | 95% CI
| | | | | Se | 70.0% | 59.6% | 80.4%
| | | | | Sp | 93.0% | 90.1% | 95.9%
| | | | | PPV | 72.6% | 62.4% | 82.8%
| | | | | NPV | 92.2% | 89.1% | 95.2%
| | | | | Results were reported, but have not been abstracted, for the following combinations:
| | | | | RMI2 cutoff 50
| | | | | RMI2 cutoff 300
Torres, Derchain, Faundes, et al., 2002 | Geographical location: | Age: | Symptomatic (n [%]): | 1) Ultrasound score (0–10) (Depriest et al 1993; Sassone et al., 1991) 0- unilocular simple cysts w/regular fine wall or lesion suggesting dermoid cyst 1-multilocular cyst w/regular and smooth wall (< 3 mm) or thick (> 3 mm) or solid homogeneous tumor w/hyperechogenic and well-defined wall 2-Unilocular cyst or multilocular cyst w/fine wall, with irregularity in the wall or septa (> 3 mm) 4-Multilocular cyst w/thick and irregular wall (irregularity in the wall or septa(> 3 mm), and/or irregular septa or cyst /papillary irregularity over 3 mm 5- Complex lesion w/irregularity in surface (< 3 mm) or badly-defined and irregular wall; or solid heterogeneous lesion 10-Complex lesion w/irregularity in surface (< 3 mm) or badly defined and irregular wall; or solid heterogenous lesion +1 ascites +2 wall expansive involvement> 3 mm | 1) RMI (cutoff 150): | | | | Comments:
#2170 | São Paolo, Brazil | NR | NR | 2) Menopausal status (1 or 3) | | Dis+ | Dis- | Tot | —18 borderline tumors were treated as malignant (dubious)
| Dates: | Menopausal status (n [%]): | Detected by exam (n [%]): | 3) CA-125 | T+ | 53 | 19 | 72 | —The scoring system for ultrasound does not appear to be the same as that used for the other RMI studies
| Jan 1996-Mar 98 | NR | NR | | T- | 14 | 72 | 86 | Quality assessment:
| Size of population: | Race/ethnicity (n [%]): | Detected by imaging (n [%]): | | Tot | 67 | 91 | 158 | Reference standard: +
| 158 | NR | NR | | | | Lower | Upper | Verification bias: - (don't know about patients who had masses/cysts, but didn't qualify for study)
| Registry | Risk factors (n [%]): | Combination (n [%]): | | | Value | 95% CI | 95% CI | Test reliability/variability: - (not sure authors did the ultrasound scoring the way other published reports did)
| Reference standard: | NR | NR | | Se | 79.0% | 69.2% | 88.8% | Sample size: +
| Pathology | Inclusion criteria: | Additional data used for diagnosis: | | Sp | 79.0% | 70.6% | 87.4% | Statistical tests: +
| Reference standard applied to all test negatives?: | Pelvic mass apparently restricted to adnexal; admitted for surgery | NR | | PPV | 73.6% | 63.4% | 83.8% | Blinding: -
| Yes | Exclusion criteria: | | | NPV | 83.7% | 75.9% | 91.5% | Definition of +/- on screening test: +
| Statistical tests used: | Known distant metastasis | | | AUC for RMI=0.90 | | | | Explicit validation method?: - (unless this is a validation study [not sure they used the same method as DePriest et al (1993) ; Sassone et al., (1991) for ultrasound score])
| Logistic regression, ROC curves | | | | 2) RMI (cutoff 30):
| Blinding: | | | | | Dis+ | Dis- | Tot
| NR | | | | T+ | 64 | 40 | 104
| Definition of positive and negative on screening test: | | | | T- | 3 | 51 | 54
| RMI = U × M × CA-125 | | | | Tot | 67 | 91 | 158
| Results reported for a cutoff of 150 | | | | | | Lower | Upper
| | | | | | Value | 95% CI | 95% CI
| | | | | Se | 96.0% | 91.3% | 100.0%
| | | | | Sp | 56.0% | 45.8% | 66.2%
| | | | | PPV | 61.5% | 52.2% | 70.9%
| | | | | NPV | 94.4% | 88.3% | 100.0%
| | | | | 3) RMI (cutoff 100):
| | | | | | Dis+ | Dis- | Tot
| | | | | T+ | 56 | 21 | 77
| | | | | T- | 11 | 70 | 81
| | | | | Tot | 67 | 91 | 158
| | | | | | | Lower | Upper
| | | | | | Value | 95% CI | 95% CI
| | | | | Se | 84.0% | 75.2% | 92.8%
| | | | | Sp | 77.0% | 68.4% | 85.6%
| | | | | PPV | 72.7% | 62.8% | 82.7%
| | | | | NPV | 86.4% | 79.0% | 93.9%
| | | | | 4) RMI (cutoff 200):
| | | | | | Dis+ | Dis- | Tot
| | | | | T+ | 49 | 13 | 62
| | | | | T- | 18 | 78 | 96
| | | | | Tot | 67 | 91 | 158
| | | | | | | Lower | Upper
| | | | | | Value | 95% CI | 95% CI
| | | | | Se | 73.0% | 62.4% | 83.6%
| | | | | Sp | 86.0% | 78.9% | 93.1%
| | | | | PPV | 79.0% | 68.9% | 89.2%
| | | | | NPV | 81.3% | 73.4% | 89.1%
| | | | | Results were reported, but have not been abstracted, for the following combinations:
| | | | | RMI cutoff 500
Twickler, Forte, Santos-Ramos, et al., 1999 | Geographical location: | Age: | Symptomatic (n [%]): | 1) Age (years) | Ovarian Tumor Index AUC=0.91 | | | | Comments:
#3080 | Dallas, TX | Mean (SD): 38.6 (12.3) | NR | 2) Ovarian volume (ml) | 1) Ovarian Tumor Index cutoff 45: | | | | —16 of 30 “malignant” neoplasms are borderline tumors (dubious)
| Dates: | Range: 15–80 | Detected by exam (n [%]): | 3) Morphology scale (1–15) Sassone ref#3 | | Dis+ | Dis- | Tot | —No validation set was tested
| Feb 1993-Aug 1996 | Menopausal status (n [%]): | 304 (100%) | 4) PI (-10 × PI) | T+ | 26 | 36 | 62 | Quality assessment:
| Size of population: | NR | Detected by imaging (n [%]): | 5) Vessel location: | T- | 5 | 178 | 183 | Reference standard: - (no followup on 60 patients)
| 304 with masses on exam: | Race/ethnicity (n [%]): | NR | Peripheral -10 | Tot | 30 | 214 | 245 | Verification bias: - (no followup on 60 patients)
| 217 had surgery | NR | Combination (n [%]): | Central +10 | | | Lower | Upper | Test reliability/variability: -
| 27 had sonographic followup | Risk factors (n [%]): | NR | 6) Intense echoes -10 | | Value | 95% CI | 95% CI | Sample size: +
| 60 had no followup | NR | Additional data used for diagnosis: | Ovarian Tumor Index is the sum of the above scores | Se | 85.0% | 72.2% | 97.8% | Statistical tests: +
| Prospective study of patients with pelvic masses detected by exam | Inclusion criteria: | NR | | Sp | 83.0% | 78.0% | 88.0% | Blinding: - (NR)
| Reference standard: | Patients with clinically suspected adnexal masses | | | PPV | 41.9% | 29.7% | 54.2% | Definition of +/- on screening test: +
| Pathology or clinical followup | Exclusion criteria: | | | NPV | 97.3% | 94.9% | 99.6% | Explicit validation method?: -
| Reference standard applied to all test negatives?: | NR | | | (likely rounding error in cell C)
| No - 60 had no followup | | | | 2) Ovarian Tumor Index cutoff 55:
| Statistical tests used: | | | | | Dis+ | Dis- | Tot
| Mann-Whitney U, Fisher exact, linear logistic regression | | | | T+ | 23 | 19 | 42
| Blinding: | | | | T- | 7 | 195 | 202
| NR | | | | Tot | 30 | 214 | 244
| Definition of positive and negative on screening test: | | | | | | Lower | Upper
| Ovarian tumor index (see Scoring column for definition). Different cutoffs tested. | | | | | Value | 95% CI | 95% CI
| | | | | Se | 78.0% | 63.2% | 92.8%
| | | | | Sp | 91.0% | 87.2% | 94.8%
| | | | | PPV | 54.8% | 39.7% | 69.8%
| | | | | NPV | 96.5% | 94.0% | 99.1%
| | | | | 3) Ovarian Tumor Index cutoff 40:
| | | | | | Dis+ | Dis- | Tot
| | | | | T+ | 28 | 54 | 82
| | | | | T- | 2 | 161 | 163
| | | | | Tot | 30 | 214 | 245
| | | | | | | Lower | Upper
| | | | | | Value | 95% CI | 95% CI
| | | | | Se | 93.0% | 83.9% | 100.0%
| | | | | Sp | 75.0% | 69.2% | 80.8%
| | | | | PPV | 34.1% | 23.9% | 44.4%
| | | | | NPV | 98.8% | 97.1% | 100.0%
| | | | | (likely rounding error)
Valentin, Hagen, Tingulstad, et al., 2001 | Geographical location: | Age: | Symptomatic (n [%]): | A) Tailor method, cutoff 50% (Tailor et al 1997): | 1) Tailor model, cutoff 50%; AUC=0.87: | | | | Comments:
#2340 | Malmo, Sweden and Trondheim, Norway | “Slightly older” than population of Tailor et al. (1997) | NR | 1) Age | | Dis+ | Dis- | Tot | —This is a validation study of two previously published models - both performed worse than in the original reports. Patient populations (numbers of different types of tumors) were different than in the original studies, possibly accounting for the worse performance.
| Dates: | Menopausal status (n [%]): | Detected by exam (n [%]): | 2) Menopausal status | T+ | 24 | 12 | 36 | —Borderline tumors classified as malignant
| NR | NR | 157 (100%) | 3) Tumor diameter | T- | 11 | 86 | 97 | Quality assessment:
| Size of population: | Race/ethnicity (n [%]): | Detected by imaging (n [%]): | 4) Tumor volume | Tot | 35 | 98 | 133 | Reference standard: +
| 157 original, 21 excluded due to no surgery, no pathology, etc.→ 136 included | NR | NR | 5) Locularity | | | Lower | Upper | Verification bias: - (some were excluded because they did not have surgery)
| Registry | Risk factors (n [%]): | Combination (n [%]): | 6) Presence of papillations | | Value | 95% CI | 95% CI | Test reliability/variability: +
| Reference standard: | NR | NR | 7) Echogenicity | Se | 69.0% | 53.7% | 84.3% | Sample size: -
| Pathology | Inclusion criteria: | Additional data used for diagnosis: | 8) Blood flow velocity waveforms | Sp | 88.0% | 81.6% | 94.4% | Statistical tests: -
| Reference standard applied to all test negatives?: | Adnexal mass diagnosed clinically and scheduled for surgery | NR | 9) Peak systolic velocity | PPV | 66.7% | 51.3% | 82.1% | Blinding: -
| Yes | Exclusion criteria: | | 10) Time-average maximum velocity | NPV | 88.7% | 82.3% | 95.0% | Definition of +/- on screening test: +
| Statistical tests used: | No surgery; no pathology from surgery available | | 11) Pulsatility index | 2) Timmerman model, cutoff 50%; AUC = 0.84: | | | | Explicit validation method?: +
| Se, Sp, ROC curves | | | 12) Resistance index | | Dis+ | Dis- | Tot
| Blinding: | | | B) Timmerman method (ref #5): | T+ | 18 | 11 | 29
| NR | | | 1) Papillary structures in mass > 3 mm | T- | 11 | 42 | 53
| Definition of positive and negative on screening test: | | | 2) Serum CA-125 | Tot | 29 | 53 | 82
| Tailor cutoff 50% | | | 3) Color score (subjective from 1–4 depending on amount of blood flow) | | | Lower | Upper
| Timmerman cutoff 50% | | | 4) Menopausal score (exact criteria unclear) | | Value | 95% CI | 95% CI
| | | | | Se | 62.0% | 44.3% | 79.7%
| | | | | Sp | 79.0% | 68.0% | 90.0%
| | | | | PPV | 62.1% | 44.4% | 79.7%
| | | | | NPV | 79.2% | 68.3% | 90.2%
| | | | | Results were reported, but have not been abstracted, for the following combinations:
| | | | | Tailor model cutoff 25%
| | | | | Timmerman model cutoff 25%

Evidence Table 5. Question 5: Among women with suspected benign masses on initial investigation, what are the sensitivity and specificity of monitoring with periodic CA-125 and/or interval ultrasound examinations for detecting malignant masses? How does the interval of testing/definition of change affect sensitivityand predictive value?

Study | Study Design | Patients | Clinical Presentation | Monitoring Strategy | Results | | | | Comments/Quality Scoring
Castillo, Alcazar, and Jurado, 2004 | Geographical location: Pamplona, Spain | Age: | Symptomatic (n [%]): | Monitoring test: | 1) Cancer in patients followed: | | | | Quality assessment:
#8040 | Dates: | Mean (SD): 59 (8.7) | 0 | Ultrasound, CA-125 | | Dis+ | Dis- | Tot | Reference standard: +
| Jan 1995-Jun 2002 | Menopausal status (n [%]): | Detected by exam (n [%]): | Interval of testing: | T+ | 0 | 44 | 44 | Verification bias: +
| Size of population: | Post (> 55): 223 (100%) | 26 (12%) | 3 months, then every 6 months | T- | 1 | 104 | 105 | Test reliability/variability: -
| 8794 total; 215 had simple unilocular cysts | Race/ethnicity (n [%]): | Detected by imaging (n [%]): | Definition of change: | Tot | 1 | 148 | 149 | Sample size: -
| Screening study | NR | 215 (100%) | Progression: cyst increased in size at least 1 cm | | | Lower | Upper | Statistical tests: +
| Reference standard: | Risk factors (n [%]): | Combination (n [%]): | Regression: decrease at least 1 cm | | Value | 95% CI | 95% CI | Blinding: -
| Surgery or followup at 3 and 9 months | NR | NR | Resolution: cyst not detected in 2 consecutive exams | Se | 0.0% | 0.0% | 0.0% | Definition of +/- on screening test: +
| Reference standard applied to all test negatives?: Yes | Inclusion criteria: | Additional data used for diagnosis: | | Sp | 70.3% | 62.9% | 77.6% | Explicit validation method?: NA
| Test reliability established?: Same examiner to eliminate interobserver variability | Postmenopausal (at least 1 year without menses and older than 45, or hysterectomy with symptoms and older than 50) | NR | | PPV | 0.0% | 0.0% | 0.0%
| Statistical tests used: | Exclusion criteria: | | | NPV | 99.0% | 97.2% | 100.0%
| Chi-square | Previous history of malignancy; history of bilateral oophorectomy
| Blinding: No | Loss to followup:
| Definition of positive and negative on screening test: | 66 (30.6%) (no statistically significant differences in any parameters between those who completed study and those who were lost to followup)
| Increase in cyst size by 1 cm or more | Of remaining 149, 34 underwent immediate surgery.
| Simple cysts (sonolucent with wall < 3 cm, no septations, solid areas, or papillary projections) less than 10 cm with CA-125 < 35, or patient choice, followed
| Length of followup:
| Median 27 months
| Type of followup:
| Repeat US and CA-125
| Followup interval:
| 3 months, then 6 months
Goldstein, Subra-manyam, Snyder, et al., 1989 | Geographical location: New York, NY | Age: | Symptomatic (n [%]): | Monitoring test: | 1) Cancer in patients followed: | | | | Quality assessment:
#10490 | Dates: | Range: 46–86 | NR | Ultrasound | | Dis+ | Dis- | Tot | Reference standard: +
| NR, but 3-year time period | Menopausal status (n [%]): | Detected by exam (n [%]): | Interval of testing: | T+ | 0 | 2 | 2 | Verification bias: +
| Size of population: | Post (> 55): 48 (100%) | NR | 3–6 months | T- | 0 | 14 | 14 | Test reliability/variability: -
| 48; 16 followed | Race/ethnicity (n [%]): | Detected by imaging (n [%]): | Definition of change: | Tot | 0 | 16 | 16 | Sample size: -
| Case series | NR | NR | NR | | | Lower | Upper | Statistical tests: -
| Reference standard: | Risk factors (n [%]): | Combination (n [%]): | | | Value | 95% CI | 95% CI | Blinding: -
| Surgery (26) or followup (16) | NR | NR | | Se | - | - | - | Definition of +/- on screening test: -
| Reference standard applied to all test negatives?: Yes | Inclusion criteria: | Additional data used for diagnosis: | | Sp | 87.5% | 71.3% | 100.0% | Explicit validation method?: NA
| Test reliability established?: No | Postmenopausal at least 12 months | NR | | PPV | 0.0% | 0.0% | 0.0%
| Statistical tests used: | Exclusion criteria: | | | NPV | 100.0% | 78.6% | 100.0%
| None | NR
| Blinding: | Loss to followup:
| “Treatment rationale was not always available to the sonographers.” | 6 (12.5%)
| Definition of positive and negative on screening test:
| Unilateral, no septations or solid components, diameter ≤ 5 cm, no ascites
| Length of followup:
| Mean 29 months (range 10–73 months)
| Type of followup:
| Repeat transabdominal US
| Followup interval:
| 3–6 months
Kurjak, Shalan, Kupesic, et al., 1994 | Geographical location: Zagreb, Croatia | Age: | Symptomatic (n [%]): | Monitoring test: | 1) Cancer during followup after initial benign: | | | | Comments:
#4470 | Dates: | NR for group with cyst | 0 | Repeat ultrasound | | Dis+ | Dis- | Tot | —Incomplete details on other 316 subjects
| Jan 1988-Dec 1992 | Menopausal status (n [%]): | Detected by exam (n [%]): | Interval of testing: | T+ | 1 | 17 | 18 | —Short duration of followup
| Size of population: | Pre (< 45): 280 (69.3%) | NR | 6 months | T- | 0 | 69 | 69 | Quality assessment:
| 5013 in initial screening population | Peri (45–55): 0 | Detected by imaging (n [%]): | Definition of change: | Tot | 1 | 86 | 87 | Reference standard: +
| 404 had simple cysts; results only reported for 88 with 2^nd^ scan | Post (> 55): 124 (30.6%) | NR | Not explicitly defined | | | Lower | Upper | Verification bias: +
| Screening study | Race/ethnicity (n [%]): | Combination (n [%]): | | | Value | 95% CI | 95% CI | Test reliability/variability: -
| Reference standard: | NR | NR | | Se | 100.0% | 0.0% | 100.0% | Sample size: -
| Surgery or followup | Risk factors (n [%]): | Additional data used for diagnosis: | | Sp | 80.2% | 71.8% | 88.6% | Statistical tests: -
| Reference standard applied to all test negatives?: Yes | NR | NR | | PPV | 5.6% | 0.0% | 16.1% | Blinding: -
| Test reliability established?: Not referenced | Inclusion criteria: | | | NPV | 100.0% | 95.7% | 100.0% | Definition of +/- on screening test: +
| Statistical tests used: | 40 years or older, absence of symptoms | | | | | | | Explicit validation method?: NA
| None | Exclusion criteria:
| Blinding: No | NR
| Definition of positive and negative on screening test: | Loss to followup:
| Cyst diameter ≥ 2.5 cm, < 5 cm, with resistance index ≥ 0.41 | NR; apparently 0
| Length of followup:
| 6 months
| Type of followup:
| Repeat ultrasound
| Followup interval:
| 6 months
Levine, Gosink, Wolf, et al., 1992 | Geographical location: Portland, OR | Age: | Symptomatic (n [%]): | Monitoring test: | 1) Cancer in simple cysts: | | | | Comments:
#10320 | Dates: | Mean (SD): 63.6 (8.1) | 0 | Transabdominal/ | | Dis+ | Dis- | Tot | —Results not presented clearly
| Oct 1989-June 1990 | Range: 50–85 | Detected by exam (n [%]): | transvaginal ultrasound | T+ | 0 | 0 | 0 | —Inconsistent followup strategy
| Size of population: | Menopausal status (n [%]): | NR | Doppler and CA-125 if abnormal | T- | 0 | 32 | 32 | Quality assessment:
| 184; 32 had simple cysts at initial evaluation, 31 developed over course of study | Post (> 55): 184 (100%) | Detected by imaging (n [%]): | Interval of testing: | Tot | 0 | 32 | 32 | Reference standard: -
| Other: | Race/ethnicity (n [%]): | NR | 3 months | | | Lower | Upper | Verification bias: -
| Cross-sectional, volunteer screening | NR | Combination (n [%]): | Definition of change: | | Value | 95% CI | 95% CI | Test reliability/variability: -
| Reference standard: | Risk factors (n [%]): | NR | Increased: diameter change ≥ 3 mm | Se | - | - | - | Sample size: -
| Followup | NR | Additional data used for diagnosis: | Decreased: diameter change ≤ 3 mm | Sp | 100.0% | 90.6% | 100.0% | Statistical tests: -
| Reference standard applied to all test negatives?: Yes | Inclusion criteria: | NR | | PPV | - | - | - | Blinding: -
| Test reliability established?: Not discussed or referenced | Age ≥ 59, postmenopausal at least 1 year | | | NPV | 100.0% | 90.6% | 100.0% | Definition of +/- on screening test: +
| Statistical tests used: | Exclusion criteria: | | | | | | | Explicit validation method?:
| Chi-square, t-test | NR | | | | | | | NA
| Blinding: No | Loss to followup:
| Definition of positive and negative on screening test: | 49 of 63 women with cysts had ultrasound followup (22.2% loss to followup)
| Simple cyst - completely anechoic, unilocular, nonseptated
| Length of followup:
| 2 years (“over half one year or more”)
| Type of followup:
| Transabdominal and transvaginal ultrasound
| Followup interval:
| 3 months × 1 year, then every 6 months
Maggino, Gadducci, D'Addario, et al., 1994 | Geographical location: Padua, Pisa, Bari, Brescia, and Milan, Italy | Age: | Symptomatic (n [%]): | Monitoring test: | 1) Cancer during followup after initial benign: | | | | Comments:
#4500 | Dates: | NR for subgroup of interest | NR | Not systematic | | Dis+ | Dis- | Tot | —No details on followup strategy
| Mar 1991-Mar 1992 | Menopausal status (n [%]): | Detected by exam (n [%]): | Interval of testing: | T+ | 0 | 0 | 0 | —No details on length of followup
| Size of population: | Post (> 55): 45 (100%) | NR | NR | T- | 0 | 45 | 45 | Quality assessment:
| 335; 45 with benign cyst and CA-125 < 35 | Race/ethnicity (n [%]): | Detected by imaging (n [%]): | Definition of change: | Tot | 0 | 45 | 45 | Reference standard: +
| Case series | NR | NR | NR | | | Lower | Upper | Verification bias: +
| Reference standard: | Risk factors (n [%]): | Combination (n [%]): | | | Value | 95% CI | 95% CI | Test reliability/variability: +
| Surgery or followup | NR | NR | | Se | - | - | - | Sample size: -
| Reference standard applied to all test negatives?: Yes | Inclusion criteria: | Additional data used for diagnosis: | | Sp | 100.0% | 93.3% | 100.0% | Statistical tests: -
| Test reliability established?: Yes | Pelvic mass, at least 1 year post-menopausal | NR | | PPV | - | - | - | Blinding: -
| Statistical tests used: | Exclusion criteria: | | | NPV | 100.0% | 93.3% | 100.0% | Definition of +/- on screening test: +
| Se, Sp, PPV, NPV, Kappa | Incomplete US data, no CA-125, no histology for patients with surgery | | | | | | | Explicit validation method?: NA
| Blinding: No | Loss to followup:
| Definition of positive and negative on screening test: | 2/45 (4.4%)
| < 5 cm, thin wall, no echoes, ≤ 3 thin septa, no free fluid in pelvis
| Length of followup:
| NR
| Type of followup:
| NR
| Followup interval:
| NR
Menon, Talaat, Rosenthal, et al., 2000 | Geographical location: United Kingdom | Age: | Symptomatic (n [%]): | Monitoring test: | Among 17 patients with an equivocal scan who were triaged to followup in 4–6 weeks: | | | | Comments:
#2780 | Dates: | NR | NR | Pelvic ultrasound/serial CA-125 | -9 had simple cysts, did not have surgery, and did not develop cancer (true negatives); | | | | —Question 4 refers to patients with masses [underlined: thought to be benign]. The only categories in this paper are normal (doesn't differentiate those with probably benign masses), equivocal (can't classify as normal or abnormal) and abnormal. Not sure the “equivocal” category can be considered “masses thought to be benign,” but that is the group we focused on to answer Question 4.
| 1986-1989 | Menopausal status (n [%]): | Detected by exam (n [%]): | Interval of testing: | -1 died of ovarian cancer before her repeat ultrasound (can't categorize); | | | | —Median followup was excellent but the exact number lost to followup was not given.
| Size of population: | All older than 45 (22,000/100%) | NR | Depends on findings. If equivocal US, repeat every 6 weeks until normal or abnormal. If normal, repeat the CA-125 every 3 months for a year. If US abnormal, refer to gynecologist for a decision. | -1 died of pneumonia before a repeat ultrasound could be done (can't categorize); | | | | —Authors didn't specify what happens if a patient with a normal scan subsequently develops a rising CA-125.
| 22,000 screened; | Race/ethnicity (n [%]): | Detected by imaging (n [%]): | Definition of nl or abnl: | -5 had surgery with benign pathology found (number of followup scans not specified; all false positives); | | | | Quality assessment:
| 741 with elevated CA-125 had US; 97 scans were abnormal or equivocal | NR | NR | Normal: volume < 8.8 ml or ovaries not visualized | -1 had surgery with ovarian cancer found (true positive). | | | | Reference standard: +/-
| Screening study | Risk factors (n [%]): | Combination (n [%]): | Equivocal: volume < 8.8 with abnormal morphology | | | | | Verification bias: +/- (median followup was specified but not all negatives got surgery)
| Reference standard: | NR | NR | Abnormal: volume > 8.8 irrespective of morphology | | | | | Test reliability/variability:
| Pathology and clinical followup | Inclusion criteria: | Additional data used for diagnosis: | | | | | | Sample size: +
| Reference standard applied to all test negatives?: No | Age > 45, CA-125 > 30 on screening | NR | | | | | | Statistical tests: ?
| Test reliability established?: ? | Exclusion criteria: | | | | | | | Blinding: -
| Statistical tests used: | Premenopausal, CA-125 < 30 | | | | | | | Definition of +/- on screening test: +
| Blinding: No | Loss to followup: | | | | | | | Explicit validation method?: -
| Definition of positive and negative on screening test: | NR
| Yes
| Length of followup:
| Median 6.8 years
| Type of followup:
| Annual questionnaires, Tumor Registry, pathology
| Followup interval:
| If scan normal, repeat CA-125 every 3 months for a year. If scan equivocal, repeat every 6 weeks until it can be classified as normal or abnormal. If scan abnormal, refer to gynecologist - surgical intervention at the gynecologist's discretion.
Modesitt, Pavlik, Ueland, et al., 2003 | Geographical location: Lexington, KY | Age: | Symptomatic (n [%]): | Monitoring test: | 2763 women had 3259 unilocular cysts. Of these, 2261 (69.4%) spontaneously resolved, 220 (6.8%) persisted, 726 (22.3%) developed changes such as septa or solid areas and were no longer considered simple, 12 (0.3%) had an ovary that couldn't be visualized on a subsequent scan, and 40 (1.2%) were removed during a subsequent surgery. | | | | Comments:
#5560 | Dates: | NR | 0 | TVUS | Authors did not report how many patients had surgery. They did report that 10 patients in this “unilocular cyst” population subsequently developed ovarian cancer: | | | | —Good evidence that simple ovarian cysts almost never represent cancer and can be followed.
| 1987-2002 | Menopausal status (n [%]): | Detected by exam (n [%]): | Interval of testing: | -7 of these had an additional abnormal area that developed on their TVUS besides the simple cyst (so presumably they are not “false negatives”-they were caught by screening eventually). | | | | —Could argue that 3 of the patients who developed cancer should be treated as “false negatives” but the cancers developed either after the original cyst had resolved or in the other ovary - did 2×2 tables for both interpretations.
| Size of population: | Post (> 55): 100% | 0 | Repeat in 4–6 weeks with Doppler and CA-125 if abnormality detected. A tumor score from 0–10 was assigned based on volume and structure at the second scan. If cyst still appears simple at second scan, repeat TVUS every 3–6 months. | -2 had the cyst in question resolve spontaneously, but were ultimately diagnosed with ovarian cancer (should these be considered false negatives - probably not). | | | | Quality assessment:
| 15,106 screened with TVUS; 2763 women had 3259 unilocular ovarian cysts | Race/ethnicity (n [%]): | Detected by imaging (n [%]): | Definition of change: | -1 was ultimately diagnosed with cancer in the opposite ovary (probably not a false negative). | | | | Reference standard: +
| Screening study | NR | 2763 (100%) | Development of a septum or solid area, | They therefore claim a 0% false negative rate in unilocular cysts < 10 cm (none of these cysts subsequently turned into cancer). | | | | Verification bias: + (good followup)
| Reference standard: | Risk factors (n [%]): | Combination (n [%]): | volume >10 cm^3^, | If all 3 in question above are treated as false negatives, the 2×2 table is below: | | | | Test reliability/variability: +
| Clinical followup (mean 6.3 years) | 49% of patients with unilocular cysts were on hormone replacement therapy | 0 | papillary projections into cyst | (“by patient,” not “by cyst”) | | | | Sample size: +
| Reference standard applied to all test negatives?: Yes | Inclusion criteria: | Additional data used for diagnosis: | | | Dis+ | Dis- | Tot | Statistical tests: - (none)
| Test reliability established?: Yes | At least 50 years old | NR | | T+ | 7 | 0 | 7 | Blinding:
| Statistical tests used: | Exclusion criteria: | | | T- | 3 | 2753 | 2756 | Definition of +/- on screening test: +
| Blinding: | Known ovarian tumor prior to screening, previous diagnosis of ovarian cancer, symptoms consistent with a pelvic mass | | | Tot | 10 | 2753 | 2763 | Explicit validation method?: -
| Definition of positive and negative on screening test: | Loss to followup: | | | | | Lower | Upper
| Negative: unilocular simple cyst | NR; mean followup 6.3 years | | | | Value | 95% CI | 95% CI
| Positive: any septum, solid area, papillary projections, or volume > 10 cm^3^ | | | | Se | 70.0% | 41.6% | 98.4%
| Length of followup: | | | | Sp | 100.0% | 99.9% | 100.0%
| 6.3 years | | | | PPV | 100.0% | 57.1% | 100.0%
| Type of followup: | | | | NPV | 99.9% | 99.8% | 100.0%
| Followup interval: | | | | 2) On a “by cyst” basis, there are no false negatives, since the 3 patients who had cancers did so after the cysts in question resolved (or in the opposite ovary):
| | | | | | Dis+ | Dis- | Tot
| | | | | T+ | 7 | 0 | 7
| | | | | T- | 0 | 3252 | 3252
| | | | | Tot | 7 | 3252 | 3259
| | | | | | | Lower | Upper
| | | | | | Value | 95% CI | 95% CI
| | | | | Se | 100.0% | 57.1% | 100.0%
| | | | | Sp | 100.0% | 99.9% | 100.0%
| | | | | PPV | 100.0% | 57.1% | 100.0%
| | | | | NPV | 100.0% | 99.9% | 100.0%
Schincaglia, Brondelli, Cicognani, et al., 1994 | Geographical location: Bologna, Italy | Age: | Symptomatic (n [%]): | Monitoring test: | 1) Of the 347 patients selected for followup initially, 283 were deemed appropriate for followup using repeat ultrasound at 3- to 6-month intervals without immediate referral for FNA/surgery. Of these 283, 34 subsequently had concerning US results and were referred for level II scan and possible FNA. The results of this group of 34 are not given separately. Of the 249 who had non-concerning followup scans, none developed cancer, with followup of“at least” 1 year. Therefore Specificity is 100% for patients with an initial abnormal but “probably benign” finding who had reassuring followup studies. Sensitivity within this group cannot be calculated with the information given. | | | | Comments:
#4520 | Dates: | NR | 0 | Ultrasound | | Dis+ | Dis- | Tot | —The category “probably benign” is not really defined here, so abstractor chose the patients who had something abnormal on their original screen.
| Aug 1988-Jun 1992 | Menopausal status (n [%]): | Detected by exam (n [%]): | Interval of testing: | T+ | 2 | 96 | 98 | —According to the authors, none of the patients who were not referred to level 2 developed ovarian cancer, but the followup time was fairly minimal compared to other large screening studies.
| Size of population: | Post (> 55): 3541 (100%) | 0 | See below | T- | 0 | 249 | 249 | Quality assessment:
| -3541 screened | Race/ethnicity (n [%]): | Detected by imaging (n [%]): | Definition of change: | Tot | 2 | 345 | 347 | Reference standard: +
| -347 were asked to followup, and can be split into 2 groups: | NR | All who qualified for followup (347) | See below | | | Lower | Upper | Verification bias: - (followup not very long)
| -249 were followed with additional scans but not deemed “abnormal” enough to refer for FNA/surgery | Risk factors (n [%]): | Combination (n [%]): | Volume of ovaries: | | Value | 95% CI | 95% CI | Test reliability/variability: +
| -98 were referred for possible FNA (“abnormal”) | NR | NR | < 9 negative | Se | 100.0% | 0.0% | 100.0% | Sample size: +
| -2 cancers diagnosed in the 98 who were referred | Inclusion criteria: | Additional data used for diagnosis: | < 9 with a cyst: followup US in 6 months. Increased volume à refer to level II | Sp | 72.2% | 67.4% | 76.9% | Statistical tests: -
| -no cancers among the rest of the population (maximum followup was 1 year) | Postmenopausal, no prior pelvic surgery or pelvic symptoms | NR | 9–15: followup 3 and 6 months. Unchanged à refer to level II | PPV | 2.0% | 0.0% | 4.8% | Blinding: - (NR )
| Screening study | Exclusion criteria: | | > 15 referral to level II | NPV | 100.0% | 98.8% | 100.0% | Definition of +/- on screening test: +
| Reference standard: | Prior pelvic surgery, pelvic symptoms | | Level II: | | | | | Explicit validation method?: -
| Pathology and clinical followup up to 1 year | Loss to followup: | | Morphology assessment and biopsy if feasible
| Reference standard applied to all test negatives?: Yes | Not stated, but followup listed as “at least one year” for negative screens and those managed conservatively | | Surgery if FNA not feasible, inadequate, positive, or patient refuses FNA
| Test reliability established?: No
| Statistical tests used:
| SP, PPV
| Blinding: NR
| Definition of positive and negative on screening test:
| See under “Monitoring Strategy”
| Length of followup:
| At least 1 year
| Type of followup:
| Questionnaire for negative screens; others had followup studies as specified under “Monitoring Strategy”
| Followup interval:
| Varied by ultrasound findings
Valentin and Akrawi, 2002 | Geographical location: Malmo, Sweden | Age: | Symptomatic (n [%]): | Monitoring test: | 1) Change in US as positive test, cancer as disease: | | | | Comments:
#8490 | Dates: | Median: 61 | 84 (62.7%) | TVUS | | Dis+ | Dis- | Tot | —Complete followup
| June 1991-Nov 2000 | Range: 47–87 | Detected by exam (n [%]): | Interval of testing: | T+ | 0 | 7 | 7 | Quality assessment:
| Size of population: | Menopausal status (n [%]): | NR | 3, 6, 12, then every 12 months | T- | 0 | 127 | 127 | Reference standard: +
| 162; 134 agreed to followup (28 not followed older, had higher mortality) | Post (> 55): 134 (100%) | Detected by imaging (n [%]): | Definition of change: | Tot | 0 | 134 | 134 | Verification bias: +
| Consecutive case-series | Race/ethnicity (n [%]): | NR | Positive difference between largest diameter at most recent examination and at initial examination, or cyst “more complex” | | | Lower | Upper | Test reliability/variability: -
| Reference standard: | NR | Combination (n [%]): | Morphology improved if cyst complexity decreased | | Value | 95% CI | 95% CI | Sample size: -
| Surgery or followup | Risk factors (n [%]): | NR | | Se | | | | Statistical tests: +
| Reference standard applied to all test negatives?: Yes | NR | Additional data used for diagnosis: | | Sp | 94.8% | 91.0% | 98.5% | Blinding: -
| Test reliability established?: Yes | Inclusion criteria: | NR | | PPV | 0.0% | 0.0% | 0.0% | Definition of +/- on screening test: + (not defined, but references provided)
| Statistical tests used: | Cysts “judged to be benign,” age ≥ 40, menopausal for at least 1 year | | | NPV | 100.0% | 97.6% | 100.0% | Explicit validation method?:
| Sp, PPV, NPV | Exclusion criteria: | | | 4 additional patients were operated on for other causes | | | | NA
| Blinding: No | NR
| Definition of positive and negative on screening test: | Loss to followup:
| Referenced but not explicitly described in this paper | 0% (mortality and surgical data obtained from Swedish national registries)
| Length of followup:
| Median 3 years (range 4 months-8 years)
| Type of followup:
| Transvaginal ultrasound
| Followup interval:
| 3, 6, 12 months, then every 12 months

Evidence Table 6. Question 6: Among women with adnexal masses, what are the morbidity and mortality from diagnostic surgery (laparoscopy or laparotomy)? At what point does the risk of surgery outweigh the risk of detecting malignancy?

Study | Study Design | Patients | Clinical Presentation | Results | | | | Comments/Quality Scoring
Canis, Mage, Pouly, et al., 1994 | Geographical location: | Age: | Symptomatic (n [%]): | 1) Mortality: 0/757 (95% CI, 0 to 0.6%) | | | | Comments:
#4610 | Clermont-Ferrand, France | Mean (SD): 35.8 (12.6) | NR | 2) Morbidity (total all complications): | | | | —Unclear whether some benign cases excluded after surgery
| Dates: NR | Range: 8–84 | Detected by exam (n [%]): | 8/727 (1.1%) | | | | Quality assessment:
| Size of population: | Menopausal status (n [%]): | NR | 3) Specific complications: | | | | Size of population from which sample drawn: -
| 757 | Pre (< 45): 671 (88.6%) | Detected by imaging (n [%]): | 1 gastric laceration | | | | Number of cases: +
| Registry | Post (> 55): 86 (11.4%) | NR | 1 acute abdomen | | | | Patient selection: -
| Morbidity definitions: | 92 patients > 50 | Combination (n [%]): | 1 peritonitis (sigmoid laceration) | | | | Application of reference standard: -
| Not described | Race/ethnicity (n [%]): | NR | 2 ovarian abscess
| Length of followup after surgery: | NR | Additional data used for diagnosis: | 2 peritonitis (ruptured teratoma)
| Mean 42 months (range 3–153) | Risk factors (n [%]): | Ultrasound | 1 led to immediate re-operation
| | NR | Age | 1 led to operation for CPP 12 mo later
| | Loss to followup: | CA-125 | 1 abdominal wall endometrioma re-operated
| | 81/620 (13.1%) | “Recurrent cysts” < endometriomas, paraovarian and functional cysts, pseudoperitoneal cysts, and hydrosalpinges excluded; not clear if excluded before or after surgical diagnosis | 4) Rate of conversion to laparotomy:
| | | | Not described for non-malignant tumors
Canis, Mashiach, Wattiez, et al., 2004 | Geographical location: | Age: | Symptomatic (n [%]): | 1) Mortality: NR | | | | Comments:
#7720 | Clermont-Ferrard, France | Mean (SD): 43.6 (15.9) | NR | 2) Morbidity (total all complications): | | | | —Clinical history prior to surgery not described
| Dates: ?1992-1997 (specific dates not given) | Menopausal status (n [%]): | Detected by exam (n [%]): | Sensitivity/specificity of frozen section: Low malignant potential = cancer, “unclear” results on frozen = positive test | | | | Quality assessment:
| Size of population: | Pre (< 45): 99 (70.2%) | NR | | Dis+ | Dis- | Tot | Size of population from which sample drawn: +
| 839 total, 141 with frozen section | Post (> 55): 42 (29.8%) | Detected by imaging (n [%]): | T+ | 47 | 4 | 51 | Number of cases: -
| Single center | Race/ethnicity (n [%]): | NR | T- | 4 | 86 | 90 | Patient selection: Not described
| Morbidity definitions: | NR | Combination (n [%]): | Tot | 51 | 90 | 141 | Application of reference standard: +
| Sensitivity/specificity of frozen section | Risk factors (n [%]): | NR | | | Lower | Upper
| Length of followup after surgery: | NR | Additional data used for diagnosis: | | Value | 95% CI | 95% CI
| Up to 10 years (not uniformly) | Loss to followup: | NR | Se | 92.2% | 84.8% | 99.5%
| | NR | | Sp | 95.6% | 91.3% | 99.8%
| | | | PPV | 92.2% | 84.8% | 99.5%
| | | | NPV | 95.6% | 91.3% | 99.8%
| | | | 3) Specific complications: NR
| | | | 4) Rate of conversion to laparotomy: NR
Carley, Klingele, Gebhart, et al., 2002 | Geographical location: | Age: | Symptomatic (n [%]): | 1) Mortality: NR | | | | Quality assessment:
#8500 | Rochester, MN | Mean (SD): | History not reported | 2) Morbidity (total all complications): | | | | Size of population from which sample drawn: +
| Dates: Dec 1995-Nov 2000 | Laparotomy: 46.4 (13.5) | Detected by exam (n [%]): | Laparotomy: 2/44 (4.6%; 95% CI, 0.7, 16.7%) | | | | Number of cases: -
| Size of population: | Laparoscopy: 49.2 (15.9) | NR | 3) Specific complications: | | | | Patient selection: -
| 106 | Menopausal status (n [%]): | Detected by imaging (n [%]): | Transfusion: | | | | Application of reference standard: +
| Single center | NR | NR | Laparotomy: 1/44 (2.3%; 95% CI, 0 to 13.5%)
| Morbidity definitions: | Race/ethnicity (n [%]): | Combination (n [%]): | Laparoscopy (including conversions): 0/62
| -Febrile morbidity | NR | NR | (0 to 8.6%)
| -Transfusion | Risk factors (n [%]): | Additional data used for diagnosis: | Febrile morbidity:
| -Conversion | NR | Masses > 7 cm or with CA-125 > 35 not included in analysis; malignant pathology excluded | Laparotomy: 1/44 (2.3%; 0 to 13.5%)
| Length of followup after surgery: | Loss to followup: | | Laparoscopy: 0/62 (0 to 8.6%)
| Not specified | NR | | 4) Rate of conversion to laparotomy: 16%
Chapron, Dubuisson, and Capella-Allouc, 1997 | Geographical location: | Age: | Symptomatic (n [%]): | 1) Mortality: | | | | Comments:
#6150 | Paris, France | Mean: | NR | Laparotomy: 0/65 (95% CI, 0 to 8.3%) | | | | —Groups not comparable in terms of baseline assessment (those with higher suspicion of malignancy went to directly to laparotomy - and 21 laparotomy patients were emergency surgery secondary to “considerable hemoperitoneum”)
| Dates: Jan 1989-Dec 1994 | Laparotomy 45.7 | Detected by exam (n [%]): | Laparoscopy: 0/121 (0 to 4.5%) | | | | —Description of clinical pathway to surgery not described
| Size of population: | Laparoscopy 49.5 | NR | 2) Morbidity (total all complications): | | | | —19 of the “laparotomy” group started as laparoscopy; data not provided to summarize results by “intention to treat”
| 186 | Range: | Detected by imaging (n [%]): | Laparotomy: 10/65 (15.4%; 95% CI, 8.9 to 27.0%) | | | | —Reoperation for laparotomy group not mentioned
| Single center | Laparotomy 18–72 | NR | Laparoscopy: 10/121 (8.3%; 4.6 to 15.0%) | | | | —Didn't include transfusion as specific com[placation (1/65 in laparotomy)
| Morbidity definitions: | Laparoscopy 19–82 | Combination (n [%]): | 3) Specific complications: | | | | Quality assessment:
| -Conversion to laparotomy | Menopausal status (n [%]): | NR | Laparotomy: | | | | Size of population from which sample drawn: - (referral base not described)
| -Complications | Laparotomy | Additional data used for diagnosis: | Cystitis: 2/65 | | | | Number of cases: -
| Length of followup after surgery: | Pre (< 40): 18 (27.7%) | All patients underwent removal of adnexal | Febrile morbidity: 2/65 | | | | Patient selection: - (not described)
| NR | Peri (40–50): 28 (43.1%) | Patients with “prophylactic” adnexal removal due to age, family history excluded | Abdominal wall hematoma: 1/65 | | | | Application of reference standard: + (all patients underwent surgery)
| | Post (> 50): 19 (29.2%) | | Abdominal wall abscess: 2/65
| | Laparoscopy | | Bowel obstruction: 1/65
| | Pre (< 40): 21 (18.2%) | | Evisceration: 2/65
| | Peri (40–50): 38 (31.4%) | | Laparoscopy:
| | Post (> 50): 61 (50.4%) | | Urinary tract infection: 1/121
| | Race/ethnicity (n [%]): | | Febrile morbidity: 5/121
| | NR | | Bowel obstruction: 1/121
| | Risk factors (n [%]): | | Evisceration: 2/121 (both re-operated)
| | NR | | Sigmoid injury: 1/121 (re-operated)
| | Loss to followup: | | 4) Rate of conversion to laparotomy:
| | NR | | 19/140 (13.6%; 95% CI, 9.0 to 20.6%)
Chi, Abu-Rustum, Sonoda, et al., 2004 | Geographical location: | Age: (all patients) | Symptomatic (n [%]): | Results presented for diagnostic laparoscopy only | | | | Comments:
#7870 | New York, NY | Median: 54 | Pre-procedure history not reported | 1) Mortality: | | | | —Gynecological oncology service
| Dates: Jan 1991-Dec 2000 | Range: (15–88) | Detected by exam (n [%]): | 3/146 (2.5%; 95% CI, 0.5 to 6.3%) | | | | —Proportion of patients with adnexal mass (as opposed to other malignancies) not reported
| Size of population: | Menopausal status (n [%]): | NR | 2) Morbidity (total all complications): | | | | Quality assessment:
| 1451 (146 with diagnostic laparoscopy) | NR | Detected by imaging (n [%]): | 19/146 (13.0%; 95% CI, 8.6 to 19.8%) | | | | Size of population from which sample drawn: +
| Single center | Race/ethnicity (n [%]): | NR | 3) Specific complications: | | | | Number of cases: -
| Morbidity definitions: | NR | Combination (n [%]): | Grade 1: 14/146 (9.6%; 95% CI, 5.8 to 15.8%) | | | | Patient selection: -
| -Grade 1: use of oral medications, bedside interventions | Risk factors (n [%]): | NR | Grade 2: 1/146 (0.7%; 0 to 4.3%) | | | | Application of reference standard: +
| -Grade 2: IV medications, TPN, enteral nutrition, or blood transfusion | NR | Additional data used for diagnosis: | Grade 3: 4/146 (2.7%; 0.9 to 7.2%)
| -Grade 3: interventional radiology, endoscopy, intubation, or operation | Loss to followup: | NR | Grade 4: 0/146 (0%; 0 to 3.76%)
| -Grade 4: Residual and lasting disability that requires major rehabilitation or organ resection | NR | | 4) Rate of conversion to laparotomy:
| -Grade 5: Death | | | 15/146 (10.3%; 95% CI, 6.4 to 16.6%)
| Length of followup after surgery: | | | 5) Multivariate analysis:
| 30 days | | | Complications significantly more likely with older age, history of radiation therapy, malignancy
Childers, Nasseri, and Surwit, 1996 | Geographical location: | Age: | Symptomatic (n [%]): | 1) Mortality: | | | | Comments:
#6940 | Tucson, AZ | Mean: 52 | NR | 0/138 (95% CI, 0 to 4.0%) | | | | —Selected population - gynecological oncology service, higher probability of malignancy
| Dates: July 1991-Jan 1995 | Range: 9–91 | Detected by exam (n [%]): | 2) Morbidity (total all complications): | | | | —No data on initial clinical presentation
| Size of population: | Menopausal status (n [%]): | NR | 14/138 (10.1%; 95% CI, 6.2 to 16.7%) | | | | —Results not stratified by age or menopausal status
| 138 | NR | Detected by imaging (n [%]): | 3) Specific complications: | | | | Quality assessment:
| Single center | Race/ethnicity (n [%]): | NR | Enterotomy: 1/138 | | | | Size of population from which sample drawn: - (no data on referral base)
| Morbidity definitions: | NR | Combination (n [%]): | Vena Cava injury: 1/138 | | | | Number of cases: - (< 200)
| Complications | Risk factors (n [%]): | NR | Bowel herniation: 1/138 (re-operated) | | | | Patient selection: - (unclear how many patients did not undergo laparoscopy)
| Length of followup after surgery: | NR | Additional data used for diagnosis: | Febrile morbidity: 2/138 | | | | Application of reference standard: + (all underwent pathology)
| 23–50 months (mean 37) in patients with malignancy; not given for others | Loss to followup: | “Suspicious adnexal mass”, which on ultrasound did not meet all criteria: | Ileus: 3/138
| | NR | —Size < 10 cm | Cardiac arrhythmia: 4/138
| | | —Unilateral | Urinary retention: 2/138
| | | —Smooth borders | 4) Rate of conversion to laparotomy:
| | | —No excrescences | 11/138 (8.0%; 95% CI, 4.5 to 14.1%)
| | | —No solid parts | All for either technical reasons, debulking, or staging; none for complications
| | | —No fluid in cul-de-sac, and with no ascites, malignant cells on paracentesis, or upper abdominal masses | 5) Malignancy
| | | | 19/138 (13.8%; 95% CI, 9.1 to 20.9%)
Deckardt, Saks, and Graeff, 1994 | Geographical location: | Age: | Symptomatic (n [%]): | 1) Mortality: | | | | Comments:
#4310 | Munich, Germany | Laparotomy: | NR | Laparotomy: 0/76 (95% CI, 0 to 7.1%) | | | | —Randomization not well described; differences in baseline characteristics, types of procedure performed suggest some bias in treatment allocation
| Dates: NR | Mean: 43.6 | Detected by exam (n [%]): | Laparoscopy: 0/116 (0 to 4.7%) | | | | —No significance testing between groups to evaluate randomization
| Size of population: | Range: 20–84 | NR | 2) Morbidity (total all complications): | | | | Quality assessment:
| 192 | Laparoscopy: | Detected by imaging (n [%]): | Laparotomy: 23/76 (30.3%; 21.8 to 42.3%) | | | | Size of population from which sample drawn: - (not described)
| Single center randomized trial | Mean: 40.1 | NR | Laparoscopy: 13/116 (11.2%; 6.8 to 18.7%) | | | | Number of cases: -
| Morbidity definitions: | Range: 18–74 | Combination (n [%]): | 3) Specific complications: | | | | Patient selection: - (possible bias in treatment allocation)
| Complications | Menopausal status (n [%]): | NR | Bladder injury: | | | | Application of reference standard: +
| Length of followup after surgery: | Laparotomy: | Additional data used for diagnosis: | Laparotomy 1/76, laparoscopy 0/116
| NR | Pre (< 45): 73.7% | Premenopausal: mass > 6 cm, persistent after 6 months, symptomatic; infertility; not a corpus luteum cyst by ultrasound | Incisional hernia:
| | Post (> 55): 26.3% | Postmenopausal: any adnexal mass | Laparotomy 3/76, laparoscopy 1/116
| | Laparoscopy: | Patients randomized according to ward where they were admitted | Umbilical hernia:
| | Pre (< 45): 77.6% | | Laparotomy 0/76, laparoscopy 1/116
| | Post (> 55): 22.4% | | UTI:
| | Race/ethnicity (n [%]): | | Laparotomy 12/76, laparoscopy 2/116
| | NR | | Febrile morbidity:
| | Risk factors (n [%]): | | Laparotomy 3/76, laparoscopy 2/116
| | NR | | Bowel obstruction:
| | Loss to followup: | | Laparotomy 1/76, laparoscopy2/116
| | NR | | Chemical peritonitis:
| | | | Laparotomy 0/76, laparoscopy 1/116
| | | | Small bowel injury:
| | | | Laparotomy 2/76, laparoscopy 1/116
| | | | Pulmonary embolus:
| | | | Laparotomy 1/76, laparoscopy 0/116
| | | | Wound dehiscence:
| | | | Laparotomy 2/76, laparoscopy 1/116
| | | | 4) Rate of conversion to laparotomy:
| | | | 4/116 (3.5%; 1.2 to 9.0%)
| | | | 5) 46% of laparotomy patients received prophylactic antibiotics, compared to 2.6% of laparoscopy patients
| | | | 6) Laparoscopy patients significantly more likely to have cystectomy (60.0% vs 20.2%), less likely to have oophorectomy (0.8% vs 20.2%), less likely to have bilateral salphingo-oophorectomy (4.0 vs 21.4%)
| | | | 7) Reoperation 1/76 for laparotomy (assume 0/116 for laparoscopy?)
Dottino, Levine, Ripley, et al., 1999 | Geographical location: | Age: | Symptomatic (n [%]): | 1) Mortality: | | | | Comments:
#6920 | New York, NY | Mean (SD): 52.2 (13.1) | NR | 0/160 (95% CI, 0 to 3.4%) | | | | —Cases only performed by gynecological oncologists - suggests substantial prescreening in terms of likelihood of cancer, or anticipated difficulty of case
| Dates: Apr 1992-Apr 1996 | Menopausal status (n [%]): | Detected by exam (n [%]): | 2) Morbidity (total all complications): | | | | Quality assessment:
| Size of population: | Pre (< 45): 75 (47%) | NR | 12/160 (7.5%; 95% CI, 4.3 to 12.9%) | | | | Size of population from which sample drawn: - (no data on overall referral pool)
| 160 | Post (> 55): 85 (53%) | Detected by imaging (n [%]): | 3) Specific complications: | | | | Number of cases: - (wide CIs)
| Single center | Race/ethnicity (n [%]): | NR | Vascular injury: 2/160 (1.3%; 95% CI, 0.9 to 4.8%) | | | | Patient selection: - (not much description of characteristics, likelihood of bias)
| Morbidity definitions: | White: 146 (91%) | Combination (n [%]): | Bleeding: 1/160 (0.6%; 0 to 3.9%) | | | | Application of reference standard: + (all got pathology)
| -Conversion to laparotomy | Other: 34 (9%) | NR | Intra-op bowel injury: 1/160 (0.6%; 0 to 3.9%)
| -“Complications” | Risk factors (n [%]): | Additional data used for diagnosis: | Postop bowel obstruction: 3/160 (1.9%; 0.4 to 5.7%)
| -Reoperation | NR | All patients undergoing laparoscopic evaluation of adnexal mass by gynecologic oncologist; excluded if mass above umbilicus, other indication for laparotomy, evidence of gross metastatic disease | Postop febrile morbidity: 4/160 (2.5%; 0.8 to 6.6%)
| -Misdiagnosis | Loss to followup: | | 4) Rate of conversion to laparotomy:
| Length of followup after surgery: | NR | | Total: 19/160 (11.9%; 95% CI, 7.8 to 18.1%)
| NR, but paper published Feb 1999, last patient enrolled Apr 1996 | | | Secondary to complications: 5/160 (3.1%; 1.2 to 7.4%)
| | | | 5) Final diagnoses
| | | | Benign: 139 (87%; 95% CI, 84 to 90%)
| | | | Borderline: 8 (5%; 2.5 to 9.9%)
| | | | Ovarian cancer: 9 (5%; 2.9 to 10.6%)
| | | | 4 of 9 epithelial cancers postmenopause
| | | | Non-gynecological cancer: 4 (3%; 0.8 to 6.6%)
| | | | 6) Other:
| | | | 5 frozen sections reports changed from benign to borderline (3), malignant to benign (1), benign to cancer (1)
Fanfani, Fagotti, Ercoli, et al., 2004 | Geographical location: | Age: | Symptomatic (n [%]): | 1) Mortality: 0 | | | | Comments:
#7810 | Rome, Italy | Mean (SD): | Laparoscopy: 35 (70%) | 2) Morbidity (total all complications): | | | | —No malignancies
| Dates: Jan 2003-Aug 2003 | Laparoscopy: 36.3 (12.1) | Laparotomy: 38 (76%) | Laparoscopy: 0/50 (0%; 95% CI, 0 to 10.6%) | | | | —Small sample size
| Size of population: | Laparotomy: 37.5 (13.4) | Detected by exam (n [%]): | Laparotomy: 3/50 (6.0%; 1.8 to 17.5%) | | | | Quality assessment:
| 100 | Menopausal status (n [%]): | NR | 3) Specific complications: | | | | Size of population from which sample drawn: +
| Single center randomized trial | Laparoscopy: 5 (10%) postmenopausal | Detected by imaging (n [%]): | Fever: | | | | Number of cases: -
| Morbidity definitions: | Laparotomy: 10 (20%) postmenopausal | NR | Laparoscopy: 0 | | | | Patient selection: +
| -Ileus | Race/ethnicity (n [%]): | Combination (n [%]): | Laparotomy: 2 (4%; 95% CI, 0.6 to 14.8%) | | | | Application of reference standard: +
| -Fever (temperature ≥ 38° C on 2 consecutive measurements at least 6 hours apart) | NR | NR | Anemia:
| -Anemia (hemoglobin < 8 g/dl) | Risk factors (n [%]): | Additional data used for diagnosis: | Laparoscopy: 0
| -Bowel/bladder/ureteral injuries | NR | Randomized trial | Laparotomy: 1 (2%; 0 to 12.0%)
| Length of followup after surgery: | Loss to followup: | Patients excluded for | 4) Rate of conversion to laparotomy: 0
| 30 days | 0 | BMI > 32
| | | Cysts > 12 cm
| | | Hysterectomy required
| | | Postmenopausal and CA-125 > 35
Havrilesky, Peterson, Dryden, et al., 2003 | Geographical location: | Age: | Symptomatic (n [%]): | 1) Mortality: | | | | Comments:
#8180 | Durham, NC | Median: 43 | Clinical history NR | 0 (95% CI, 0 to 1.2%) | | | | —Presurgical history not reported
| Dates: NR | Range: 12–87 | Detected by exam (n [%]): | 2) Morbidity (total all complications): | | | | —Risk of complications increased with concurrent hysterectomy
| Size of population: | Menopausal status (n [%]): | NR | 33/396 (8.3%; 95% CI, 6.0 to 11.6%) | | | | —Risk of conversion increased with history of hysterectomy
| 396 | Pre (< 45): NR | Detected by imaging (n [%]): | 3) Specific complications: | | | | —8/396 (2%) had cancer, 4 (1%) had borderline disease
| Single center | Peri (45–55): NR | NR | Incisional disruption/infection: 7 (1.8%; 95% CI, 0.8 to 3.7%) | | | | Quality assessment:
| Morbidity definitions: | Post (> 55): 317 (37.2%) | Combination (n [%]): | Urinary retention: 3 (0.8%; 0.2 to 2.4%) | | | | Size of population from which sample drawn: +
| -Estimated blood loss ≥ 500 cc | Race/ethnicity (n [%]): | NR | Partial small bowel obstruction/prolonged ileus: 5 (1.3%; 0.5 to 3.1%) | | | | Number of cases: +
| -Incision disruption/infection | White: 71.2% | Additional data used for diagnosis: | Urinary tract injury: 1 (0.25%; 0 to 1.6%) | | | | Patient selection: -
| -Urinary retention | Black: 26.2% | NR | Bowel injury: 2 (0.5%; 0.03 to 2.0%) | | | | Application of reference standard: +
| -Small bowel obstruction | Other: 2.4% | | Nerve injury: 1 (0.25%; 0 to 1.6%)
| -Urinary tract/GI/nerve injury | Risk factors (n [%]): | | Hemorrhage: 7 (1.8%; 0.8 to 3.7%)
| -Subcutaneous emphysema | NR | | Re-exploration: 5 (1.3%; 0.5 to 3.1%)
| -Hemorrhage | Loss to followup: | | 4) Rate of conversion to laparotomy: 25%
| -Transfusion | NR | | 5) Undiagnosed cancer: 8/396 (2.0%)
| -Readmission
| -Re-exploration
| Length of followup after surgery:
| NR
Hidlebaugh, Vulga-ropulos, and Orr, 1997 | Geographical location: | Age: | Symptomatic (n [%]): | 1) Mortality: | | | | Comments:
#9490 | Worcester, MA | Range: 14–83 | NR | 0 (95% CI, 0 to 1.38%) | | | | —Selection criteria for laparoscopy vs. laparotomy not described
| Dates: Jan 1988-Dec 1995 | Menopausal status (n [%]): | Detected by exam (n [%]): | 2) Morbidity (total all complications): | | | | —Potential differences in other risk factors for complications not described
| Size of population: | Pre (< 45): NR | NR | Laparoscopy: 5/199 (2.5%; 95% CI, 1.0 to 6.0%) | | | | —Clinical history not described
| 405 | Peri (45–55): NR | Detected by imaging (n [%]): | Laparotomy: 56/206 (27.2%; 21.8 to 34.0%) | | | | Quality assessment:
| Single center | Post (> 55): 82 (20.2%) | NR | 3) Specific complications: | | | | Size of population from which sample drawn: +
| Morbidity definitions: | Race/ethnicity (n [%]): | Combination (n [%]): | Intra-operative: | | | | Number of cases: +
| -Fever | NR | NR | Laparoscopy: 1/199 (0.5%; 95% CI, 0 to 3.2%) | | | | Patient selection: -
| -Ilieus | Risk factors (n [%]): | Additional data used for diagnosis: | Laparotomy: 3/206 (1.5%; 0.3 to 4.5%) | | | | Application of reference standard: +
| -Anemia/transfusion | NR | NR | Postoperative:
| -Wound infection | Loss to followup: | | Laparoscopy: 2/199 (1.0%; 0.1 to 3.9%)
| -Deep vein thrombosis | NR | | Laparotomy: 33/206 (16.0%; 11.8 to 21.9%)
| -Reoperation | | | Late:
| -Readmission | | | Laparoscopy: 2/199 (1.0%; 0.1 to 3.9%)
| Length of followup after surgery: | | | Laparotomy: 18/206 (8.7%; 5.6 to 13.6%)
| NR | | | Readmission:
| | | | Laparoscopy: 0/199 (0%; 0 to 2.4%)
| | | | Laparotomy: 2/206 (1.0%; 0.1 to 3.8%)
| | | | 4) Rate of conversion to laparotomy:
| | | | 10/199 (5.0%; 95% CI, 2.7 to 9.2%)
Lok, Sahota, Rogers, et al., 2000 | Geographical location: | Age: | Symptomatic (n [%]): | 1) Mortality: | | | | Comments:
#8890 | Hong Kong, China | Mean (SD): 35.6 (9.8) | 389 (75.8%) | 0/513 (95% CI, 0 to 1.1%) | | | | —Preoperative history not described in detail
| Dates: NR | Menopausal status (n [%]): | Detected by exam (n [%]): | 2) Morbidity (total all complications): | | | | —Prevalence of malignancy 0.4%
| Size of population: | Pre (< 45): NR | NR | 68/513 (13.3%; 95% CI, 10.6 to 16.6%) | | | | —Criteria for selection for laparoscopic approach well described
| 513 | Peri (45–55): NR | Detected by imaging (n [%]): | 3) Specific complications: | | | | Quality assessment:
| Single center | Post (> 55): 28 (5.5%) | NR | Transfusion: 0 (95% CI, 0 to 1.1%) | | | | Size of population from which sample drawn: +
| Morbidity definitions: | Race/ethnicity (n [%]): | Combination (n [%]): | Intra-operative: 16/513 (3.1%; 1.9 to 5.1%) | | | | Number of cases: +
| -Transfusion | NR; presumably Asian | NR | Postoperative: 44 (8.6%; 6.5 to 11.4%) | | | | Patient selection: +
| -Fever | Risk factors (n [%]): | Additional data used for diagnosis: | Febrile morbidity: 20/513 (3.9%; 2.5 to 6.0%) | | | | Application of reference standard: +
| -Small bowel hernia | NR | “Concurrent problems necessitating other major laparoscopic procedures” excluded | Reoperation: 7/513 (1.4%; 0.6 to 2.9%)
| -Pelvic hematoma | Loss to followup: | | 4) Rate of conversion to laparotomy:
| -Urinary retention | NR | | 5 (0.97%; 95% CI, 0.4 to 2.4%)
| -Bowel/ureter/vascular injury | | | 5) Undiagnosed cancer: 2/513 (0.4%)
| -Reoperation
| Length of followup after surgery:
| NR
Mann and Reich, 1992 | Geographical location: | Age: | Symptomatic (n [%]): | 1) Mortality: | | | | Comments:
#10330 | Kingston, PA | Mean: 58.7 | 7 (15.9%) | 0/44 (95% CI, 0 to 11.9%) | | | | —1/44 had cancer
| Dates: NR | Range: 44–90 | Detected by exam (n [%]): | 2) Morbidity (total all complications): | | | | —Ascites, effusion only exclusion
| Size of population: | Menopausal status (n [%]): | NR | 2/44 (4.6%; 95% CI, 0.7 to 16.7%) | | | | Quality assessment:
| 44 | Post (> 55): 44 (100%) | Detected by imaging (n [%]): | 3) Specific complications: | | | | Size of population from which sample drawn: -
| Single center | Race/ethnicity (n [%]): | NR | Readmission: 2/44 (4.6%; 95% CI, 0.7 to 16.7%) | | | | Number of cases: -
| Morbidity definitions: | NR | Combination (n [%]): | 4) Rate of conversion to laparotomy: | | | | Patient selection: +
| Readmission | Risk factors (n [%]): | 37 (84.0%) ; proportion detected by exam vs imaging not reported | 2/44 (4.6%; 95% CI, 0.7 to 16.7%) | | | | Application of reference standard: +
| Length of followup after surgery: | NR | Additional data used for diagnosis: | 5) Undiagnosed cancer: 1/44 (2.3%)
| NR | Loss to followup: | NR
| | NR
Marana, Muzii, Catalano, et al., 2004 | Geographical location: | Age: | Symptomatic (n [%]): | 1) Mortality: | | | | Comments:
#5450 | Rome, Italy | Mean: 27.6 | 416 (60.9%) | 0/683 (95% CI, 0 to 0.82%) | | | | —Fairly complete reporting of important clinical information
| Dates: Jul 1990 - Dec 2001 | Range: 12–39 | Chronic pain: 147 (21.5%) | 2) Morbidity (total all complications): | | | | —Limited to premenopausal women
| Size of population: | Menopausal status (n [%]): | Dysmenorrhea: 145 (21.2%) | 6/683 (0.9%; 95% CI, 0.4 to 2.0%) | | | | —Laparotomy 1/76, laparoscopy 0/116
| 683 | Pre (< 45): 100% | Infertility: 66 (9.7%) | 3) Specific complications: | | | | Quality assessment:
| Two centers (same surgeon) | Race/ethnicity (n [%]): | Menstrual irregularity: 57 (8.3%) | Retrouterine hematoma: 3/683 | | | | Size of population from which sample drawn: - (referral base not described)
| Morbidity definitions: | NR | Abdominal swelling: 1 (0.2%) | Febrile morbidity: 2/683 | | | | Number of cases: +
| -Complications | Risk factors (n [%]): | Detected by exam (n [%]): | Ileus: 1/683 | | | | Patient selection: +
| -Recurrence | NR | 267 (39.1%) (“routine”) | Umbilical hernia: 1/683 | | | | Application of reference standard: +
| Length of followup after surgery: | Loss to followup: | Detected by imaging (n [%]): | Transfusion: 1/683
| Mean 30.2 months (minimum 6 months) | NR | Not clear which of symptomatic ones were initially detected by imaging or exam | 4) Rate of conversion to laparotomy:
| | | Combination (n [%]): | 16/683 (2.3%; 95% CI, 1.3 to 3.8%)
| | | NR | 13 patients with advanced endometriosis, 2 with large dermoids, one (0.15%) suspected malignancy (final pathology borderline)
| | | Additional data used for diagnosis: | 5) 8 patients total with final path not benign - 7 borderline, 1 focal invasive endometrioid cancer
| | | No solid components, papillation, or septae; if mass < 7 cm, ultrasound repeated in 8–12 weeks; CA-125 not done
| | | Age < 40
Parker, Levine, Howard, et al., 1994 | Geographical location: | Age: | Symptomatic (n [%]): | 1) Mortality: | | | | Comments:
#910 | Santa Monica, Irvine, and Los Angeles, CA; Louisville, KY; Rochester, NY | Mean: 65 | NR | 0/61(95% CI, 0 to 7.4%) | | | | —Initial presentation not described
| Dates: NR | Range: 47–81 | Detected by exam (n [%]): | 2) Morbidity (total all complications): | | | | —“Presumptively benign” masses form series
| Size of population: | Menopausal status (n [%]): | NR | 2/61 (3.3%; 95% CI, 0.4 to 12.3%) | | | | —Only intra-operative complications reported - length of followup after surgery not reported - assume very short or not at all?
| 61 | Post (> 55): 61 (100%) postmenopausal (> 45 with 12 months of amenorrhea, or FSH > 40 mIU/mL) | Detected by imaging (n [%]): | 3) Specific complications: | | | | Quality assessment:
| Multicenter | Race/ethnicity (n [%]): | NR | Bladder perforation: 1/61 | | | | Size of population from which sample drawn: - (referral base not described)
| Morbidity definitions: | NR | Combination (n [%]): | Sigmoid injury: 1/61 (led to laparotomy) | | | | Number of cases: -
| -Complications | Risk factors (n [%]): | NR | 4) Rate of conversion to laparotomy: | | | | Patient selection: - (not described)
| -Conversion to laparotomy | NR | Additional data used for diagnosis: | 3/61 (4.9%; 95% CI, 1.4 to 14.5%) | | | | Application of reference standard: + (laparotomy 1/76, laparoscopy 0/116)
| Length of followup after surgery: | Loss to followup: | Ultrasound done in all; masses < 10 cm, cystic, no irregularities, solid components, septae > 2 mm, no ascites = “presumptively benign”
| NR | NR | Post menopause = > 45 years old with at least 12 months amenorrhea, if prior hysterecotomy = FSH > 40
Parker and Proietto, 1997 | Geographical location: | Age: | Symptomatic (n [%]): | 1) Mortality: | | | | Quality assessment:
#9440 | Newcastle, Australia | Mean: 34.4 | NR | 0/86 (95% CI, 0 to 5.4%) | | | | Size of population from which sample drawn:
| Dates: Jan 1993-Dec 1995 | Range: 12–82 | Detected by exam (n [%]): | 2) Morbidity (total all complications): | | | | Number of cases:
| Size of population: | Menopausal status (n [%]): | NR | 19/86 (22.1%; 95% CI, 15.1 to 32.7%) | | | | Patient selection:
| 86 | NR | Detected by imaging (n [%]): | 3) Specific complications: | | | | Application of reference standard:
| Single center | Race/ethnicity (n [%]): | NR | Wound infection: 7/86 (8.1%; 95% CI, 4.0 to 16.5%)
| Morbidity definitions: | NR | Combination (n [%]): | Other infection: 5/86 (5.8%; 2.4 to 13.5%)
| -Infection | Risk factors (n [%]): | NR | Other wound: 2/86 (2.3%; 0.2 to 8.5%)
| -Hernia | NR | Additional data used for diagnosis: | 4) Rate of conversion to laparotomy:
| -Pulmonary embolus | Loss to followup: | NR | NA (all laparotomies)
| -Wound hematoma or other complication | NR | | 5) Undiagnosed cancer: 1/86 (1.2%)
| Length of followup after surgery:
| NR
Sadik, Onoglu, Gokdeniz, et al., 1999 | Geographical location: | Age: | Symptomatic (n [%]): | 1) Mortality: | | | | Comments:
#2880 | Matalyta, Turkey | Mean (SD): 30.0 (9.7) | NR | 0/220 | | | | —Data on masses converted to laparotomy not provided
| Dates: NR | Range: 13–68 | Detected by exam (n [%]): | 2) Morbidity (total all complications): | | | | —Followup not described
| Size of population: | Menopausal status (n [%]): | NR | 2/220 (0.9%) | | | | Quality assessment:
| 220 | Pre (< 45): 213 (96.8%) | Detected by imaging (n [%]): | 3) Specific complications: | | | | Size of population from which sample drawn: -
| Single center registry | Post (> 55): 7 (3.2%) | NR | Acute abdominal pain on postoperative day 5 – no cause at laparotomy | | | | Number of cases: +
| Morbidity definitions: | Race/ethnicity (n [%]): | Combination (n [%]): | Sigmoid perforation | | | | Patient selection: -
| -Hospital stay | NR | NR | 4) Rate of conversion to laparotomy: | | | | Application of reference standard: -
| -“Complications” | Risk factors (n [%]): | Additional data used for diagnosis: | Malignant masses “excluded from study”
| Length of followup after surgery: | NR | Cystic adnexal mass > 5, < 10 cm, no irregular solid parts or septae > 2mm | 5) 1 malignant dysgerminoma, 1 borderline serous cystadoma
| NR | Loss to followup: | CA-125 < 35 | 6) 146 (67.3%) ruptured masses
| | NR | No ascites, matted bowel
| | Other: | No contraindication to surgery
| | 66.9% no prior surgery
Serur, Emeney, and Byrne, 2001 | Geographical location: | Age: | Symptomatic (n [%]): | 1) Mortality: | | | | Quality assessment:
#8700 | Brooklyn, NY | Range: 17–80 | NR | 0/100 (0%; 95% CI, 0 to 5.44%) | | | | Size of population from which sample drawn: -
| Dates: Mar 1996-Nov 1998 | (Means not given for entire group) | Detected by exam (n [%]): | 2) Morbidity (total all complications): | | | | Number of cases: +
| Size of population: | Menopausal status (n [%]): | NR | 10/100 (10%; 95% CI, 5.6 to 19.0%) | | | | Patient selection: -
| 100 (19 converted to laparotomy) | Pre (< 45): 51 (51%) | Detected by imaging (n [%]): | 3) Specific complications: NR | | | | Application of reference standard: +
| Single center | Post (> 55): 49 (49%) | NR | 4) Rate of conversion to laparotomy:
| Morbidity definitions: | Race/ethnicity (n [%]): | Combination (n [%]): | 19/100 (19%; 95% CI, 12.8 to 38.6%)
| -Pneumothorax | NR | NR
| -Wound infection | Risk factors (n [%]): | Additional data used for diagnosis:
| -Fever | NR | NR
| -Enterotomy | Loss to followup:
| -Pneumonia | 1/100 (1%)
| Length of followup after surgery:
| Variable: 6 weeks for all
| All masses except patients with complex masses, ascites, and “elevated” CA-125
Shalev, Eliyahu, Peleg, et al., 1994 | Geographical location: | Age: | Symptomatic (n [%]): | 1) Mortality: | | | | Comments:
#10140 | Afula, Israel | NR | NR | 0/55 (95% CI, 0 to 9.6%) | | | | —Preoperative history not reported
| Dates: May 1988-June 1993 | Menopausal status (n [%]): | Detected by exam (n [%]): | 2) Morbidity (total all complications): | | | | Quality assessment:
| Size of population: | Post (> 55): 204 (100%) | NR | 6/55 (10.9%; 95% CI, 5.2 to 22.9%) | | | | Size of population from which sample drawn: -
| 204; 55 underwent laparoscopy | Race/ethnicity (n [%]): | Detected by imaging (n [%]): | 3) Specific complications: | | | | Number of cases: -
| Single center | NR | NR | “Fever or pain” – not specified further | | | | Patient selection: +
| Morbidity definitions: | Risk factors (n [%]): | Combination (n [%]): | 4) Rate of conversion to laparotomy: | | | | Application of reference standard: +
| -Fever | NR | NR | 0/55 (95% CI, 0 to 9.6%)
| -Pain (prolonged hospitalization) | Loss to followup: | Additional data used for diagnosis:
| Length of followup after surgery: | NR | Inclusion: Simple or septate unilateral mass, CA-125 < 35
| NR
Somigliana, Ragni, Benedetti, et al., 2003 | Geographical location: | Age: | Symptomatic (n [%]): | 1) Mortality: NR | | | | Quality assessment:
#8140 | Milan, Italy | Mean (SD): 32.2 (3.7) | NR | 2) Morbidity (total all complications): | | | | Size of population from which sample drawn: -
| Dates: Jan 2001-Dec 2002 | Menopausal status (n [%]): | Detected by exam (n [%]): | Number of follicles after stimulation significantly lower in ovary where cyst removed (2.0 ± 1.5) compared to other ovary (4.2 ± 2.5) | | | | Number of cases: -
| Size of population: | Pre (< 45): 32 (100%) | NR | 3) Specific complications: NR | | | | Patient selection: +
| 32 | Race/ethnicity (n [%]): | Detected by imaging (n [%]): | 4) Rate of conversion to laparotomy: NR | | | | Application of reference standard: -
| Single center | NR | NR
| Morbidity definitions: | Risk factors (n [%]): | Combination (n [%]):
| Number of follicles in response to ovarian stimulation after removal of endometriotic cyst | NR | NR
| Length of followup after surgery: | Loss to followup: | Additional data used for diagnosis:
| Mean 2.4 (± 1.7) years | NR | NR
Tangjit-gamol, Jesadapa-trakul, Manusiri-vithaya, et al., 2004 | Geographical location: | Age: | Symptomatic (n [%]): | 1) Mortality: NR | | | | Comments:
#1570 | Bangkok, Thailand | Mean (SD): 45.9 (17.1) | NR | 2) Morbidity (total all complications): | | | | —Presurgical history not reported
| Dates: Jan 1992-Dec 2002 | Range: 13–89 | Detected by exam (n [%]): | “Defer” or greater = positive test, borderline = malignant | | | | Quality assessment:
| Size of population: | Menopausal status (n [%]): | NR | | Dis+ | Dis- | Tot | Size of population from which sample drawn: +
| 212 | NR | Detected by imaging (n [%]): | T+ | 84 | 8 | 92 | Number of cases: +
| Single center | Race/ethnicity (n [%]): | NR | T- | 8 | 112 | 120 | Patient selection: +
| Morbidity definitions: | NR | Combination (n [%]): | Tot | 92 | 120 | 212 | Application of reference standard: +
| Sensitivity/specificity of frozen section | Risk factors (n [%]): | NR | | | Lower | Upper
| Length of followup after surgery: | NR | Additional data used for diagnosis: | | Value | 95% CI | 95% CI
| NR | Loss to followup: | NR | Se | 91.3% | 85.5% | 97.1%
| | NA | | Sp | 93.3% | 88.9% | 97.8%
| | | | PPV | 91.3% | 85.5% | 97.1%
| | | | NPV | 93.3% | 88.9% | 97.8%
| | | | “Defer” or greater = positive test, borderline = benign
| | | | | Dis+ | Dis- | Tot
| | | | T+ | 66 | 9 | 75
| | | | T- | 10 | 127 | 137
| | | | Tot | 76 | 136 | 212
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 86.8% | 79.2% | 94.4%
| | | | Sp | 93.4% | 89.2% | 97.6%
| | | | PPV | 88.0% | 80.6% | 95.4%
| | | | NPV | 92.7% | 88.3% | 97.1%
| | | | 3) Specific complications: NR
| | | | 4) Rate of conversion to laparotomy: NR
Tarik and Fehmi, 2004 | Geographical location: | Age: | Symptomatic (n [%]): | 1) Mortality: | | | | Comments:
#7770 | Ankara, Turkey | Mean (SD): | NR | 0/3572 (95% CI, 0 to 0.13%) | | | | —Proportion with pre-op diagnosis of adnexal mass not reported
| Dates: 1996-2003 | Diagnostic: 27.2 (4.6) | Detected by exam (n [%]): | 2) Morbidity (total all complications): | | | | —No malignancies
| Size of population: | Minor: 30.3 (3.2) | NR | Diagnostic: 7/386 (1.8%; 95% CI, 0.8 to 3.8%) | | | | —Preprocedure history not reported
| 3572 (386 diagnostic laparoscopy, 1092 minor procedures) | Menopausal status (n [%]): | Detected by imaging (n [%]): | Minor: 15/1092 (1.4%; 0.8 to 2.3%) | | | | Quality assessment:
| Single center | NR | NR | 3) Specific complications: | | | | Size of population from which sample drawn: +
| Morbidity definitions: | Race/ethnicity (n [%]): | Combination (n [%]): | Vascular injury: | | | | Number of cases: +
| -Vascular injury | NR | NR | Diagnostic: 4/386 (1.0%; 95% CI, 0.3 to 2.8%) | | | | Patient selection: -
| -Urinary tract injury | Risk factors (n [%]): | Additional data used for diagnosis: | Minor: 5/1092 (0.5%; 0.2 to 1.1%) | | | | Application of reference standard: +
| -Bowel injury | NR | NR | Bowel injury:
| -Postoperative complications | Loss to followup: | | Diagnostic: 2/386 (0.5%; 0.03 to 2.0%)
| Length of followup after surgery: | NR | | Minor:
| NR | | | 4) Rate of conversion to laparotomy: NR
van Herendael, Beretta, Slangen, et al., 1995 | Geographical location: | Age: | Symptomatic (n [%]): | 1) Mortality: | | | | Comments:
#9830 | Antwerp, Belgium and Varese, Italy | Mean: 36 | NR | 0/121 (95% CI, 0 to 4.5%) | | | | —Preoperative history not reported in detail
| Dates: Jan 1989-Dec 1993 | Range: 18–63 | Detected by exam (n [%]): | 2) Morbidity (total all complications): | | | | Quality assessment:
| Size of population: | Menopausal status (n [%]): | NR | 2/121 (1.7%; 95% CI, 0.1 to 6.4%) | | | | Size of population from which sample drawn: -
| 121 | NR | Detected by imaging (n [%]): | 3) Specific complications: | | | | Number of cases: -
| Single center | Race/ethnicity (n [%]): | NR | Anemia (no transfusion): | | | | Patient selection: +
| Two centers | NR | Combination (n [%]): | 2/121 (1.7%; 95% CI, 0.1 to 6.4%) | | | | Application of reference standard: +
| Morbidity definitions: | Risk factors (n [%]): | NR | 4) Rate of conversion to laparotomy:
| -Conversion | NR | Additional data used for diagnosis: | 3/121 (2.5%; 95% CI, 0.6 to 7.5%)
| -Anemia | Loss to followup: | NR
| Length of followup after surgery: | NR
| Median 20 months (range 1–60 months)
Yuen, Yu, Yip, et al., 1997 | Geographical location: | Age: | Symptomatic (n [%]): | 1) Mortality: | | | | Comments:
#6930 | Hong Kong | Mean (SD): | Laparotomy: 32 (64%) | Laparotomy: 0/50 (95% CI, 0 to 10.6%) | | | | — Well-defined complications
| Dates: Jul 1994-Sep 1995 | Laparotomy: 34.7 (8.8) | Laparoscopy: 28 (54%) | Laparoscopy: 0/52 (0 to 10.2%) | | | | Quality assessment:
| Size of population: | Laparoscopy: 35.1 (10.3) | Detected by exam (n [%]): | 2) Morbidity (total all complications): | | | | Size of population from which sample drawn: -
| 110 | Menopausal status (n [%]): | Asymptomatic: | Total: | | | | Number of cases: + (a priori sample size calculation)
| Single center | Laparotomy | Laparotomy 18 (36%) | Laparotomy: 14/50 (28%; 95% CI, 18.5 to 43.1%) | | | | Patient selection: +
| Morbidity definitions: | Pre (< 45): 47 (94%) | Laparoscopy 24 (46.1%) | Laparoscopy: 4/52 (9.6%; 4.2 to 21.8%) | | | | Application of reference standard: +
| -Complications | Post (> 55): 3 (6%) | Detected by imaging (n [%]): | Intraoperative
| -Cyst rupture rate | Laparoscopy | NR | Laparotomy: 1/50 (2.0%; 0 to 12.0%)
| Length of followup after surgery: | Pre (< 45): 50 (96.2%) | Combination (n [%]): | Laparoscopy: 1/52 (1.9%; 0 to 11.6%)
| 8 weeks | Post (> 55): 2 (3.8%) | NR | Postoperative:
| | Race/ethnicity (n [%]): | Additional data used for diagnosis: | Laparotomy: 13/50 (26%; 16.8 to 41.0%)
| | NR; presumably most Asian | Cystic masses with no irregular solid parts, thick septae, ascites; except dermoid | Laparoscopy 4/52 (7.8%; 2.9 to 19.3%)
| | Risk factors (n [%]): | | 3) Specific complications:
| | NR | | Laparotomy:
| | Loss to followup: | | Bladder injury: 1/50
| | 4/110 (3.6%) | | Febrile morbidity: 10/50
| | | | UTI: 5/50
| | | | Urinary retention: 4/50
| | | | Wound infection: 1/50
| | | | Laparoscopy:
| | | | Inf epigastric artery injury: 1/52
| | | | Febrile morbidity: 3/52
| | | | UTI: 2/52
| | | | 4) Rate of conversion to laparotomy:
| | | | 0/52
| | | | 5) Cyst rupture rate
| | | | Lapartomy: 9/30 (30%; 95% CI, 18.4 to 50.3%)
| | | | Laparoscopy: 9/33 (27.3%; 16.5 to 46.4%)

Evidence Table 7. Question 7: What are the estimated trade-offs resulting from various strategies for evaluation of the adnexal mass?

Study | Study Design | Study Outcomes | Sources for Model Probabilities | Sources for Model Outcomes | Results | Comments
Schapira, Matchar, and Young, 1993 | Type of model: | Life-expectancy | No data used for transition probabilities. One time screen assumed. Used NCI data to determine prevalence of disease in 40 year old population. Adjusted for % that would present with symptoms. | DEALE used to determine life expectancy. 1988 NCHS figures used to estimate average life expectancy. | 1) CA125+TVS – 40.192 years | Progression of ovarian cancer assumed to proceed in stepwise fashion through stages
#4870 | Decision tree | No costs included | National Halothane study used for estimate of laparotomy mortality | Note European citations 31 and 32 for life expectancy for those with early and late stage cancer. | No Screen - 40.191 years
| Population modeled (age, range): | | Simplifying assumptions: | | 2) No screening preferred if post-operative mortality rate > 7.32% or specificity of the test is 98.35%
| Cohort of healthy 40-year old women. | | Assume that survival time for early disease detected by screening or clinical symptoms is equivalent | | 3) Findings similar although LE gains not as great for women aged 65+. Specificity of test ≥ 99.25% in order for screening to be favored.
| Life expectancy based on average life expectancy in the US for a 40-year old woman. | | Morbidity and mortality rates for diagnostic laparotomy are the same for pts with and without the disease
| Strategies compared: | | No benefit from identifying benign disease
| No screening to screening using CA 125 and TVS in combination | | One-time screen
Skates and Singer, 1991 | Type of model: | Years of life saved (undiscounted) | Assumes; - log-normal distribution for each stage; - correlation between duration of adjacent stages is high, lower for stages far apart; - coefficient of variation constant across all stages | Massachusetts General Hospital survival data for cancer | Based on “best” estimates of mean duration and variation of duration, 3.4 ± 1 year of life saved per case by annual screening; range of 1–5 years | —Model assumes stepwise progression through disease stages (“all tumors are assumed to pass through all four stages if there is no intervention”
#7000 | Stochastic simulation model | | Estimates and ranges for duration of stage obtained from 2 gynecologic oncologists | Life tables for competing cause of death | Overall increase in life expectancy (cases and noncases) not reported | —Source of estimates for natural history parameters obtained from only 2 gynecologic oncologists (not discussed in article, only evident from reference 11 (personal communications)
| Population modeled: | | Stage I: 9 months | | Results sensitive to assumptions about duration of early stage cancer, frequency of screening | —Assumption regarding duration of disease and likelihood of detection doesn't necessarily reflect biology of disease
| (age, range): | | Stage II: 4.5 months | | | —Model output of stage distribution in unscreened population not reported.
| Age 50 to 75 | | Stage III: 12 months
| Strategies compared: | | Stage IV: 3 months
| CA-125 screening | | Range corresponded to CV of approximately 50%
| | | Stage at clinical detection is independent of duration of disease; “major determinant of detection being the size and spread of the tumor and not it's rate of growth”
| | | CA-125 produced from “tumor inception”
| | | Screen detected cases have identical survival within each stage as clinically detected cases
| | | Survival independent of age
Tengs, Winer, Paddock, et al., 1998 | Type of model: | Life years saved quality adjusted life years saved | Test accuracy provided by survey of companies marketing the tests | SEER data and literature (Rubin, NEJM, 1996) used for ovarian cancer 5 year survival | 1) Immediate mastectomy + oophorectomy offers greatest gains in survival when measured using LE | —Only considers prophylactic oophorectomy in setting of positive BRCA1/2 test; testing for early stage disease not considered
#6010 | Markov model | No costs included | SEER data for incidence - adjusted to account for the fact that data does not distinguish between those with genetic risk and those without. | NCHS for non-breast ovarian cancer survival | Testing offers no benefit. | —Natural history of ovarian cancer not explicitly modeled
| Population modeled (age, range): | | Literature used to estimate 92% risk reduction for breast cancer. | Unclear where data for utilities came from | 2) Optimal intervention depends on pre-test probability of carrying mutation.
| 30-year old woman testing for BRCA 1 and 2 | | Cancer experts for effectiveness of oophorectomy w/wout mastectomy | | 3) When QALYs incorporated, depends on the test characteristics. If test is perfectly sens and spec then maximizes QALYs. If not perfectly sens and spec, then depends again on pre-test probability of mutation.
| Strategies compared | | Simplifying assumptions:
| Testing for BRCA 1 and 2 with the following surgical options: | | “Operative mortality not included in the model as it would not have…an appreciable effect.”
| Do nothing
| Mastectomy
| Mastectomy and oophorectomy
| Oophorectomy
Urban, Drescher, Etzioni and Colby 1997 | Type of model: | Years of life saved | Age and stage based on SEER data | Costs are based on a survey of labs, hospital clinics, and physician offices in Seattle, WA | Multimodal strategy using CA 125 with a threshold for positivity of either elevation above 35U/ml or doubling since the previous screen, followed by TVS only if CA 125 is positive was found to be efficient. (Cost/year of life saved is $64,000) | —Model assumes stepwise progression through disease stages; assumption based on opinion of clinicians (Skates and Singer 1991, above)
#6140 | Stochastic simulation model | | Length of Stage 1 assumed to be independent of stage of disease at clinical diagnosis; | Note: used a 5% discount rate for the analysis | Effectiveness and cost-effectiveness sensitive to assumptions about the behavior of early stage disease
| Population modeled: | | Model assumes disease stages that correspond to FIGO staging with durations that are distributed log-normally with geometric means of 9, 4.5 12 and 3 months respectively,
| (age, range): | | Stage 2 – ½ of Stage I; Stage 3, 1.333 times the length of Stage I; Stage 4, .333 times the length of Stage 1.
| Age 50 to 80 | | Used data from Skates and Singer to model natural history
| Strategies compared: | | 0.001 probability of death each time laparotomy is performed.
| TVS and CA-125

## Abbreviations used in the Evidence Tables

2D | Two-dimensional
3D | Three-dimensional
AFP | Alpha-fetoprotein
AHRQ | Agency for Healthcare Research and Quality
AUC | Area under the curve
BME | Bimanual examination
BMI | Body mass index
CA-19-9 | Cancer antigen 19-9
CA-72–4 | Cancer antigen 72–4
CA-125 | Cancer antigen 125
CEA | Carcinoembryonic antigen
CI | Confidence interval
CPP | Chronic pelvic pain
CT | Computed tomography
F-FDG | 18-Fluorodeoxyglucose
FNA | Fine needle aspiration
FSH | Follicle-stimulating hormone
GI | Gastrointestinal
hCG | Human chorionic gonadotropin
ICD-9 | International Classification of Diseases, Ninth Revision
LDH | Lactate dehydrogenase
LMP | Low malignant potential
MRI | Magnetic resonance imaging
NIS | Nationwide Inpatient Sample
NA | Not applicable
NPV | Negative predictive value
NR | Not reported
OR | Odds ratio
PE | Pelvic examination
PET | Positron emission tomography
PI | Pulsatility index
PID | Pelvic inflammatory disease
PPS | Papillary projection score
PPV | Positive predictive value
PSV | Peak systolic velocity
RI | Resistance index
RMI | Risk of Malignancy Index
ROC | Receiver operating characteristic
SD | Standard deviation
Se | Sensitivity
SEM | Standard error of the mean
Sp | Specificity
TAG-72 | Tumor-associated glycoprotein 72
TAMXV | Time-averaged maximum velocity
ATI | Tumor-associated trypsin inhibitor
TVUS | Transvaginal ultrasound
US | Ultrasound
UTI | Urinary tract infection