# Appendix C: Sample Data Abstraction Forms

Table C1 Question 1: What is the prevalence of various tumor types among peri- and postmenopausal women with an adnexal mass, stratified by cancer status (malignant vs. benign), age, and size of tumor?

Study | Study Design | Patients | Clinical Presentation | Results | Comments/Quality Scoring
StudyID | Geographical location: | Age: | Symptomatic (n [%]): | [Proportion of each type of finding, stratified by cancer status, age/menopausal status (<45, 45–55, >55 or pre-peri-post-menopausal), and size of tumor. Include individual tumor types where possible.] | [IF ARTICLE SHOULD BE EXCLUDED, PLEASE EXPLAIN WHY HERE]
| Dates: | Mean (SD): | Detected by exam (n [%]): | Use Excel spreadsheet to calculate confidence intervals for prevalence data from screening studies | [COMMENT ON BIASES, ETC. AFFECTING CLINICAL INTERPRETATION]
| Size of population: | Median: | Detected by imaging (n [%]): | 1) | Quality assessment:
| [num/denom for screening studies] | Range: | Combination (n [%]): | 2) | [assign + or - to each item, and provide a brief rationale]
| Screening study Registry | Menopausal status (n [%]): | Additional data used for diagnosis: | 3) | Size of population from which sample drawn:
| Other | Pre (< 45): | | 4) | Number of cases:
| [delete all but one; please specify “Other”] | Peri (45–55): | | 5) | Patient selection:
| | Post (> 55): | | | Application of reference standard:
| | Race/ethnicity (n [%]): | | | This article is also relevant to: [delete as appropriate]
| | Risk factors (n [%]): | | | Question 2
| | Family history: | | | Question 3
| | Genotype: | | | Question 4
| | Other [specify]: | | | Question 5
| | | | | Question 6
| | | | | Question 7

Table C2 Question 2: What are the sensitivity, specificity, and reliability of the bimanual examination?

Study | Study Design | Patients | Clinical Presentation | Clinical Setting of Exam | Results | Comments/Quality Scoring
StudyID | Geographical location: | Age: | Symptomatic (n [%]): | [Please provide brief description of clinical setting in which bimanual exam was performed] | [For bimanual exam, provide reported sensitivity/specificity and provide 2×2 tables (if possible). If possible and appropriate, stratify by age or menopausal status. If data are available on reliability/ reproducibility, report these as well. Include kappa scores if these are reported or can be calculated.] | [IF ARTICLE SHOULD BE EXCLUDED, PLEASE EXPLAIN WHY HERE]
| Dates: | Mean (SD): | Detected by exam (n [%]): | | 1) [Use this space to provide information needed for reader to interpret Test +, Test -, Disease +, and Disease - headings in following table.] | [COMMENT ON BIASES, ETC. AFFECTING CLINICAL INTERPRETATION]
| Size of population: | Median: | Detected by imaging (n [%]): | | | Quality assessment:
| [num/denom for screening studies] | Range: | Combination (n [%]): | | | [assign + or - to each item, and provide a brief rationale]
| Screening study Registry | Menopausal status (n [%]): | Additional data used for diagnosis: | | | Reference standard:
| Other | Pre (< 45): | | | | Verification bias:
| [delete all but one; please specify “Other”] | Peri (45–55): | | | | Test reliability/variability:
| Reference standard: | Post (> 55): | | | | Sample size:
| Reference standard applied to all test negatives?: | Race/ethnicity (n [%]): | | | | Statistical tests:
| Test reliability established?: | Risk factors (n [%]): | | | | Blinding:
| Statistical tests used: | Family history: | | | | Definition of +/- on screening test:
| Blinding: | Genotype: | | | | This article is also relevant to: [delete as appropriate]
| Definition of positive and negative on screening test: | Other [specify]: | | | 2) | Question 1
| | Inclusion criteria: | | | | Question 2
| | Exclusion criteria: | | | | Question 3
| | | | | | Question 4
| | | | | | Question 5
| | | | | | Question 7

Table C3 Question 3: Among peri- and postmenopausal women with a palpable adnexal mass on exam or a mass identified by ultrasound/imaging, what is the sensitivity/specificity of various evaluation modalities including ultrasound (transvaginal ultrasound, transabdominal ultrasound, color Doppler, 2-D vs 3D ultrasound, CT scan, MRI scan, and CA-125 levels) for diagnosing malignant masses?

Study | Study Design | Patients | Clinical Presentation | Results | Comments/Quality Scoring
StudyID | Geographical location: | Age: | Symptomatic (n [%]): | [For each test reported, please provide a 2×2 table and report or calculate sensitivity, specificity, NPV, and PPV (all with confidence intervals). If possible and appropriate, stratify by age or menopausal status.] | [IF ARTICLE SHOULD BE EXCLUDED, PLEASE EXPLAIN WHY HERE]
| Dates: | Mean (SD): | Detected by exam (n [%]): | 1) [Use this space to provide information needed for reader to interpret Test +, Test -, Disease +, and Disease - headings in following table.] | [COMMENT ON BIASES, ETC. AFFECTING CLINICAL INTERPRETATION]
| Size of population: | Median: | Detected by imaging (n [%]): | | Quality assessment:
| [num/denom for screening studies] | Range: | Combination (n [%]): | | [assign + or - to each item, and provide a brief rationale]
| Screening study Registry | Menopausal status (n [%]): | Additional data used for diagnosis: | | Reference standard:
| Other | Pre (< 45): | | | Verification bias:
| [delete all but one; please specify “Other”] | Peri (45ndash;55): | | | Test reliability/variability:
| Reference standard: | Post (> 55): | | | Sample size:
| Reference standard applied to all test negatives?: | Race/ethnicity (n [%]): | | | Statistical tests:
| Test reliability established?: | Risk factors (n [%]): | | | Blinding:
| Statistical tests used: | Family history: | | | Definition of +/- on screening test:
| Blinding: | Genotype: | | 2) | This article is also relevant to: [delete as appropriate]
| Definition of positive and negative on screening test: | Other [specify]: | | | Question 1
| | Inclusion criteria: | | | Question 3
| | Exclusion criteria: | | | Question 4
| | | | | Question 5
| | | | | Question 6
| | | | | Question 7

Table C4 Question 4: What is the accuracy of explicit scoring systems which incorporate various combinations of imaging findings, patient risk factors, and/or CA-125 levels for detecting malignancy? Have these scoring systems been applied to a population of peri-/postmenopausal women before laparoscopy?

Study | Study Design | Patients | Clinical Presentation | Items Included in Scoring System | Results | Comments/Quality Scoring
StudyID | Geographical location: | Age: | Symptomatic (n [%]): | 1) | [For each reported scoring system (and individual components, if reported), provide reported sensitivity/specificity and provide 2×2 table; if multivariate analysis, provide area under ROC curve or c-statistic, if reported. If possible and appropriate, stratify by age or menopausal status.] | [IF ARTICLE SHOULD BE EXCLUDED, PLEASE EXPLAIN WHY HERE]
| Dates: | Mean (SD): | Detected by exam (n [%]): | 2) | 1) [Use this space to provide information needed for reader to interpret Test +, Test -, Disease +, and Disease - headings in following table.] | [COMMENT ON BIASES, ETC. AFFECTING CLINICAL INTERPRETATION]
| Size of population: | Median: | Detected by imaging (n [%]): | 3) | 2) | Quality assessment:
| [num/denom for screening studies] | Range: | Combination (n [%]): | 4) | Results were reported, but have not been abstracted, for the following combinations: [list] | [assign + or - to each item, and provide a brief rationale]
| Screening study Registry | Menopausal status (n [%]): | Additional data used for diagnosis: | 5) | | Reference standard:
| Other | Pre (< 45): | | 6) | | Verification bias:
| [delete all but one; please specify “Other”] | Peri (45–55): | | 7) | | Test reliability/variability:
| Reference standard: | Post (> 55): | | 8) | | Sample size:
| Reference standard applied to all test negatives?: | Race/ethnicity (n [%]): | | 9) | | Statistical tests:
| Statistical tests used: | Risk factors (n [%]): | | 10) | | Blinding:
| Blinding: | Family history: | | | | Definition of +/- on screening test:
| Definition of positive and negative on screening test: | Genotype: | | | | Explicit validation method?:
| | Other [specify]: | | | | This article is also relevant to: [delete as appropriate]
| | Inclusion criteria: | | | | Question 1
| | Exclusion criteria: | | | | Question 2
| | | | | | Question 4
| | | | | | Question 5
| | | | | | Question 6
| | | | | | Question 7

Table C5 Question 5: Among women with suspected benign lesions on initial investigation, what is the sensitivity and specificity of monitoring with periodic CA-125 and/or interval ultrasound examinations for detecting malignant masses? How does the interval of testing/definition of change affect sensitivity and predictive value?

Study | Study Design | Patients | Clinical Presentation | Monitoring Strategy | Results | Comments/Quality Scoring
StudyID | Geographical location: | Age: | Symptomatic (n [%]): | Monitoring test: | [For each reported monitoring strategy, provide reported sensitivity/specificity and provide 2×2 table; if multivariate analysis, provide area under ROC curve or c-statistic, if reported. If possible and appropriate, stratify by age or menopausal status.] | [IF ARTICLE SHOULD BE EXCLUDED, PLEASE EXPLAIN WHY HERE]
| Dates: | Mean (SD): | Detected by exam (n [%]): | Interval of testing: | 1) [Use this space to provide information needed for reader to interpret Test +, Test -, Disease +, and Disease - headings in following table.] | [COMMENT ON BIASES, ETC. AFFECTING CLINICAL INTERPRETATION]
| Size of population: | Median: | Detected by imaging (n [%]): | Definition of change: | 2) | Quality assessment:
| [num/denom for screening studies] | Range: | Combination (n [%]): | | 3) | [assign + or - to each item, and provide a brief rationale]
| Screening study Registry | Menopausal status (n [%]): | Additional data used for diagnosis: | | | Reference standard:
| Other | Pre (< 45): | | | | Verification bias:
| [delete all but one; please specify “Other”] | Peri (45–55): | | | | Test reliability/variability:
| Reference standard: | Post (> 55): | | | | Sample size:
| Reference standard applied to all test negatives?: | Race/ethnicity (n [%]): | | | | Statistical tests:
| Test reliability established?: | Risk factors (n [%]): | | | | Blinding:
| Statistical tests used: | Family history: | | | | Definition of +/- on screening test:
| Blinding: | Genotype: | | | | Explicit validation method?:
| Definition of positive and negative on screening test: | Other [specify]: | | | | This article is also relevant to: [delete as appropriate]
| Length of follow up: | Inclusion criteria: | | | | Question 1
| Type of follow up: | Exclusion criteria: | | | | Question 2
| Follow-up interval: | Loss to follow up: | | | | Question 3
| | | | | | Question 5
| | | | | | Question 6
| | | | | | Question 7

Table C6 Question 6: Among women with adnexal masses, what is the morbidity and mortality from diagnostic laparoscopy? At what point does the risk of laparoscopy outweigh the risk of detecting malignancy?

Study | Study Design | Patients | Clinical Presentation | Results | Comments/Quality Scoring
StudyID | Geographical location: | Age: | Symptomatic (n [%]): | [For each, provide reported rate and 95% CI, if appropriate. If possible and appropriate, stratify results by age or menopausal status.] | [IF ARTICLE SHOULD BE EXCLUDED, PLEASE EXPLAIN WHY HERE]
| Dates: | Mean (SD): | Detected by exam (n [%]): | Use Excel spreadsheet to calculate confidence intervals for morbidity/mortality | [COMMENT ON BIASES, ETC. AFFECTING CLINICAL INTERPRETATION]
| Size of population: | Median: | Detected by imaging (n [%]): | 1) Mortality: | Quality assessment:
| [num/denom for screening studies] | Range: | Combination (n [%]): | 2) Morbidity (total all complications): | [assign + or - to each item, and provide a brief rationale]
| Single center Registry | Menopausal status (n [%]): | Additional data used for diagnosis: | 3) Specific complications: | Size of population from which sample drawn:
| [delete one] | Pre (< 45): | | 4) Rate of conversion to laparotomy: | Number of cases:
| Morbidity definitions: | Peri (45–55): | | 5) | Patient selection:
| Length of follow up after surgery: | Post (> 55): | | 6) | Application of reference standard:
| | Race/ethnicity (n [%]): | | | This article is also relevant to: [delete as appropriate]
| | Risk factors (n [%]): | | | Question 1
| | Family history: | | | Question 2
| | Genotype: | | | Question 3
| | Other [specify]: | | | Question 4
| | Loss to follow up: | | | Question 6
| | | | | Question 7

Table C7 Question 7: What are the estimated trade-offs resulting from various strategies for evaluation of the adnexal mass?

Study | Study Design | Study Outcomes | Sources for Model Probabilities | Sources for Model Outcomes | Results | Comments
StudyID | Type of model: | [Life expectancy, quality of life, cancer incidence, cancer death, etc. Include costs, but we will not be using them here] | [In particular, sources for transition probabilities between different stages of pre-cancer/cancer] | | [For each strategy compared, compare results for different outcomes; also, report results of significant sensitivity analyses.] | [IF ARTICLE SHOULD BE EXCLUDED, PLEASE EXPLAIN WHY HERE]
| Population modeled (age, range): | | Simplifying assumptions: | | 1) | [COMMENT ON BIASES, ETC. AFFECTING CLINICAL INTERPRETATION]
| Strategies compared: | | | | 2) | This article is also relevant to: [delete as appropriate]
| | | | | 3) | Question 1
| | | | | 4) | Question 2
| | | | | 5) | Question 3
| | | | | 6) | Question 4
| | | | | | Question 5
| | | | | | Question 6