# Appendix B: List of Excluded Studies

All excluded studies listed below were reviewed in their full text version. Following each reference, in italics, is the reason(s) for exclusion and the Question (Q) for which the article was considered. If no Q is indicated, then the article was excluded a priori from the study for the reason given. An article can be considered (and therefore excluded) for more than one question, and all questions for which the article was excluded are identified. Reasons for exclusion signify only the usefulness of the articles for this study and are not intended as criticisms of the articles.

For reference, the questions are:

Question 1: What is the prevalence of various tumor types among women with an adnexal mass, stratified by cancer status (malignant vs. benign), age, menopausal status, and size of tumor?

Question 2: What are the sensitivity, specificity, and reliability of the bimanual examination?

Question 3: Among women with a palpable adnexal mass on exam or a mass identified by ultrasound/imaging, what is the sensitivity/specificity of various evaluation modalities including ultrasound (transvaginal ultrasound, transabdominal ultrasound, color Doppler, 2D vs. 3D ultrasound, CT scan, MRI scan, and CA-125 levels) for diagnosing malignant masses?

Question 4: What is the accuracy of explicit scoring systems which incorporate various combinations of imaging findings, patient risk factors, and/or CA-125 levels for detecting malignancy? Have these scoring systems been applied to a population of women before laparoscopy?

Question 5: Among women with suspected benign lesions on initial investigation, what are the sensitivity and specificity of monitoring with periodic CA-125 and/or interval ultrasound examinations for detecting malignant masses? How does the interval of testing/definition of change affect sensitivity and predictive value?

Question 6: Among women with adnexal masses, what are the morbidity and mortality from diagnostic surgery (laparoscopy or laparotomy)? At what point does the risk of laparoscopy outweigh the risk of detecting malignancy?

Question 7: What are the estimated trade-offs resulting from various strategies for evaluation of the adnexal mass?

## List of Excluded Studies

Abu-Rustum NR, Rhee EH, Chi DS, et al. Subcutaneous tumor implantation after laparoscopic procedures in women with malignant disease.[see comment]. Obstet Gynecol. 2004;103(3):480-7. Exclude no mass. [pmid: 14990410].
Adonakis GL, Paraskevaidis E, Tsiga S, et al. A combined approach for the early detection of ovarian cancer in asymptomatic women. Eur J Obstet Gynecol Reprod Biol. 1996;65(2):221-5. Exclude Q5-wrong pt population. [pmid: 8730628].
Alcazar JL, Jurado M. Using a logistic model to predict malignancy of adnexal masses based on menopausal status, ultrasound morphology, and color Doppler findings. Gynecol Oncol. 1998;69(2):146-50. Exclude Q3-unable to construct 2×2. [pmid: 9600822].
Alcazar JL, Jurado M. Prospective evaluation of a logistic model based on sonographic morphologic and color Doppler findings developed to predict adnexal malignancy. J Ultrasound Med. 1999;18(12):837-42. Exclude Q3-unable to construct 2×2. [pmid: 10591449].
Alcazar JL, Laparte C, Jurado M, et al. The role of transvaginal ultrasonography combined with color velocity imaging and pulsed Doppler in the diagnosis of endometrioma. Fertil Steril. 1997;67(3):487-91. Exclude Q1-sample size. [pmid: 9091335].
Alcazar JL, Ruiz-Perez ML, Errasti T. Transvaginal color Doppler sonography in adnexal masses: which parameter performs best?. Ultrasound Obstet Gynecol. 1996;8(2):114-9. Exclude Q3-unable to construct 2×2. [pmid: 8883314].
Alexander-Sefre F, Menon U, Jacobs IJ. Ovarian cancer screening. Hosp Med. 2002;63(4):210-3. Exclude review. [pmid: 11995270].
Ali N, Jan H, Van Trappen P, et al. Radioimmunoscintigraphy with Tc-99m-labelled SM3 in differentiating malignant from benign adnexal masses. BJOG. 2003;110(5):508-14. Exclude Q3-experimental or non-standard test. [pmid: 12742337].
Alvarez RD, Kilgore LC, Partridge EE, et al. Staging ovarian cancer diagnosed during laparoscopy: accuracy rather than immediacy. South Med J. 1993;86(11):1256-8. Exclude review. [pmid: 8235778].
Alvarez-Sanchez F, Brache V, de Oca VM, et al. Prevalence of enlarged ovarian follicles among users of levonorgestrel subdermal contraceptive implants (Norplant). Am J Obstet Gynecol. 2000;182(3):535-9. Exclude Q3-no histol. dx. [pmid: 10739504].
American College of Obstetricians and Gynecologists. ACOG Committee Opinion: number 280, December 2002. The role of the generalist obstetrician-gynecologist in the early detection of ovarian cancer. Obstet Gynecol. 2002;100(6):1413-6. Exclude review. [pmid: 12468197].
Anderiesz C, Quinn MA. Screening for ovarian cancer. Med J Aust. 2003;178(12):655-6. Exclude review. [pmid: 12797860].
Andersen WA, Nichols GE, Avery SR, et al. Cytologic diagnosis of ovarian tumors: factors influencing accuracy in previously undiagnosed cases. Am J Obstet Gynecol. 1995;173(2):457-63. discussion 463–4. Exclude Q3-wrong test. [pmid: 7645621].
Anderson MM, Irwin CE Jr, Snyder DL. Abnormal vaginal bleeding in adolescents. Pediatr Ann. 1986;15(10):697-701. Exclude Q1-no histol. dx. [pmid: 3785996].
Andolf E, Jorgensen C, Astedt B. Ultrasound examination for detection of ovarian carcinoma in risk groups. Obstet Gynecol. 1990;75(1):106-9. Exclude Q7-not descrip of sim model. [pmid: 2404221].
Angeid-Backman E, Coleman BG, Arger PH, et al. Comparison of resistive index versus pulsatility index in assessing the benign etiology of adnexal masses. Clin Imaging. 1998;22(4):284-91. Exclude no mass. [pmid: 9699050].
Aslam N, Tailor A, Lawton F, et al. Prospective evaluation of three different models for the pre-operative diagnosis of ovarian cancer. BJOG. 2000;107(11):1347-53. Exclude Q3-inconsistent data. [pmid: 11117760].
Aubel S, Wozney P, Edwards RP. MRI of female uterine and juxta-uterine masses: clinical application in 25 patients. Magn Reson Imaging. 1991;9(4):485-91. Exclude Q3-sample size. [pmid: 1779718].
Bandera CA, Ye B, Mok SC. New technologies for the identification of markers for early detection of ovarian cancer. Curr Opin Obstet Gynecol. 2003;15(1):51-5. Exclude review. [pmid: 12544502].
Baron AT, Cora EM, Lafky JM, et al. Soluble epidermal growth factor receptor (sEGFR/sErbB1) as a potential risk, screening, and diagnostic serum biomarker of epithelial ovarian cancer. Cancer Epidemiol Biomarkers Prev. 2003;12(2):103-13. Exclude no mass. [pmid: 12582019].
Bast RC Jr, Feeney M, Lazarus H, et al. Reactivity of a monoclonal antibody with human ovarian carcinoma. J Clin Invest. 1981;68(5):1331-7. Exclude no mass. [pmid: 7028788]. [pmcid: 370929].
Bast RC Jr, Knauf S, Epenetos A, et al. Coordinate elevation of serum markers in ovarian cancer but not in benign disease. Cancer. 1991;68(8):1758-63. [pmid: 1913520].
Bast RC Jr, Urban N, Shridhar V, et al. Early detection of ovarian cancer: promise and reality. Cancer Treat Res. 2002;107:61-97. Exclude review. [pmid: 11775462].
Bell R, Petticrew M, Sheldon T. The performance of screening tests for ovarian cancer: results of a systematic review. Br J Obstet Gynaecol. 1998;105(11):1136-47. Exclude no mass. [pmid: 9853761].
Benacerraf BR, Finkler NJ, Wojciechowski C, et al. Sonographic accuracy in the diagnosis of ovarian masses. J Reprod Med. 1990;35(5):491-5. Exclude Q3-distguish malignant versus nonmalignant. [pmid: 2191131].
Berlanda N, Ferrari MM, Mezzopane R, et al. Impact of a multiparameter, ultrasound-based triage on surgical management of adnexal masses. Ultrasound Obstet Gynecol. 2002;20(2):181-5. Exclude Q6-no M&M data. [pmid: 12153670].
Biran G, Golan A, Sagiv R, et al. Conversion of laparoscopy to laparotomy due to adnexal malignancy. Eur J Gynaecol Oncol. 2002;23(2):157-60. Exclude Q6-no M&M data/Exclude Q4-unable to construct 2×2/ Exclude Q3-unable to construct 2×2. [pmid: 12013116].
Blend MJ, Ostrowski GJ. Recent advances in the detection of ovarian cancer: a review. J Am Osteopath Assoc. 1994;94(4):305-18. Exclude review. [pmid: 8026999].
Bohm-Velez M, Mendelson E, Bree R, et al. Ovarian cancer screening. American College of Radiology. ACR Appropriateness Criteria. Radiology. 2000;215(Suppl):861-71. Exclude review. [pmid: 11037511].
Bohm-Velez M, Mendelson E, Bree R, et al. Suspected adnexal masses. American College of Radiology. ACR Appropriateness Criteria. Radiology. 2000;215(Suppl):931-8. Exclude review. [pmid: 11037519].
Boll D, Geomini PM, Brolmann HA, et al. The pre-operative assessment of the adnexal mass: the accuracy of clinical estimates versus clinical prediction rules. BJOG. 2003;110(5):519-23. Exclude Q4-partial dupl new data not relevant. [pmid: 12742339].
Bossuyt PM, Reitsma JB, Bruns DE, et al. Towards complete and accurate reporting of studies of diagnostic accuracy: the STARD initiative. Clin Radiol. 2003;58(8):575-80. Exclude review. [pmid: 12887949].
Bourne TH, Campbell S, Reynolds KM, et al. Screening for early familial ovarian cancer with transvaginal ultrasonography and colour blood flow imaging. BMJ. 1993;306(6884):1025-9. Exclude no mass. [pmid: 8490496]. [pmcid: 1677026].
Bourne TH, Hampson J, Reynolds K, et al. Screening for early ovarian cancer. Br J Hosp Med. 1992;48(8):454-9. Exclude review. [pmid: 1422556].
Brown DL, Frates MC, Laing FC, et al. Ovarian masses: can benign and malignant lesions be differentiated with color and pulsed Doppler US?. Radiology. 1994;190(1):333-6. Exclude Q3-sample size. [pmid: 8284377].
Brown DL, Zou KH, Tempany CM, et al. Primary versus secondary ovarian malignancy: imaging findings of adnexal masses in the Radiology Diagnostic Oncology Group Study. Radiology. 2001;219(1):213-8. Exclude no mass. [pmid: 11274559].
Buist MR, Golding RP, Burger CW, et al. Comparative evaluation of diagnostic methods in ovarian carcinoma with emphasis on CT and MRI. Gynecol Oncol. 1994;52(2):191-8. Exclude Q6-no M&M data. [pmid: 8314138].
Buquet RA, Amato AR, Huang GB, et al. Is preoperative selection of patients with cystic adnexal masses essential for laparoscopic treatment?. J Am Assoc Gynecol Laparosc. 1999;6(4):477-81. Exclude Q6-no M&M data. [pmid: 10548708].
Buy JN, Ghossain MA, Mark AS, et al. Focal hyperdense areas in endometriomas: a characteristic finding on CT. AJR Am J Roentgenol. 1992;159(4):769-71. Exclude Q3-distguish malignant versus nonmalignant. [pmid: 1326887].
Buy JN, Ghossain MA, Sciot C, et al. Epithelial tumors of the ovary: CT findings and corrrelation with US. Radiology. 1991;178:811-18. Exclude Q3-unable to construct 2×2. [pmid: 1994423].
Campbell S, Bhan V, Royston P, et al. Transabdominal ultrasound screening for early ovarian cancer. BMJ. 1989;299(6712):1363-7. Exclude no mass. [pmid: 2513964]. [pmcid: 1838264].
Canis M, Bassil S, Wattiez A, et al. Fertility following laparoscopic management of benign adnexal cysts. Hum Reprod. 1992;7(4):529-31. Exclude Q6-review. [pmid: 1387882].
Canis M, Pouly JL, Wattiez A, et al. Laparoscopic management of adnexal masses suspicious at ultrasound. Obstet Gynecol. 1997;89(5 Pt 1):679-83. Exclude Q6-no M&M data. [pmid: 9166300].
Caoili EM, Hertzberg BS, Kliewer MA, et al. Refractory shadowing from pelvic masses on sonography: a useful diagnostic sign for uterine leiomyomas. AJR Am J Roentgenol. 2000;174(1):97-101. Exclude no mass. [pmid: 10628461].
Cappelleri JC, Ioannidis JP, Schmid C. Large trials vs meta-analysis of smaller trials: how do their results compare?. JAMA. 1996;276:1332-8. Exclude review. [pmid: 8861993].
Carlson KJ, Skates SJ, Singer DE. Screening for ovarian cancer. Ann Intern Med. 1994;121(2):124-32. Exclude review. [pmid: 8017726].
Carter J. An update on ovarian cancer screening. Aust N Z J Obstet Gynaecol. 1994;34(2):169-74. Exclude no mass. [pmid: 7980306].
Carter J, Fowler J, Carson L, et al. How accurate is the pelvic examination as compared to transvaginal sonography? A prospective, comparative study. J Reprod Med. 1994;39(1):32-4. Exclude Q3-distguish malignant versus nonmalignant/ Exclude Q2-unable to construct 2×2. [pmid: 8169913].
Carter J, Saltzman A, Hartenbach E, et al. Flow characteristics in benign and malignant gynecologic tumors using transvaginal color flow Doppler. Obstet Gynecol. 1994;83(1):125-30. Exclude Q3-distguish malignant versus nonmalignant. [pmid: 8272293].
Chadha P, Puri M, Gupta R. A comparative evaluation of clinical examination, pelvic ultrasound and laparoscopy in the diagnosis of pelvic masses. Indian J Med Sci. 1994;48(7):158-60. Exclude Q2-unable to construct 2×2. [pmid: 7959976].
Chalas E, Constantino J, Wickerham L, et al. Benign gynecologic conditions among participants in the breast cancer prevention trial. Am J Obstet and Gynecol. 2005;192:1230-9. Exclude Q1-wrong pt population. [pmid: 15846210].
Cherry C, Vacchiano SA. Ovarian cancer screening and prevention. Semin Oncol Nurs. 2002;18(3):167-73. Exclude no mass. [pmid: 12184039].
Childers JM, Aqua KA, Surwit EA, et al. Abdominal-wall tumor implantation after laparoscopy for malignant conditions. Obstet Gynecol. 1994;84(5):765-9. Exclude no mass. [pmid: 7936509].
Close RJ, Sachs CJ, Dyne PL. Reliability of bimanual pelvic examinations performed in emergency departments. West J Med. 2001;175(4):240-4. Exclude Q2-unable to construct 2×2. [pmid: 11577050].
Cohen L, Fishman DA. Ultrasound and ovarian cancer. Cancer Treat Res. 2002;107:119-32. Exclude review. [pmid: 11775447].
Cooper BC, Ritchie JM, Broghammer CL, et al. Preoperative serum vascular endothelial growth factor levels: significance in ovarian cancer. Clin Cancer Res. 2002;8(10):3193-7. Exclude Q3-experimental or non-standard test. [pmid: 12374688].
Crade M, Yiu-Chiu V, Kincaid K. Color Doppler and ovarian masses: familiarity breeds confidence. Ultrasound Obstet Gynecol. 1995;6(5):373-4. Exclude Q3-no histol. dx. [pmid: 8590214].
Crawford RA, Gore ME, Shepherd JH. Ovarian cancers related to minimal access surgery.[see comment]. Br J Obstet Gynaecol. 1995;102(9):726-30. Exclude no mass. [pmid: 7547764].
Crayford TJ, Campbell S, Bourne TH, et al. Benign ovarian cysts and ovarian cancer: a cohort study with implications for screening. Lancet. 2000;355(9209):1060-3. Exclude Q5-wrong pt population. [pmid: 10744092].
Creasman WT, Soper JT. The undiagnosed adnexal mass after the menopause. Clin Obstet Gynecol. 1986;29(2):446-52. Exclude Q1-study design not case series or cohort. [pmid: 3720067].
Crump C, McIntosh MW, Urban N, et al. Ovarian cancer tumor marker behavior in asymptomatic healthy women: implications for screening. Cancer Epidemiol Biomarkers Prev. 2000;9(10):1107-11. Exclude review. [pmid: 11045795].
Crvenkovic G, Karlan BY, Platt LD. Current role of ultrasound in ovarian cancer screening. Clin Obstet Gynecol. 1996;39(1):259-67. Exclude review. [pmid: 8635305].
de Bruijn HW, van der Zee AG, Aalders JG. The value of cancer antigen 125 (CA 125) during treatment and follow-up of patients with ovarian cancer. Curr Opin Obstet Gynecol. 1997;9(1):8-13. Exclude Q3-distguish malignant versus nonmalignant. [pmid: 9090475].
De Vries SO, Hunink MG, Polak JF. Summary receiver operating characteristic curves as a technique for meta analysis of the diganoistic performance of duplex ultrasonography in peripheral arterial disease. Acad Radiol. 1996;3:361-9. Exclude review. [pmid: 8796687].
Decloedt J, Berteloot P, Vergote I. The feasibility of open laparoscopy in gynecologic-oncologic patients. Gynecol Oncol. 1997;66(1):138-40. Exclude no mass. [pmid: 9234934].
Demirkiran F, Kumbak B, Bese T, et al. Vascular endothelial growth factor in adnexal masses. Int J Gynaecol Obstet. 2003;83(1):53-8. Exclude Q3-experimental or non-standard test. [pmid: 14511872].
Dgani R, Shani A, Elchalal U, et al. The leukocyte adherence inhibition test (LAI) in preoperative diagnosis of epithelial ovarian cancer. Gynecol Oncol. 1993;49(3):349-53. Exclude Q3-wrong test. [pmid: 8314537].
Dietrich M, Osmers RG, Grobe G, et al. Limitations of the evaluation of adnexal masses by its macroscopic aspects, cytology and biopsy. Eur J Obstet Gynecol Reprod Biol. 1999;82(1):57-62. Exclude Q3-wrong test. [pmid: 10192486].
Dixon JG, Bognar BA, Keyserling TC, et al. Teaching women's health skills: confidence, attitudes and practice patterns of academic generalist physician. J Gen Intern Med. 2003;18(6):411-8. Exclude review. [pmid: 12823647]. [pmcid: 1494877].
Dogan MM, Ugur M, Soysal SK, et al. Transvaginal sonographic diagnosis of ovarian endometrioma. Int J Gynaecol Obstet. 1966;52(2):145-9. Exclude no mass. [pmid: 8855093].
Domar AD. Psychological aspects of the pelvic exam: individual needs and physician involvement. Women Health. 1985-1986;10(4):75-90. Exclude no mass.
Dordoni D, Zaglio S, Zucca S, et al. The role of sonographically guided aspiration in the clinical management of ovarian cysts. J Ultrasound Med. 1993;12(1):27-31. Exclude Q3-wrong test. [pmid: 8455217].
Dorum A, Blom G, Ekerhovd E, et al. Prevalence and histologic diagnosis of adnexal cysts in postmenopausal women: an autopsy study. Am J Obstet Gynecol. 2005;192:48-54. Exclude non U.S. [pmid: 15672002].
Dueholm M, Lundorf E, Hansen ES, et al. Magnetic resonance imaging and transvaginal ultrasonography for the diagnosis of adenomyosis. Fertil Steril. 2001;76(3):588-94. Exclude no mass. [pmid: 11532486].
Ehlen T. Management of low malignant potential tumour of the ovary: a policy statement. SOGC/GOC/SCC Policy and Practice Guideline Committee 2000;(85). Exclude review.
Einhorn N. Ovarian cancer. Early diagnosis and screening. Hematol Oncol Clin North Am. 1992;6(4):843-50. Exclude no mass. [pmid: 1500389].
Eisen A, Rebbeck TR, Wood WC, et al. Prophylactic surgery in women with a hereditary predisposition to breast and ovarian cancer. J Clin Oncol. 2000;18(9):1980-95. Exclude review. [pmid: 10784640].
Elg S, Lee RB, Stones C, et al. Evaluation of serum haptoglobin levels in patients with adnexal masses. Mil Med. 1989;154(5):234-6. Exclude Q3-experimental or non-standard test. [pmid: 2499834].
Elit L. Surgical management of an adnexal mass suspicious for malignancy. SOGC Clinical Practice Guidelines 2000;(97). Exclude review.
Elwood M. Proteomic patterns in serum and identification of ovarian cancer. Lancet. 2002;360(9327):170-1. Exclude no mass. [pmid: 12126844].
Emery J, Yaphe J, Priest P, et al. Screening for ovarian cancer. Lancet. 1999;354(9177):509-10. Exclude no mass. [pmid: 10465193].
Fadare O, Mariappan MR, Wang S, et al. The histologic subtype of ovarian tumors affects the detection rate by pelvic washings. Cancer. 2004;102(3):150-6. Exclude no mass. [pmid: 15211473].
Fayed ST, Ahmad SM, Kassim SK, et al. The value of CA 125 and CA72-4 in management of patients with epithelial ovarian cancer. Dis Markers. 1998;14(3):155-60. Exclude Q3-no verification test negative. [pmid: 10427474].
Fedele L, Bianchi S, Dorta M, et al. Transvaginal ultrasonography versus hysteroscopy in the diagnosis of uterine submucous myomas. Obstet Gynecol. 1991;77(5):745-8. Exclude no mass. [pmid: 2014089].
Fedele L, Bianchi S, Dorta M, et al. Transvaginal ultrasonography in the differential diagnosis of adenomyoma versus leiomyoma. Am J Obstet Gynecol. 1992;167(3):603-6. Exclude no mass. [pmid: 1530011].
Finkler NJ. Clinical utility of CA 125 in preoperative diagnosis of patients with pelvic masses. Eur J Obstet Gynecol Reprod Biol. 1993;49(12):105-7. Exclude Review. [pmid: 8365503].
Finkler NJ, Benacerraf B, Lavin PT, et al. Comparison of serum CA 125, clinical impression, and ultrasound in the preoperative evaluation of ovarian masses. Obstet Gynecol. 1988;72(4):659-64. Exclude Q1-no histol. dx. [pmid: 3047614].
Fishman DA, Cohen L, Blank SV, et al. The role of ultrasound evaluation in the detection of early-stage epithelial ovarian cancer. Am J Obstet Gynecol. 2005;192(4):1214-21. discussion 1221–2. Exclude Q3-unable to construct 2×2. [pmid: 15846205].
Fleischer AC, Cullinan JA, Jones HW 3rd, et al. Correlation of histomorphology of ovarian masses with color Doppler sonography. Ultrasound Med Biol. 1996;22(5):555-9. Exclude Q3-unable to construct 2×2. [pmid: 8865552].
Fleischer AC, Cullinan JA, Kepple DM, et al. Conventional and color Doppler transvaginal sonography of pelvic masses: a comparison of relative histologic specificities. J Ultrasound Med. 1993;12(12):705-12. Exclude Q3-unable to construct 2×2. [pmid: 8301708].
Fleischer AC, Jones HW 3rd. Color Doppler sonography of ovarian masses: the importance of a multiparameter approach. Gynecol Oncol. 1993;50(1):1-2. Exclude review. [pmid: 8349149].
Fleischer AC, McKee MS, Gordon AN, et al. Transvaginal sonography of postmenopausal ovaries with pathologic correlation. J Ultrasound Med. 1990;9(11):637-44. Exclude no mass. [pmid: 2258995].
Fleischer AC, Rodgers WH, Rao BK, et al. Assessment of ovarian tumor vascularity with transvaginal color Doppler sonography. J Ultrasound Med. 1991;10(10):563-8. Exclude Q3-publ duplicate. [pmid: 1942222].
Flynn MK, Niloff JM. Outpatient minilaparotomy for ovarian cysts. J Reprod Med. 1999;44(5):399-404. Exclude Q6-no M&M data. [pmid: 10360250].
Foxall MJ, Barron CR, Houfek JF. Ethnic influences on body awareness, trait anxiety, perceived risk, and breast and gynecologic cancer screening practices. Oncol Nurs Forum. 2001;28(4):727-38. Exclude review. [pmid: 11383186].
Franchi M, Beretta P, Ghezzi F, et al. Diagnosis of pelvic masses with transabdominal color Doppler, CA 125 and ultrasonography. Acta Obstet Gynecol Scand. 1995;74(9):734-9. Exclude Q4-unable to construct 2×2. [pmid: 7572110].
Frederick JL, Paulson RJ, Sauer MV. Routine use of vaginal ultrasonography in the preoperative evaluation of gynecologic patients. An adjunct to resident education. J Reprod Med. 1991;36(11):779-82. Exclude no mass. [pmid: 1765955].
Frenkel Y, Oelsner G, Ben-Baruch G, et al. Major surgical complications of laparoscopy. Eur J Obstet Gynecol Reprod Biol. 1981;12(2):107-11. Exclude Other All Premenopausal. [pmid: 6459254].
Gadducci A, Baicchi U, Marrai R, et al. Pretreatment plasma levels of fibrinopeptide-A (FPA), D-dimer (DD), and von Willebrand factor (vWF) in patients with ovarian carcinoma. Gynecol Oncol. 1994;53(3):352-6. Exclude Q3-wrong test. [pmid: 8206409].
Gadducci A, Marrai R, Baicchi U, et al. Preoperative D-dimer plasma assay is not a predictor of clinical outcome for patients with advanced ovarian cancer. Gynecol Oncol. 1997;66(1):85-8. Exclude no mass. [pmid: 9234926].
Geomini P, Bremer G, Kruitwagen R, et al. Diagnostic accuracy of frozen section diagnosis of the adnexal mass: a metanalysis. [Review] [43 refs] [Journal Article. Meta-Analysis. Review] Gynecol Oncol. 2005;96(1):1-9. Exclude review. [pmid: 15589572].
Goff BA, Mandel L, Muntz HG, et al. Ovarian carcinoma diagnosis. Cancer. 2000;89(10):2068-75. Exclude review. [pmid: 11066047].
Grab D, Flock F, Stohr I, et al. Classification of asymptomatic adnexal masses by ultrasound, magnetic resonance imaging, and positron emission tomography. Gynecol Oncol. 2000;77(3):454-9. Exclude Q4-not scoring system. [pmid: 10831359].
Granberg S, Wikland M. A comparison between ultrasound and gynecologic examination for detection of enlarged ovaries in a group of women at risk for ovarian carcinoma. J Ultrasound Med. 1988;7(2):59-64. Exclude no mass. [pmid: 3279225].
Gryspeerdt S, Clabout L, Van Hoe L, et al. Intraperitoneal contrast material combined with CT for detection of peritoneal metastases of ovarian cancer. Eur J Gynaecol Oncol. 1998;19(5):434-7. Exclude no mass. [pmid: 9863905].
Guerriero S, Ajossa S, Lai MP, et al. The diagnosis of functional ovarian cysts using transvaginal ultrasound combined with clinical parameters, CA125 determinations, and color Doppler. Eur J Obstet Gynecol Reprod Biol. 2003;110(1):83-8. Exclude other all premenopausal. [pmid: 12932878].
Guerriero S, Ajossa S, Lai MP, et al. Transvaginal ultrasonography associated with colour Doppler energy in the diagnosis of hydrosalpinx. Hum Reprod. 2000;15(7):1568-72. Exclude Q3-no cancer outcome. [pmid: 10875867].
Guerriero S, Mais V, Ajossa S, et al. The role of endovaginal ultrasound in differentiating endometriomas from other ovarian cysts. Clin Exp Obstet Gynecol. 1995;22(1):20-2. Exclude Other All Premenopausal. [pmid: 7736636].
Guerriero S, Mais V, Ajossa S, et al. Transvaginal ultrasonography combined with CA-125 plasma levels in the diagnosis of endometrioma. Fertil Steril. 1996;65(2):293-8. Exclude other all premenopausal. [pmid: 8566251].
Guerriero S, Mallarini G, Ajossa S, et al. Transvaginal ultrasound and computed tomography combined with clinical parameters and CA-125 determinations in the differential diagnosis of persistent ovarian cysts in premenopausal women. Ultrasound Obstet Gynecol. 1997;9(5):339-43. Exclude Q4-all premenopausal/ Exclude Q3-all premenopausal. [pmid: 9201878].
Guidozzi F. Screening for ovarian cancer. Obstet Gynecol Surv. 1996;51(11):696-701. Exclude no mass. [pmid: 8914162].
Hakama M, Stenman UH, Knekt P, et al. CA 125 as a screening test for ovarian cancer. J Med Screen. 1996;3(1):40-2. Exclude no mass. [pmid: 8861050].
Hall DJ, Hurt WG. The adnexal mass. J Fam Pract. 1982;14(1):135-40. Exclude no mass. [pmid: 7054360].
Hamm B, Kubik-Huch RA, Fleige B. MR imaging and CT of the female pelvis: radiologic-pathologic correlation. Eur Radiol. 1999;9(1):3-15. Exclude Q3-sample size. [pmid: 9933373].
Hamper UM, Sheth S, Abbas FM, et al. Transvaginal color Doppler sonography of adnexal masses: differences in blood flow impedance in benign and malignant lesions. AJR Am J Roentgenol. 1993;160(6):1225-8. Exclude Q3-unable to construct 2×2. [pmid: 8498222].
Hartge P, Hayes R, Reding D, et al. Complex ovarian cysts in postmenopausal women are not associated with ovarian cancer risk factors. Am J Obstet and Gynecol. 2000;183(5):1232-7. Exclude Q1-no histol. dx. [pmid: 11084571].
Hata K, Hata T, Collins WP. Association of thymidine phosphorylase concentration with ultrasound-derived indices of blood flow in ovarian masses. Cancer. 1997;80(6):1079-84. Exclude Q3-sample size. [pmid: 9305708].
Hata K, Miyazaki K, Collins WP. Value of end-points from multiple or worst case Doppler spectra for the assessment of ovarian masses. Ultrasound Obstet Gynecol. 1999;13(4):284. Exclude no mass. [pmid: 10341412].
Hata K, Nagami H, Iida K, et al. Expression of thymidine phosphorylase in malignant ovarian tumors: correlation with microvessel density and an ultrasound-derived index of angiogenesis. Ultrasound Obstet Gynecol. 1998;12(3):201-6. Exclude Q3-no histol. dx. [pmid: 9793193].
Hefler L, Mayerhofer K, Nardi A, et al. Serum soluble Fas levels in ovarian cancer. Obstet Gynecol. 2000;96(1):65-9. Exclude no mass. [pmid: 10862844].
Helzlsouer KJ, Bush TL, Alberg AJ, et al. Prospective study of serum CA-125 levels as markers of ovarian cancer. JAMA. 1993;269(9):1123-6. Exclude no mass. [pmid: 8433467].
Hensley ML, Castiel M, Robson ME. Screening for ovarian cancer: what we know, what we need to know. Oncology (Huntingt) 2000;14(11):1601–8, 1613–6. Exclude no mass.
Hricak H, Chen M, Coakley FV, et al. Complex adnexal masses: detection and characterization with MR imaging—multivariate analysis. Radiology. 2000;214(1):39-46. Exclude Q1-denom is masses. [pmid: 10644099].
Hulka JF, Hulka CA. Preoperative sonographic evaluation and laparoscopic management of persistent adnexal masses: a 1994 review. J Am Assoc Gynecol Laparosc. 1994;1(3):197-205. Exclude review. [pmid: 9050487].
Im S, Gordon A, Buttin B, et al. Validation of referral guidelines for women with pelvic masses. Obstet Gyencol. 2005;205(1):35-41. Exclude Q4-not scoring system/Exclude Q3-unable to construct 2×2.
Irwig L, Tosteson A, Gatsonis C. Guidelines for meta-analyses evaluating diagnositc tests. Ann Intern Med. 1994;120:667-76. Exclude review. [pmid: 8135452].
Jacobs I. Genetic, biochemical, and multimodal approaches to screening for ovarian cancer. Gynecol Oncol. 1994;55(3 Pt 2):S22-7. Exclude no mass. [pmid: 7835805].
Jacobs I, Davies AP, Bridges J, et al. Prevalence screening for ovarian cancer in postmenopausal women by CA 125 measurement and ultrasonography. BMJ. 1993;306(6884):1030-4. Exclude no mass. [pmid: 8490497]. [pmcid: 1677033].
Jacobs I, Oram D. Screening for ovarian cancer. Biomed Pharmacother. 1988;42(9):589-96. Exclude review. [pmid: 3071382].
Jacobs I, Stabile I, Bridges J, et al. Multimodal approach to screening for ovarian cancer. Lancet. 1988;1(8580):268-71. Exclude Q4-unable to construct 2×2. [pmid: 2893084].
Jacobs IJ, Oram DH, Bast RC Jr. Strategies for improving the specificity of screening for ovarian cancer with tumor-associated antigens CA 125, CA 15-3, and TAG 72.3. Obstet Gynecol. 1992;80(3 Pt 1):396-9. Exclude no mass. [pmid: 1495694].
Jacobs IJ, Rivera H, Oram DH, et al. Differential diagnosis of ovarian cancer with tumour markers CA 125, CA 15-3 and TAG 72.3. Br J Obstet Gynaecol. 1993;100(12):1120-4. Exclude Q4-partial dupl new data not relevant. [pmid: 8297846].
Jain KA. Prospective evaluation of adnexal masses with endovaginal gray-scale and duplex and color Doppler US: correlation with pathologic findings. Radiology. 1994;191(1):63-7. Exclude Q1-denom is masses. [pmid: 8134599].
Kadar N. Port-site recurrences following laparoscopic operations for gynaecological malignancies. Br J Obstet Gynaecol. 1997;104(11):1308-13. Exclude no mass. [pmid: 9386034].
Karlan BY. Screening for ovarian cancer: what are the optimal surrogate endpoints for clinical trials? J Cell Biochem 1995;23(227–32). Exclude review.
Karlan BY, Platt LD. The current status of ultrasound and color Doppler imaging in screening for ovarian cancer. Gynecol Oncol. 1994;55(3 Pt 2):S28-33. Exclude review. [pmid: 7835806].
Kerpsack JT, Finan MA. Thrombocytosis as a predictor of malignancy in women with a pelvic mass. J Reprod Med. 2000;45(11):929-32. Exclude Q3-wrong test. [pmid: 11127106].
Kim JH, Skates SJ, Uede T, et al. Osteopontin as a potential diagnostic biomarker for ovarian cancer. JAMA. 2002;287(13):1671-9. Exclude Q3-unable to construct 2×2. [pmid: 11926891].
Kinkel K, Hricak H, Lu Y, et al. US characterization of ovarian masses: a meta-analysis. Radiology. 2000;217(3):803-11. Exclude Q3-review. [pmid: 11110947].
Klaren HM, van't Veer LJ, van Leeuwen FE, et al. Potential for bias in studies on efficacy of prophylactic surgery for BRCA1 and BRCA2 mutation. J Natl Cancer Inst. 2003;95(13):941-7. Exclude review. [pmid: 12837830].
Kramer BS, Gohagan J, Prorok PC, et al. A National Cancer Institute sponsored screening trial for prostatic, lung, colorectal, and ovarian cancers. Cancer. 1993;71(2 Suppl):589-93. Exclude review. [pmid: 8420681].
Kruitwagen RF, Swinkels BM, Keyser KG, et al. Incidence and effect on survival of abdominal wall metastases at trocar or puncture sites following laparoscopy or paracentesis in women with ovarian cancer.[see comment]. Gynecol Oncol. 1996;60(2):233-7. Exclude Q6-sample size. [pmid: 8631544].
Kupesic S, Kurjak A. Contrast-enhanced, three-dimensional power Doppler sonography for differentiation of adnexal masses. Obstet Gynecol. 2000;96(3):452-8. Exclude Q3-sample size. [pmid: 10960641].
Kurjak A, Kupesic S, Anic T, et al. Three-dimensional ultrasound and power doppler improve the diagnosis of ovarian lesions. Gynecol Oncol. 2000;76(1):28-32. Exclude Q3-publ duplicate. [pmid: 10620437].
Kurjak A, Kupesic S, Babic MM, et al. Preoperative evaluation of cystic teratoma: what does color Doppler add?. J Clin Ultrasound. 1997;25(6):309-16. Exclude no mass. [pmid: 9142626].
Kurjak A, Predanic M. Ovarian cancer screening. Curr Opin Obstet Gynecol. 1994;6(1):67-74. Exclude review. [pmid: 8180353].
Lang F. Resident behaviors during observed pelvic examinations. Fam Med. 1990;22(2):153-5. Exclude no mass. [pmid: 2323497].
Larsen T, Torp-Pedersen ST, Ottesen M, et al. Abdominal ultrasound combined with histological and cytological fine needle biopsy of suspected ovarian tumors. Eur J Obstet Gynecol Reprod Biol. 1993;50(3):203-9. Exclude Q3-experimental or non-standard test. [pmid: 8262297].
Layfield LJ, Heaps JM, Berek JS. Fine-needle aspiration cytology accuracy with palpable gynecologic neoplasms. Gynecol Oncol. 1991;40(1):70-3. Exclude Q3-sample size. [pmid: 1989918].
Lee JH, Jeong YK, Park JK, et al. “Ovarian vascular pedicle” sign revealing organ of origin of a pelvic mass lesion on helical CT. AJR Am J Roentgenol. 2003;181(1):131-7. Exclude Q3-distguish malignant versus nonmalignant. [pmid: 12818843].
Lehner R, Wenzl R, Heinzl H, et al. Influence of delayed staging laparotomy after laparoscopic removal of ovarian masses later found malignant. Obstet Gynecol. 1998;92(6):967-71. Exclude no mass. [pmid: 9840559].
Lerner JP, Timor-Tritsch IE, Federman A, et al. Transvaginal ultrasonographic characterization of ovarian masses with an improved, weighted scoring system. Am J Obstet Gynecol. 1994;170(1 Pt 1):81-5. Exclude Q1-denom is masses. [pmid: 8296849].
Levine D, Feldstein VA, Babcook CJ, et al. Sonography of ovarian masses: poor sensitivity of resistive index for identifying malignant lesions. AJR Am J Roentgenol. 1994;162(6):1355-9. Exclude Q3-sample size. [pmid: 8191998].
Levine D, Gosink BB, Wolf SI, et al. Simple adnexal cysts: the natural history in postmenopausal women.[see comment]. Radiology. 1992;184(3):653-9. Exclude Q6-sample size. [pmid: 1509047].
Levy G, Levine P, Brennan J, et al. Color flow-directed Doppler studies of ovarian masses. Computer analysis. J Reprod Med. 1998;43(10):865-8. Exclude Other. [pmid: 9800668].
Lieberman G, Buscombe JR, Hilson AJ, et al. Preoperative diagnosis of ovarian carcinoma with a novel monoclonal antibody. Am J Obstet Gynecol. 2000;183(3):534-40. Exclude Q3-experimental or non-standard test. [pmid: 10992170].
Lieberman G, MacLean AB, Buscombe JR, et al. The clinical application of a dual head gamma camera with coincidence detection in 20 women with suspected ovarian cancer. BJOG. 2001;108(12):1229-36. Exclude no mass. [pmid: 11843384].
Liede A, Karlan B, Baldwin RL, et al. Cancer Incidence in a population of jewish women at risk of ovarian cancer. J Clin Oncol. 2002;20(6):1570-77. Exclude review. [pmid: 11896106].
Lin P, Falcone T, Tulandi T. Excision of ovarian dermoid cyst by laparoscopy and by laparotomy. Am J Obstet Gynecol. 1995;173(3 Pt 1):769-71. Exclude Q6-sample size. [pmid: 7573241].
Lynch HT, Albano WA, Lynch JF, et al. Surveillance and management of patients at high genetic risk for ovarian carcinoma. Obstet Gynecol. 1982;59(5):589-96. Exclude no mass. [pmid: 7070730].
MacDonald ND, Rosenthal AN, Jacobs IJ. Screening for ovarian cancer. Ann Acad Med Singapore. 1998;27(5):676-82. Exclude review. [pmid: 9919339].
Mackey SE, Creasman WT. Ovarian cancer screening. J Clin Oncol. 1995;13(3):783-93. Exclude review. [pmid: 7884436].
Maggino T, Gadducci A. Serum markers as prognostic factors in epithelial ovarian cancer: an overview. Eur J Gynaecol Oncol. 2000;21(1):64-9. Exclude review. [pmid: 10726623].
Mais V, Ajossa S, Piras B, et al. Treatment of nonendometriotic benign adnexal cysts: a randomized comparison of laparoscopy and laparotomy. Obstet Gynecol. 1995;86(5):770-4. Exclude Q6-sample size. [pmid: 7566846].
Mais V, Guerriero S, Ajossa S, et al. Transvaginal ultrasonography in the diagnosis of cystic teratoma. Obstet Gynecol. 1995;85(1):48-52. Exclude Q3-all premenopausal. [pmid: 7800323].
Markman M. Limitations to the use of the CA-125 antigen level in ovarian cancer. Curr Oncol Rep. 2003;5(4):263-4. Exclude review. [pmid: 12781066].
Masson V. Bodies of knowledge. Nurs Health Care Perspect. 1997;18(6):291. Exclude no mass. [pmid: 9407849].
McIntosh MW, Urban N. A parametric empirical Bayes method for cancer screening using longitudinal observations of a biomarker. Biostatistics. 2003;4(1):27-40. Exclude Q7-not descrip of sim model. [pmid: 12925328].
Mendilcioglu I, Zorlu CG, Trak B, et al. Laparoscopic management of adnexal masses. Safety and effectiveness. J Reprod Med. 2002;47(1):36-40. Exclude Q6-sample size. [pmid: 11838308].
Menon U, Jacobs IJ. Ovarian cancer screening in the general population. Curr Opin Obstet Gynecol. 2001;13(1):61-4. Exclude review. [pmid: 11176234].
Menon U, Talaat A, Rosenthal AN, et al. Performance of ultrasound as a second line test to serum CA125 in ovarian cancer screening. BJOG. 2000;107(2):165-9. Exclude Q4-wrong pt population. [pmid: 10688498].
Mensah LG. Gynecology in the generalist's office. Ethn Dis 2003;13(3 Suppl 3):S3-50-1.Exclude Q1-no histol. dx.
Merz E, Miric-Tesanic D, Bahlmann F, et al. Sonographic size of uterus and ovaries in pre- and postmenopausal women. Ultrasound Obstet Gynecol. 1996;7(1):38-42. Exclude no mass. [pmid: 8932630].
Mettler L, Semm K, Shive K. Endoscopic management of adnexal masses. J Soc Laparoendosc Surg. 1997;1(2):103-12. Exclude Q6-no M&M data.
Midgette AS, Stukel TA, Littenberg B. A meta-analytic method for summarizing diagnostic test performances: receiver-operating-characteristic-summary point estimates. Med Decis Making. 1993;13:253-7. Exclude review. [pmid: 8412556].
Milad MP, Cohen L. Preoperative ultrasound assessment of adnexal masses in premenopausal women. Int J Gynaecol Obstet. 1999;66(2):137-41. Exclude other all premenopausal. [pmid: 10468336].
Mills GB, Bast RC Jr, Srivastava S. Future for ovarian cancer screening: novel markers from emerging technologies of transcriptional profiling and proteomics. J Natl Cancer Inst. 2001;93(19):1437-9. Exclude review. [pmid: 11584052].
Misawa T, Asai M, Higashide K. How to decrease false-positive cases of ovarian cancer screening by transvaginal sonography. J Exp Clin Cancer Res. 1997;16(2):217-20. Exclude no mass. [pmid: 9261750].
Modesitt SC, Pavlik EJ, Ueland FR, et al. Risk of malignancy in unilocular ovarian cystic tumors less than 10 centimeters in diameter. Obstet Gynecol. 2003;102(3):594-9. Exclude Q3-no cancer outcome. [pmid: 12962948].
Morgan A. Adnexal mass evaluation in the emergency department. Emerg Med Clin North Am. 2001;19(3):799-816. Exclude review. [pmid: 11554288].
Moses LE, Shapiro D. Combining independent studies of a diagnostic test into a summary ROC curve: data-analytic approaches and some additional considerations. Stat Med. 1993;12:1293-316. Exclude review. [pmid: 8210827].
Muto MG, Cramer DW, Brown DL, et al. Screening for ovarian cancer: the preliminary experience of a familial ovarian cancer center. Gynecol Oncol. 1993;51(1):12-20. Exclude Q3-sample size. [pmid: 8244166].
Nagarsheth NP, Rahaman J, Cohen CJ, et al. The incidence of port-site metastases in gynecologic cancers. J Soc Laparoendosc Surg. 2004;8(2):133-9. Exclude no mass.
Nevin J, Denny L, Soeters R, et al. Ultrasonography of pelvic masses. Br J Obstet Gynaecol. 1998;105(2):137-9. Exclude review. [pmid: 9501775].
Nezhat C, Santolaya J, Nezhat FR. Comparison of transvaginal sonography and bimanual pelvic examination in patients with laparoscopically confirmed endometriosis. J Am Assoc Gynecol Laparosc. 1994;1(2):127-30. Exclude Q3-distguish malignant versus nonmalignant. [pmid: 9050474].
Nezhat F, Nezhat C, Welander CE, et al. Four ovarian cancers diagnosed during laparoscopic management of 1011 women with adnexal masses. Am J Obstet Gynecol. 1992;167(3):790-6. Exclude other. [pmid: 1388333].
Nichols M, Morgan E, Jensen JT. Comparing bimanual pelvic examination to ultrasound measurement for assessment of gestational age in the first trimester of pregnancy. J Reprod Med. 2002;47(10):825-8. Exclude Q1-no histol. dx. [pmid: 12418065].
O'Rourke J, Mahon SM. A comprehensive look at the early detection of ovarian cancer. Clin J Oncol Nurs. 2003;7(1):41-7. Exclude no mass. [pmid: 12629933].
Ong S, Duffy T, Murphy J. Transabdominal ultrasound and its correlation with clinical findings in gynaecology. Ir J Med Sci. 1996;165(4):268-70. Exclude Q3-unable to construct 2×2. [pmid: 8990652].
Onsrud M, Shabana A, Austgulen R, et al. Comparison between soluble tumor necrosis factor receptors and CA125 in peritoneal fluids as a marker for epithelial ovarian cancer. Gynecol Oncol. 1995;57(2):183-7. Exclude Q3-wrong test. [pmid: 7729731].
Opala T, Drews K, Rzymski P, et al. Evaluation of soluble intracellular adhesion molecule-1 (sICAM-1) in benign and malignant ovarian masses. Eur J Gynaecol Oncol. 2003;24(34):255-7. Exclude Q3-experimental or non-standard test. [pmid: 12807235].
Opala T, Rzymski P, Wilczak M, et al. Evaluation of soluble tumour necrosis factor alpha receptors p55 and p75 in ovarian cancer patients. Eur J Gynaecol Oncol. 2005;26(1):43-6. Exclude Q3-wrong test. [pmid: 15754999].
Oram DH, Jacobs IJ, Brady JL, et al. Early diagnosis of ovarian cancer. Br J Hosp Med 1990;44(5):320, 322, 324. Exclude Q3-review.
Paley PJ. Screening for the major malignancies affecting women: current guidelines. Am J Obstet Gynecol. 2001;184(5):1021-30. Exclude review. [pmid: 11303215].
Papasakelariou C, Saunders D, De La Rosa A. Comparative study of laparoscopic oophorectomy. J Am Assoc Gynecol Laparosc. 1995;2(4):407-10. Exclude Q6-no M&M data. [pmid: 9050593].
Pardo J, Kaplan B, Yitzhak M, et al. Ultrasonographic evaluation of hysterectomized patients with and without concomitant adnexectomy?. Clin Exp Obstet Gynecol. 1998;25(4):133-4. Exclude no mass. [pmid: 9987570].
Parker WH. Management of adnexal masses by operative laparoscopy. Selection criteria. J Reprod Med. 1992;37(7):603-6. Exclude no mass. [pmid: 1387908].
Parker WH, Berek JS. Management of selected cystic adnexal masses in postmenopausal women by operative laparoscopy: a pilot study. Am J Obstet Gynecol. 1990;163(5 Pt 1):1574-7. Exclude Q2-no physical exam. [pmid: 2146879].
Patel MD, Feldstein VA, Chen DC, et al. Endometriomas: diagnostic performance of US [erratum appears in Radiology 1999 Dec;213(3):930]. Radiology. 1999;210(3):739-45. Exclude Q3-distguish malignant versus nonmalignant. [pmid: 10207476].
Patel MD, Feldstein VA, Lipson SD, et al. Cystic teratomas of the ovary: diagnostic value of sonography. AJR Am J Roentgenol. 1998;171(4):1061-5. Exclude Q3-distguish malignant versus nonmalignant. [pmid: 9762997].
Patsner B, Mann WJ, Chalas E. Predictive value of CA 125 for ovarian carcinoma in patients presenting with pelvic masses. Obstet Gynecol. 1988;71(6 Pt 1):949-50. Exclude review. [pmid: 3163416].
Pauler DK, Menon U, McIntosh M, et al. Factors influencing serum CA125II levels in healthy postmenopausal women. Cancer Epidemiol Biomarkers Prev. 2001;10(5):489-93. Exclude Q1-no histol. dx. [pmid: 11352859].
Pearson VA. Screening for ovarian cancer: a review. Public Health. 1994;108(5):367-82. Exclude review. [pmid: 7972677].
Petricoin EF, Ardekani AM, Hitt BA, et al. Use of proteomic patterns in serum to identify ovarian cancer. Lancet. 2002;359(9306):572-7. Exclude no mass. [pmid: 11867112].
Predanic M, Vlahos N, Pennisi JA, et al. Color and pulsed Doppler sonography, gray-scale imaging, and serum CA 125 in the assessment of adnexal disease. Obstet Gynecol. 1996;88(2):283-8. Exclude Q1-sample size. [pmid: 8692517].
Prefontaine M, Kroft T, Monck M, et al. Evaluation of a simple line width test involving magnetic resonance spectroscopy of plasma in carcinoma of the ovary. Cancer. 1991;67(2):406-11. Exclude Q3-wrong test. [pmid: 1985735].
Pugh CM, Youngblood P. Development and validation of assessment measures for a newly developed physical examination simulator. J Am Med Inform Assoc. 2002;9(5):448-60. Exclude review. [pmid: 12223497]. [pmcid: 346632].
Qureshi IA, Ullah H, Akram MH, et al. Transvaginal versus transabdominal sonography in the evaluation of pelvic pathology. J Coll Physicians Surg Pak. 2004;14(7):390-3. Exclude Q3-no histol. dx. [pmid: 15279738].
Ramirez PT, Frumovitz M, Wolf JK, et al. Laparoscopic port-site metastases in patients with gynecological malignancies. [Review...] [58 refs]. Int J Gynecol Cancer. 2004;14(6):1070-7. Exclude review. [pmid: 15571612].
Rifkin JI, Shapiro H, Regensteiner JG, et al. Why do some women refuse to allow male residents to perform pelvic exams?. Acad Med. 2002;77(10):1034-8. Exclude no mass. [pmid: 12377683].
Rollins G. Developments in cervical and ovarian cancer screening: implications for current practice. Ann Intern Med. 2000;133(12):1021-4. Exclude review. [pmid: 11119415].
Roman LD, Muderspach LI, Stein SM, et al. Pelvic examination, tumor marker level, and gray-scale and Doppler sonography in the prediction of pelvic cancer. Obstet Gynecol. 1997;89(4):493-500. Exclude Q7-not descrip of sim model/Exclude Q5-wrong pt population. [pmid: 9083301].
Rosenthal AN, Jacobs IJ. The role of CA 125 in screening for ovarian cancer. Int J Biol Markers. 1998;13(4):216-20. Exclude review. [pmid: 10228904].
Sari R, Buyukberber S, Sevinc A, et al. The effects of abdominal and bimanual pelvic examination and transvaginal ultrasonography on serum CA-125 levels. Clin Exp Obstet Gynecol. 2000;27(1):69-71. Exclude review. [pmid: 10758808].
Sassone AM, Timor-Tritsch IE, Artner A, et al. Transvaginal sonographic characterization of ovarian disease: evaluation of a new scoring system to predict ovarian malignancy. Obstet Gynecol. 1991;78(1):70-6. Exclude Q1-denom is masses. [pmid: 2047071].
Schwartz LB, Seifer DB. Diagnostic imaging of adnexal masses. A review. J Reprod Med. 1992;37(1):63-71. Exclude review. [pmid: 1548639].
Seewaldt VL, Cain JM, Greer BE, et al. Reviving the pelvic examination for evaluating the status of ovarian carcinoma. J Clin Oncol. 1995;13(3):799. Exclude Q1-no histol. dx. [pmid: 7884443].
Sengoku K, Satoh T, Saitoh S, et al. Evaluation of transvaginal color Doppler sonography, transvaginal sonography and CA 125 for prediction of ovarian malignancy. Int J Gynaecol Obstet. 1994;46(1):39-43. Exclude Q4-sample size. [pmid: 7805982].
Shaharabany Y, Akselrod S, Tepper R. A sensitive new indicator for diagnostics of ovarian malignancy, based on the Doppler velocity spectrum. Ultrasound Med Biol. 2004;30(3):295-302. Exclude Q3-unable to construct 2×2. [pmid: 15063511].
Shalev E, Eliyahu S, Peleg D, et al. Laparoscopic management of adnexal cystic masses in postmenopausal women. Obstet Gynecol. 1994;83(4):594-6. Exclude Q3-not complete series. [pmid: 8134071].
Shapiro I, Friedman Z, Lysyansky P, et al. The instantaneous measurement of multiple Doppler spectra in the investigation of ovarian masses. Ultrasound Obstet Gynecol. 1998;11(5):353-6. Exclude Q3-no histol. dx. [pmid: 9644776].
Shen-Gunther J, Mannel RS. Ascites as a predictor of ovarian malignancy. Gynecol Oncol. 2002;87(1):77-83. Exclude Q3-unable to construct 2×2/ Exclude Q2-only 1 patient had ascites. [pmid: 12468346].
Sheppard R, Fry A, Rush R, et al. Women at risk of ovarian cancer: attitudes towards and expectations of the familial ovarian cancer clinic. Fam Cancer. 2001;1(1):31-7. Exclude no mass. [pmid: 14574013].
SOGC/GOC/SCC Policy and Practice Guideline Committee. Guidelines for the Laparoscopic Management of the adnexal mass: a policy statement. SOGC Clinical Practice Guidelines 1998;(76). Exclude review.
Soriano D, Yefet Y, Seidman DS, et al. Laparoscopy versus laparotomy in the management of adnexal masses during pregnancy. Fertil Steril. 1999;71(5):955-60. Exclude Other All Premenopausal. [pmid: 10231065].
Sparks JM, Varner RE. Ovarian cancer screening. Obstet Gynecol. 1991;77(5):787-92. Exclude review. [pmid: 2014097].
Stein SM, Laifer-Narin S, Johnson MB, et al. Differentiation of benign and malignant adnexal masses: relative value of gray-scale, color Doppler, and spectral Doppler sonography. AJR Am J Roentgenol. 1995;164(2):381-6. Exclude Q1-denom is masses. [pmid: 7839975].
Tailor A, Jurkovic D, Bourne TH, et al. Sonographic prediction of malignancy in adnexal masses using multivariate logistic regression analysis. Ultrasound Obstet Gynecol. 1997;10(1):41-7. Exclude Q4-sample size. [pmid: 9263422].
Tailor A, Jurkovic D, Bourne TH, et al. Sonographic prediction of malignancy in adnexal masses using an artificial neural network. Br J Obstet Gynaecol. 1999;106(1):21-30. Exclude Q3-unable to construct 2×2. [pmid: 10426255].
Tailor A, Jurkovic D, Bourne TH, et al. A comparison of intratumoural indices of blood flow velocity and impedance for the diagnosis of ovarian cancer. Ultrasound Med Biol. 1996;22(7):837-43. Exclude Q3-sample size. [pmid: 8923703].
Tangjitgamol S, Jesadapatrakul S, Manusirivithaya S, et al. Accuracy of frozen section in diagnosis of ovarian mass. Int J Gynecol Cancer. 2004;14(2):212-9. Exclude Q3-wrong test. [pmid: 15086718].
Tekay A, Jouppila P. Controversies in assessment of ovarian tumors with transvaginal color Doppler ultrasound. Acta Obstet Gynecol Scand. 1996;75(4):316-29. Exclude Q3-review. [pmid: 8638449].
Tempfer C, Hefler L, Heinzl H, et al. CYFRA 21-1 serum levels in women with adnexal masses and inflammatory diseases. Br J Cancer. 1998;78(8):1108-12. Exclude Q3-experimental or non-standard test. [pmid: 9792159].
Teneriello MG, Park RC. Early detection of ovarian cancer. CA Cancer J Clin. 1995;45(2):71-87. Exclude review. [pmid: 7889392].
Tepper R, Keselbrener L, Manor M, et al. Decay constant of Doppler flow waveform as a possible indicator of ovarian malignancy. Ultrasound Med Biol. 1997;23(8):1171-7. Exclude Q3-unable to construct 2×2. [pmid: 9372565].
Thorvinger B. Diagnostic and interventional radiology in gynecologic neoplasms. Acta Radiol Suppl. 1992;378(Pt 3):93-108. Exclude Q1-no histol. dx. [pmid: 1323200].
Timmerman D, Bourne TH, Tailor A, et al. A comparison of methods for preoperative discrimination between malignant and benign adnexal masses: the development of a new logistic regression model. Am J Obstet Gynecol. 1999;181(1):57-65. Exclude Q3-unable to construct 2×2. [pmid: 10411796].
Timmerman D, Schwarzler P, Collins WP, et al. Subjective assessment of adnexal masses with the use of ultrasonography: an analysis of interobserver variability and experience. Ultrasound Obstet Gynecol. 1999;13(1):11-6. Exclude Q3-unable to construct 2×2. [pmid: 10201081].
Timor-Tritsch IE. Is office use of vaginal ultrasonography feasible?. Am J Obstet Gynecol. 1990;162(4):983-5. Exclude Q1-no histol. dx. [pmid: 2183621].
Togashi K, Nishimura K, Kimura I, et al. Endometrial cysts: diagnosis with MR imaging. Radiology. 1991;180(1):73-8. Exclude Q3-no cancer outcome. [pmid: 2052726].
Tuxen MK, Soletormos G, Dombernowsky P. Tumor markers in the management of patients with ovarian cancer. Cancer Treat Rev. 1995;21(3):215-45. Exclude Q3-review. [pmid: 7656266].
U.S. Preventive Services Task Force. Screening for ovarian cancer: recommendation statement. Ann Fam Med. 2004;2(3):260-2. Exclude Q1-no histol. dx. [pmid: 15209204]. [pmcid: 1466669].
Ueland F, DePriest P, DeSimone C, et al. The accuracy and examination under anesthesia and transvaginal sonography in evaluating ovarian size. Gynecol Oncol 2005 (in Press) Exclude no mass.
Urban N. Screening for ovarian cancer. We now need a definitive randomised trial. BMJ. 1999;319(7221):1317-8. Exclude Q1-no histol. dx. [pmid: 10567117]. [pmcid: 1117062].
Urban N, McIntosh MW, Andersen M, et al. Ovarian cancer screening. Hematol Oncol Clin North Am. 2003;17(4):985-1005. Exclude review.
Usubutun A, Altinok G, Kucukali T. The value of intraoperative consultation (frozen section) in the diagnosis of ovarian neoplasms. Acta Obstet Gynecol Scand. 1998;77(10):1013-6. Exclude Q3-wrong test. [pmid: 9849847].
Vaidya AP, Curtin JP. The follow-up of ovarian cancer. Semin Oncol. 2003;30(3):401-12. Exclude Q1-no histol. dx. [pmid: 12870142].
Valentin L. Prospective cross-validation of Doppler ultrasound examination and gray-scale ultrasound imaging for discrimination of benign and malignant pelvic masses. Ultrasound Obstet Gynecol. 1999;14(4):273-83. Exclude Q3-publ duplicate. [pmid: 10586480].
Valentin L, Sladkevicius P, Marsal K. Limited contribution of Doppler velocimetry to the differential diagnosis of extrauterine pelvic tumors. Obstet Gynecol. 1994;83(3):425-33. Exclude Q3-unable to construct 2×2. [pmid: 8127537].
van Dam PA, DeCloedt J, Tjalma WA, et al. Trocar implantation metastasis after laparoscopy in patients with advanced ovarian cancer: can the risk be reduced?. Am J Obstet Gynecol. 1999;181(3):536-41. Exclude no mass. [pmid: 10486460].
van der Burg ME, Lammes FB, Verweij J. The role of CA 125 and conventional examinations in diagnosing progressive carcinoma of the ovary. Surg Gynecol Obstet. 1993;176(4):310-4. Exclude Q3-wrong test. [pmid: 8460404].
van Nagell JR Jr, DePriest PD, Gallion HH, et al. Ovarian cancer screening. Cancer. 1993;71(4 Suppl):1523-8. Exclude review. [pmid: 8431889].
van Nagell JR Jr, DePriest PD, Reedy MB, et al. The efficacy of transvaginal sonographic screening in asymptomatic women at risk for ovarian cancer. Gynecol Oncol. 2000;77(3):350-6. Exclude Q5-wrong pt population. [pmid: 10831341].
van Nagell JR Jr, Higgins RV, Donaldson ES, et al. Transvaginal sonography as a screening method for ovarian cancer. A report of the first 1000 cases screened. Cancer. 1990;65(3):573-7. Exclude Q1-pop is subset of larger study (#2730). [pmid: 2404560].
van Nagell JR Jr, Ueland FR. Ultrasound evaluation of pelvic masses: predictors of malignancy for the general gynecologist. Curr Opin Obstet Gynecol. 1999;11(1):45-9. Exclude review. [pmid: 10047963].
Varpula M. Magnetic resonance imaging of female pelvic masses and local recurrent tumors at an ultra low (0.02 T) magnetic field: correlation with computed tomography. Magn Reson Imaging. 1993;11(1):35-46. Exclude Q3-sample size. [pmid: 8423720].
Varras M. Benefits and limitations of ultrasonographic evaluation of uterine adnexal lesions in early detection of ovarian cancer. Clin Exp Obstet Gynecol. 2004;31(2):85-98. Exclude review. [pmid: 15266758].
Vogl FD, Frey M, Kreienberg R, et al. Autoimmunity against p53 predicts invasive cancer with poor survival in patients with an ovarian mass. Br J Cancer. 2000;83(10):1338-43. Exclude Q3-sample size. [pmid: 11044359].
von Schlippe M, Rustin GJ. Circulating tumour markers in ovarian tumours. Forum. 2000;10(4):383-92. Exclude review. [pmid: 11535987].
Voss SC, Lacey CG, Pupkin M, et al. Ultrasound and the pelvic mass. J Reprod Med. 1983;28(12):833-7. Exclude Q3-no verification test negative/ Exclude Q2-unable to construct 2×2. [pmid: 6229631].
Wakahara F, Kikkawa F, Nawa A, et al. Diagnostic efficacy of tumor markers, sonography, and intraoperative frozen section for ovarian tumors. Gynecol Obstet Invest. 2001;52(3):147-52. Exclude Q4-unable to construct 2×2. [pmid: 11598354].
Wardle FJ, Collins W, Pern, et al. Psychological impact of screening for familial ovarian cancer. J Natl Cancer Inst. 1993;85(8):653-7. Exclude review. [pmid: 8468723].
Weerakiet S, Wongkularb A, Rochanawutanon M, et al. Transvaginal ultrasonography combined with pelvic examination in the diagnosis of ovarian endometrioma. J Med Assoc Thai. 2000;83(5):523-8. Exclude Q3-no cancer outcome. [pmid: 10863898].
Weiner Z, Beck D, Brandes JM. Transvaginal sonography, color flow imaging, computed tomographic scanning, and CA 125 as a routine follow-up examination in women with pelvic tumor: detection of recurrent disease. J Ultrasound Med. 1994;13(1):37-41. Exclude no mass. [pmid: 7636952].
Westhoff C, Levin B, Ladd G, et al. Sources of variability in normal CA 125 levels. Cancer Epidemiol Biomarkers Prev. 1992;1(5):357-9. Exclude review. [pmid: 1305467].
Yawn BP, Wollan PC. Ovarian cancer: the neglected diagnosis. Mayo Clinic Proceedings. 2004;79(10):1277-82. Exclude review. [pmid: 15473410].
Zhang Z, Bast RC Jr, Yu Y, et al. Three biomarkers identified from serum proteomic analysis for the detection of early stage ovarian cancer.[see comment]. Cancer Res. 2004;64(16):5882-90. Exclude Q3-experimental or non-standard test. [pmid: 15313933].
Zurawski VR Jr, Knapp RC, Einhorn N, et al. An initial analysis of preoperative serum CA 125 levels in patients with early stage ovarian carcinoma. Gynecol Oncol. 1988;30(1):7-14. Exclude Q3-distguish malignant versus nonmalignant. [pmid: 2452773].
Zygmunt A, Markowska J, Fischer N. Significance of tissue polypeptide specific antigen (TPS) in diagnosis and monitoring of treatment in ovarian cancer. Eur J Gynaecol Oncol. 1998;19(5):484-6. Exclude review. [pmid: 9863919].