# Appendix A: Exact Search Strings

Search Strategy 1: pelvic exam performance

(developed and run by McCrory and Myers on September 10, 2004)

Database: Ovid MEDLINE(R) <1966 to September Week 1 2004>

Search Strategy: ————————————————————————————————————————

1 pelvic exam.mp.(53)
2 (bimanual adj pelvic).mp. [mp=title, original title, abstract, name of substance, mesh subject heading] (25)
3 (physical exam and pelvis).mp.(7)
4 “diagnostic techniques, obstetrical and gynecological”/ or culdoscopy/ or laparoscopy/ or physical examination/ (45383)
5 physical examination/ (18265)
6 Ovarian Cysts/ or Ovarian Neoplasms/ or Genital Neoplasms, Female/ or Adnexal Diseases/ or adnexal mass.mp. (48599)
7 exp Ovarian Cysts/ or exp Ovarian Neoplasms/ or Genital Neoplasms, Female/ or Adnexal Diseases/ or adnexal mass.mp. (53879)
8 exp fallopian tube diseases/ (4449)
9 5 and (7 or 8) (124)
10 (or/1–3) and (or/7–8) (18)
11 9 and 10 (5)
12 “diagnostic techniques, obstetrical and gynecological”/ and (or/7–8) (8)
13 culdoscopy/ and (or/7–8) (52)
14 or/1–3,9–10 (204)
15 limit 14 to (human and english language and yr=1980 - 2004) (147)
16 from 15 keep 1–147 (147)

***************************

Search Strategy 2: test performance

Developed and run by McCrory on September 28, 2004

Database: Ovid MEDLINE(R) <1966 to September Week 3 2004>

Search Strategy: ————————————————————————————————————————

1 (vagin$ adj ultraso$).mp. [mp=title, original title, abstract, name of substance, mesh subject heading] (1391)
2 (adnex$ adj2 mas$).mp. (873)
3 (pelvi$ adj mas$).mp. (1537)
4 (ovar$ adj mas$).mp. (1479)
5 or/2–4 (3696)
6 “sensitivity and specificity”/ (121128)
7 6 and 1 (132)
8 6 and 5 (316)
9 7 or 8 (431)
10 limit 9 to (human and english language) (387)
11 from 10 keep 1–387 (387)
12 (ovar$ adj tumo$).mp. (11435)
13 12 and 6 (405)
14 ROC Curve/ (7282)
15 13 and 14 (27)
16 from 15 keep 4,7,9,15,19–20,22–23,27 (9)
17 from 15 keep 22–23,27 (3)
18 16 not 11 (4)
19 11 or 18 (391)
20 limit 19 to yr=1980 - 2004 (391)
21 from 20 keep 1–391 (391)

***************************

Search Strategy 3: predictive models

(strategy developed and run by McCrory on September 29, 2004)

Database: Ovid MEDLINE(R) <1966 to September Week 3 2004>

Search Strategy: ————————————————————————————————————————

1 (vagin$ adj ultraso$).mp. [mp=title, original title, abstract, name of substance, mesh subject heading] (1391)
2 (adnex$ adj2 mas$).mp. (873)
3 (pelvi$ adj mas$).mp. (1537)
4 (ovar$ adj mas$).mp. (1479)
5 or/2–4 (3696)
6 “sensitivity and specificity”/ (121128)
7 6 and 1 (132)
8 6 and 5 (316)
9 7 or 8 (431)
10 limit 9 to (human and english language) (387)
11 predictive value of tests/ (56850)
12 Risk Assessment/ (47548)
13 roc curve/ (7282)
14 “Multivariate Analysis”/ (31714)
15 or/11–14 (136223)
16 15 and 5 (260)
17 16 not 9 (142)
18 limit 17 to (human and english language) (131)
19 from 18 keep 1–131 (131)

***************************