# Appendixes

Appendix A: Exact Search Strings

Appendix B: List of Excluded Studies

Appendix C: Sample Data Abstraction Forms

Appendix D: Evidence Tables

Appendix E: Peer Reviewers