# List of Acronyms and Abbreviations

AHCPR: Agency for Health Care Policy and Research

AHRQ: Agency for Healthcare Research and Quality

AIDS: Acquired immune deficiency syndrome

ANOVA: Analysis of variance

AV: Arteriovenous

BFR: Blood flow rate

BMI: Body-mass index

BP: Blood pressure

BUN: Blood urea nitrogen

Ca: Calcium

CABG: Coronary artery bypass graft

CAD/CHD: Coronary artery disease/coronary heart disease

CAPD: Continuous ambulatory peritoneal dialysis

CCPD: Continuous cycling peritoneal dialysis

COPD: Chronic obstructive pulmonary disease

CRD: Chronic renal disease

CRF: Chronic renal failure

CVA: Cerebrovascular accident

DBP: Diastolic blood pressure

DISM: Disability Insurance State Manual

DMMS: Dialysis Morbidity and Mortality Study

EKG: Electrocardiograph

EPO: Erythropoietin

ESRD: End-stage renal disease

FN: False negative

FP: False positive

FT: Full time

GFR: Glomerular filtration rate

HCFA: Health Care Financing Administration

HD: Hemodialysis

HDL: High density lipoprotein

HIV: Human immunodeficiency virus

HMO: Health maintenance organization

IPD: Intermittent peritoneal dialysis

IQ: Intelligence quotient

KDQOLTM: Kidney Disease Quality of Life

LDL: Low density lipoprotein

MI: Myocardial infarction

NIDDK: National Institute of Diabetes and Digestive and Kidney Diseases

PAIS: Psychological Adjustment to Illness Scale

PD: Peritoneal dialysis

PL: Public Law

POMS: Profile of Mood States

PT: Part time

PTCA: Percutaneous transluminal coronary angioplasty

PTFE: Polytetrafluoroethylene

PTH: Parathyroid hormone

PVD: Peripheral vascular disease

ROC: Receiver operating characteristic

SBP: Systolic blood pressure

SGA: Substantial gainful activity

SIP: Sickness impact profile

SSA: Social Security Administration

SSDI: Social Security Disability Insurance

SSI: Supplemental Security Income

TIA: Transient ischemic attack

TN: True negative

TP: True positive

UUN: Urine urea nitrogen

USRDS: United States Renal Data System

WAIS: Wechsler Adult Intelligence Scale