# Evidence Tables

Evidence Table 1. Evidence regarding predictors of disability of ESRD patients as defined by employment

Study | Study type | Patient selection | Number of patients | Avg age | % Female | Months since dialysis onset | Patient characteristics | Outcome variables | Significant predictors | Non-significant predictors | Comments
(Curtin, Oberley, Sacksteder et al, 1996.) | Questionnaire | Random sampling of facilities All patients aged 18 to 62 | 359 | 43 | 49 | 45 | Demographics Treatment Health measures (MOS-20; Karnofsky) Attitudes and perceptions | Vocational status | Education MOS-20 Predialysis employment status Perceptions on limitations Perceptions of others' expectations of ability to work | Mode of dialysis Location of dialysis center | Multiple logistic regression to control for covariates
(Holley and Nespor, 1994) | Survey and medical chart review (?) | NR | 77 | NR (20-55) | 53% | 24 (median) | Many | Vocational status | LOT Education | Sex Age Race Disease Kt/V Hct Albumin | No attempt made to control for covariates
(Rasgon, Schwankovsky, James-Rogers et al, 1993) | Interview | Hemodialysis, previously working, under age 65 | 107 | Circa. 50 | 36.5% | 49.2 | Karnofsky Sex Ethnicity Marital status Age Diabetes Education | Vocational status | Age Diabetes Karnofsky QoL Self-esteem | Sex Ethnicity Marital status Education | Chi-square analyses
(Kutner, Brogan, and Fielding, 1991) | Interview | Two-stage cluster sample -- geographical location of dialysis facility and facility size Age 18 to 59 | 283 | 44.7 | 46.9% | NR | Demographic Dialysis treatment variables Health status; Employment variables | Reported ability to work among nonemployed patients who had worked previously | Age Education Race (blacks more likely) Presence of comorbid conditions Total number of physical skill difficulties Perceived health status MD rating of ability to work Work interest Recency of past work | Sex Marital status LOT Work enjoyment Former occupational level | Only 15% of unemployed patients said that someone talked to them about getting a job. Univariate analyses. No attempt made to control covariates. One-third of unemployed patients said they are able to work, most part time.
(Julius, Kneisley, Carpentier-Alting et al, 1989) | Interview | Michigan dialysis patients aged >18 | 214 | NR | 45.3% | NR | Demographic Treatment Diagnosis Duration of disease | Vocational status | Sex Education Treatment | Race Age Marital status Primary diagnosis Duration of disease | Logistic regression to control for covariates Employment refers to employment outside the home Patients with diabetes and patients over 65 excluded.
(Friedman and Rogers, 1988) | Interview | One half working, one half not | 263 | NR | NR | NR | Demographics Occupation Education Karnofsky Activity Scale | Vocational status | Age Education Occupation level Karnofsky score | Sex Race Marital status Employment level of spouse | No details on statistical methods
(Wolcott, Nissenson, and Landsverk, 1988) | Chart review; interview | Matched pairs (HD and PD) | 34 | 50 | 35.3% | 59.9 | Cognitive scores | Vocational status | 7 out of 11 cognitive tests | 4 out of 11 cognitive tests | Cause and effect unclear -- does greater cognitive ability lead to employment, or does employment maintain greater cognitive ability?
(Wolcott and Nissenson, 1988) | Chart review, interview | Matched-pairs | 66 | 47.4 | 30.3% | 58.5 | QoL | Vocational status | Age Education Karnofsky score (higher) Anxiety (lower) Fatigue (lower) Anger (lower) Social support satisfaction (higher) | Laboratory and clinical measures QoL scale Self-esteem POMS-Depression, Confusion Illness adjustment Active Sedentary | Cause and effect unclear in this study
(Ferrans and Powers, 1985) | Medical chart review; questionnaire | HD patients aged 21-59 | 40 | 44.5 | 22.5% | 38 | Laboratory measures Job-related variables Life satisfaction Illness-related variables | Vocational status | Importance of returning to work Change in life goals Being refused a job because of health | Biophysiological measures Life satisfaction Job satisfaction prior to dialysis | All subjects had been employed prior to dialysis
(Stegman, Pohren, Ducan et al, 1985) | Cross-sectional survey | Stratified proportional random sample, age < 65 | 27 | NR (<65) | 70.4 | NR | Total years worked Age Sex Education Comorbidities | Vocational status | Age Number of years in workforce Presence of peripheral neuropathy | NR | Significance levels not given; patients reported that scheduling conflicts were the single largest barrier to employment. None reported that being too close to retirement, fear of losing disability income, or prejudice by employers were reasons not to work.
(Kutner and Cardenas, 1982) | Interview | Long-term dialysis pts Recruited | 137 | 43 | 39 | 27 (med) | Diabetes Sex Race Education Age | Vocational status | Diabetes Education Age > 55 | NR | Significance levels not given.
(Calsyn, Sherrard, Hyerstay et al, 1981) | Survey and medical chart review (?) | Trained for home hemodialysis | 107 | ~42 | 2.9 | NR | Demographics Comorbidities Intelligence (WAIS) | Vocational status: full time (>30 hrs), part time, <10 hrs per week | Education I.Q. | WAIS organicity Comorbidities Age | Statistical methods not described -- appear to be ANOVA. No adjustment for covariates.
(Gutman, Stead, and Robinson, 1981) | Survey | All patients at 18 dialysis centers | 2481 | NR | 45 | NR | Sex Race Education Diabetes Karnofsky Scale physical activity score | Vocational status | Diabetes Race (among men, education not adjusted for) Education (patients with diabetes excluded for this analysis) | NR | No analyses performed that attempted to control for covariates - chi-square.
(De-Nour and Czaczkes, 1975) | Longitudinal, fixed interval interview | Males on HD | 50 | NR (14-65) | 0 | NA - longitudinal study | Predialysis functioning Predialysis work satisfaction Sick role Dependency needs | Vocational status | Working pre-dialysis Liking job Attitude about sick role Dependency needs | Age Education | Researchers found that most patients reached their final level of rehab by 6 months on dialysis; low socioeconomic status.

Note: All studies were case series design.

NR = Not reported

NA = Not applicable

LOT = Length of treatment

HD = Hemodialysis

KT/V is an indication of dialysis efficiency. It denotes permeability of the hemodialyzer membrane to urea, multiplied by time of treatment and normalized to the volume of distribution of urea.

Evidence Table 2 Rejected studies with some relevant data

Study | Evidence | Reason for exclusion
(Merkus, Jager, Dekker et al, 1997) | Employed patients scored higher on 7 of 8 SF-36 subscales | Cause versus effect not clear Conducted in the Netherlands, which may result in different scores than U.S.
(Sesso and Yoshihiro, 1997) | Adult ESRD: employment status and ability to work compared in early and late diagnosis patients. No differences | Early and late diagnosis are probably not factors that SSA would have any control over.
(Kimmel, Peterson, Weihs et al, 1995) | PAIS vocational subscale was not significantly correlated with any other QoL measure | PAIS vocational subscale is not solely vocational status.
(Ifudu, Paul, Mayers et al, 1994) | Supports assumption that some dialysis patients work | Employment is not the main outcome. Not limited to working-aged patients.
(Kurtin, Landgraf, and Abetz, 1994) | Pediatric ESRD: relationships among self-reported health status, activity, expected grade in school | The necessary correlations or predictors are not supplied in the article -- expected grade level is only correlated with family activity, not relevant to this study
(McMahon and Dawborn, 1992) | Adult ESRD: correlation between hemoglobin and SIP work score | SIP work scale is not specific enough -- incorporates many different aspects of work.
(Simmons and Abress, 1990) | Adult ESRD: employment by treatment method | USRDS data more complete.
(Spinowitz, 1990) | Adult ESRD: self-reported ability to work | Researchers did not report relationship of employment to any other variable. Treatment efficacy study (EPO)
(Bremer, McCauley, Wrona et al, 1989) | Employment by treatment modality | No predictor variables. USRDS data more complete.
(Henning, Tomlinson, Rigden et al, 1988) | Adult ESRD: rate of employment | No predictor variables. United Kingdom USRDS data more complete.
(Wolcott, Wellisch, Marsh et al, 1988) | Adult ESRD: neuropsychological measures of employed versus unemployed | Number of subjects too small (8 in employed group).
(Crittenden, Holliday, Piel et al, 1985) | Children with CRD and ESRD do maintain intellectual development when treated with dialysis; children who were diagnosed with CRF early were more intellectually disabled than those diagnosed later | Descriptive statistics and graphs only. No significance levels reported.
(Bullock, Amer, Simpson et al, 1984) | Adult ESRD: relation between employment and exercise tolerance | Only provides descriptive statistics and graphs. United Kingdom
(Rozenbaum, Chaimovitz, and Bearman, 1984) | Adult ESRD: education correlated with employment | Israel
(Johnson, McCauley, and Copley, 1982) | Adult ESRD: Employment prior to disease and currently. | Researchers did not report relationship of employment to any other variable. Cannot compare pre-dialysis and current employment because current includes housework and pre- does not.
(Kutner and Cardenas, 1981) | Adult ESRD: employment statistics by grade | USRDS published data are more complete. Descriptive statistics and anecdotal approach.
(Tews, Schreiber, Huber et al, 1980) | Adult ESRD: employment status affected by pre-dialysis position, education, and local labor markets | Germany Type of dialysis not mentioned.
(Wadgymar, Wu, Fenton et al, 1980) | Adult ESRD: employment rates of CAPD patients | USRDS data more complete and more recent.
(Chantler, Broyer, Donckerwolcke et al, 1981) | Pediatric ESRD: long-term employment rates | Not correlated with any other variable. Dutch Future employment rates are not a disability criterion for pediatric patients in the United States.