# Bibliography

Completeness and reliability of USRDS data: comparisons with the Michigan Kidney Registry. Am J Kidney Dis. 1992 Nov;20(5 Suppl 2):84-8.
Bremer BA, McCauley CR, Wrona RM, et al. Quality of life in end-stage renal disease: a reexamination. Am J Kidney Dis. 1989 Mar;13(3):200-9.
Bullock RE, Amer HA, Simpson I, et al. Cardiac abnormalities and exercise tolerance in patients receiving renal replacement therapy. Br Med J (Clin Res Ed). 1984 Dec 1;289(6457):1479-84.
Calsyn DA, Sherrard DJ, Hyerstay BJ, et al. Vocational adjustment and survival on chronic hemodialysis. Arch Phys Med Rehabil. 1981 Oct;62(10):483-7.
Chantler C, Broyer M, Donckerwolcke RA, et al. Growth and rehabilitation of long-term survivors of treatment for end- stage renal failure in childhood. Proc Eur Dial Transplant Assoc. 1981;18:329-42. [pmid: 7329977].
Cook TD, Campbell DT. Quasi-experimentation: design and analysis issues for field settings. Boston: Houghton Mifflin Company; 1979. 405 p.
Crittenden MR, Holliday MA, Piel CF, et al. Intellectual development of children with renal insufficiency and end stage disease. Int J Pediatr Nephrol. 1985 Oct-Dec;6(4):275-80.
Curtin RB, Oberley ET, Sacksteder P, et al. Differences between employed and nonemployed dialysis patients. Am J Kidney Dis. 1996 Apr;27(4):533-40.
De-Nour AK, Czaczkes JW. Personality factors influencing vocational rehabilitation. Arch Gen Psychiatry. 1975 May;32(5):573-7.
Dowdney L, Skuse D, Morris K, et al. Short normal children and environmental disadvantage: a longitudinal study of growth and cognitive development from 4 to 11 years. J Child Psychol Psychiatry. 1998;39(7):1017-29. [pmid: 9804034].
Downie AB, Mulligan J, Stratford RJ, et al. Are short normal children at a disadvantage? The Wessex growth study. BMJ. 1997 Jan 11;314(7074):97-100. [pmcid: 167160].
Evans RW, Manninen DL, Garrison LP, et al. The use of rehabilitation services by patients with chronic renal failure: results from the National Kidney Dialysis and Kidney Transplantation Study. AANNT J. 1983 Oct;10(6):19-25.
Faber RL, Wilde SW, editors. The KT/DA patient handbook. 4th ed. Boston (MA): Kidney Transplant/Dialysis Association, Inc; 1993. 47 p.
Ferrans CE, Powers MJ. The employment potential of hemodialysis patients. Nurs Res. 1985 Sep-Oct;34(5):273-7.
Friedman N, Rogers TF. Dialysis and the world of work. Contemp Dial Nephrol. 1988 Jan;19:16-9.
Gutman RA, Stead WW, Robinson RR. Physical activity and employment status of patients on maintenance dialysis. N Engl J Med. 1981 Feb 5;304(6):309-13.
Hahn H. The political implications of disability definitions and data. J Disabil Policy Stud. 1993;4(2):41-52.
Henning P, Tomlinson L, Rigden SP, Haycock GB, Chantler C. Long term outcome of treatment of end stage renal failure. Arch Dis Child. 1988 Jan;63(1):35-40.
Hirth RA. (University of Michigan School of Public Health). Personal communication. 1999 Sep 30. 5 p.
Holley JL, Nespor S. An analysis of factors affecting employment of chronic dialysis patients. Am J Kidney Dis. 1994 May;23(5):681-5.
Hu J, Lahiri K, Vaughan DR, et al. A structural model of Social Security's disability determination process. Washington (DC): Social Security Administration Division of Economic Research; 1997 Aug. 61 p. (ORES working paper series; no. 72).
Ifudu O, Paul H, Mayers JD, et al. Pervasive failed rehabilitation in center-based maintenance hemodialysis patients. Am J Kidney Dis. 1994 Mar;23(3):394-400.
Improvements in data quality in the USRDS database: determining treatment modalities. Am J Kidney Dis. 1992 Nov;20(5 Suppl 2):89-94.
Johnson JP, McCauley CR, Copley JB. The quality of life of hemodialysis and transplant patients. Kidney Int. 1982 Sep;22(3):286-91.
Julius M, Kneisley JD, Carpentier-Alting P, et al. A comparison of employment rates of patients treated with continuous ambulatory peritoneal dialysis vs in-center hemodialysis (Michigan End- Stage Renal Disease Study). Arch Intern Med. 1989 Apr;149(4):839-42.
Kamberg C. (Rand Corporation). Personal communication. 1999 May 19. 5 p.
Kapron KA, Nix W, Smith-Wheelock L. Getting patients back to work: an update on the NKF Michigan Renal Rehabilitation Program. Nephrol News Issues. 1996 Nov;10(11):44-6 48, 53.
Kidney Dialysis Foundation. About kidney disease and dialysis. Vascular access [online]. Singapore: Kidney Dialysis Foundation; [cited 1999 Mar 24]. [13 p]. Available: http://www.kdf.org.sg/aboutkidney-main.html.
Kimmel PL, Peterson RA, Weihs KL, et al. Aspects of quality of life in hemodialysis patients. J Am Soc Nephrol. 1995 Nov;6(5):1418-26.
Kruger J, Dunning D. Unskilled and unaware of it: how difficulties in recognizing one's own incompetence lead to inflated self-assessments. J Pers Soc Psychol. 1999 Dec;77(6):1121-34.
Kurtin PS, Landgraf JM, Abetz L. Patient-based health status measurements in pediatric dialysis: expanding the assessment of outcome. Am J Kidney Dis. 1994 Aug;24(2):376-82.
Kutner NG, Brogan D, Fielding B. Employment status and ability to work among working-age chronic dialysis patients. Am J Nephrol. 1991;11(4):334-40. [pmid: 1799194].
Kutner NG, Brogan DR. Network vocational rehabilitation goals. Nephrol News Iss. 1989;3:28-9.
Kutner NG, Cardenas DD. Assessment of rehabilitation outcomes among chronic dialysis patients. Am J Nephrol. 1982;2(3):128-32. [pmid: 7180909].
Kutner NG, Cardenas DD. Rehabilitation status of chronic renal disease patients undergoing dialysis: variations by age category. Arch Phys Med Rehabil. 1981 Dec;62(12):626-30.
Lachman ME, Jelalian E. Self-efficacy and attributions for intellectual performance in young and elderly adults. J Gerontol. 1984 Sep;39(5):577-82.
LaPlante MP. The demographics of disability. Milbank Q. 1991;69 Suppl 1:55-77. [pmid: 1837839].
Levey AS, Bosch JP, Lewis JB, et al. A more accurate method to estimate glomerular filtration rate from serum creatinine: a new prediction equation. Modification of Diet in Renal Disease Study Group. Ann Intern Med. 1999 Mar 16;130(6):461-70.
The Life Options Rehabilitation Advisory Council, Amgen, Inc. Building quality of life: a practical guide to renal rehabilitation. Thousand Oaks (CA): Amgen, Inc; 1997. 145 p.
The Life Options Rehabilitation Advisory Council (LORAC). Oberley E, editor. Renal rehabilitation. Bridging the barriers. Madison (WI): Medical Eduction Institute, Inc; 1994. 144 p.
Lundin AP, Lundin MF. Some impediments to rehabilitation in dialysis patients. AANNT J. 1983 Oct;10(6):29-31, 57.
McKillop KJ Jr, Berzonsky MD, Schlenker BR. The impact of self-presentations on self-beliefs: effects of social identity and self-presentational context. J Pers. 1992 Dec;60(4):789-808.
McMahon LP, Dawborn JK. Subjective quality of life assessment in hemodialysis patients at different levels of hemoglobin following use of recombinant human erythropoietin. Am J Nephrol. 1992;12(3):162-9. [pmid: 1415377].
Merkus MP, Jager KJ, Dekker FW, et al. Quality of life in patients on chronic dialysis: self-assessment 3 months after the start of treatment. The Necosad Study Group. Am J Kidney Dis. 1997 Apr;29(4):584-92.
Mitch WE, Maroni BJ. Nutritional considerations and the indications for dialysis. Am J Kidney Dis. 1998 Jan;31(1):185-9.
Morrison G. Kidney. In: Tierney LM Jr, McPhee SJ, Papadakis MA, editors. Current medical diagnosis and treatment. 36th ed. Stamford (CT): Appleton & Lange; 1997. p. 827-53.
Nagi SZ. The concept and measurement of disability. In: Berkowitz ED, editor. Disability policies and government programs. New York: Praeger; 1979. p. 1-15.
Nagi SZ. Disability concepts revisited: implications for prevention. In: Pope AM, Tarlov AR, editors. Disability in America: toward a national agenda for prevention.. Washington (DC): National Academy Press; 1991. p. 309-27.
Nagi SZ. Some conceptual issues in disability and rehabilitation. In: Sussman MB, editor. Sociology and rehabilitation. Washington (DC): American Sociological Association; 1965. p. 100-13.
National Institute of Diabetes and Digestive and Kidney Diseases. End-stage renal disease: choosing a treatment that's right for you [online]. Bethesda (MD): National Kidney and Urologic Diseases Information Clearinghouse; 1994 Jun [updated 1997 Oct 17]; [cited 1998 Sep 22]. [17 p]. Available: http://www.niddk.nih.gov/health/kidney/pubs/esrd/esrd.html.
National Institute of Diabetes and Digestive and Kidney Diseases. Your kidneys and how they work [online]. Bethesda (MD): National Kidney and Urologic Diseases Information Clearinghouse (NKUDIC); 1998 Mar [cited 1998 Nov 13]. [12 p.]. Available: http://www.niddk.nih.gov/health/kidney/pubs/yourkids/index.htm.
Pope AM, Tarlov AR, editors. Disability in America: toward a national agenda for prevention. Washington (DC): National Academy Press; 1991. 362 p.
Proposed rules. Federal old-age, survivors and disability insurance and supplemental security income for the aged, blind, and disabled; determining disability and blindness; clarification of "age" as a vocational factor. 20 CFR Parts 404 and 416. Fed Regist. 1999 Aug 4;64(149):42310-5.
Rasgon S, Schwankovsky L, James-Rogers A, et al. An intervention for employment maintenance among blue-collar workers with end-stage renal disease. Am J Kidney Dis. 1993 Sep;22(3):403-12.
Rettig RA, Levinsky NG, editors. Institute of Medicine, Division of Health Care Services, Committee for the Study of the Medicare End-Stage Renal Disease Program. Kidney failure and the federal government. Washington, DC: National Academy Press; 1991. 426 p.
Rozenbaum EA, Chaimovitz C, Bearman JE. Quality of life of patients on chronic dialysis. Isr J Med Sci. 1984 Feb;20(2):104-8.
Sesso R, Yoshihiro MM. Time of diagnosis of chronic renal failure and assessment of quality of life in haemodialysis patients. Nephrol Dial Transplant. 1997 Oct;12(10):2111-6.
Simmons RG, Abress L. Quality-of-life issues for end-stage renal disease patients. Am J Kidney Dis. 1990 Mar;15(3):201-8.
Social Security Administration, Office of Disability, Office of Supplemental Security Income. Red book on work incentives -- a summary guide to Social Security and supplemental security income work incentives for people with disabilities. Baltimore (MD): Social Security Administration; 1995 Aug. 57 p.
Social Security Administration. Disability evaluation under Social Security. Washington DC: Social Security Administration, U.S. Government Printing Office; 1998 Jan. 205 p. (no. 64-039).
Social Security Administration. How we can help with vocational rehabilitation [online]. Baltimore, MD: Social Security Administration; 1997b [cited 1999 Mar 18]. Available: http://www.ssa.gov/pubs/10050.html.
Social Security Administration. Personal communication. 1999b Oct 1. 32 p.
Social Security Administration. Social Security Act. Vocational considerations. 20 CFR § 404.1562 (1997a). Available: http://www.ssa.gov/OP_Home/cfr20/404/404-1562.htm.
Social Security Administration. Social Security history page [online]. Baltimore (MD): Social Security Administration; 1999a [cited 1999 Mar 16]. [15 p]. Available: http://www.ssa.gov/history/history6.html.
Social Security Administration. 20 CFR Parts 404 and 416. Old-age, survivors, and disability insurance and supplemental security income for the aged, blind, and disabled; substantial gainful activity amounts [published erratum Fed Regist 1999 Apr 28 64(81);22903]. Fed Regist. 1999c Apr 15;64(72):18566-71.
Solomon CD. Major decisions in the House and Senate chambers on Social Security: 1935-1985. Washington (DC): Library of Congress, Congressional Research Service; 1986 Dec 29. 122 p. (CRS report for Congress; no. 86-193 EPW).
Spinowitz BS. EPO -- one year later: a look at rehabilitation. The impact of long-term epoetin beta therapy on ESRD patient quality of life. Nephrol News Issues. 1990 Jun;4(6):35-7. [pmid: 2205809].
Stegman MR, Pohren E, Ducan K, et al. Clinical determinants of vocational status among hemodialysis patients. J Nephrol Nurs. 1985 Sep-Oct;2(5):236-40.
Stone DA. The disabled state. Philadelphia: Temple University Press; 1984. 241 p.
Tews HP, Schreiber WK, Huber W, et al. Vocational rehabilitation in dialyzed patients. A cross-sectional study. Nephron. 1980;26(3):130-6. [pmid: 6968040].
United Network for Organ Sharing (UNOS). The 1997 report of center specific graft and patient survival rates [online]. Richmond (VA): United Network for Organ Sharing; 1997 [cited 1999 Mar 25]. [33 p]. Available: http://www.unos.org/frame_Default.asp?category=resourcereport#centerspecific [order printed version only].
United States Congress. H.R. Res. 8423, 95th Cong., 1st Sess. (1977).
United States Congress. Social Security Act (act of August 14, 1935) (Public Law 74-271). Washington (DC): Government Printing Office; 1935 Aug 14.
United States Congress. Social Security Act. Subpart P - Determining disability and blindness. 20 CFR § 404.1501-1599 (1997).
United States Renal Data System. Researcher's guide to the USRDS database. Bethesda (MD): The National Institutes of Health, National Institute of Diabetes and Digestive and Kidney Diseases; 1998.
United States Renal Data System, National Institutes of Health (NIH), National Institute for Diabetes and Digestive and Kidney Diseases (NIDDK). Researcher's guide to the USRDS database. Bethesda (MD): United States Renal Data System; 1999b Apr. 505 p.
United States Renal Data System, National Institutes of Health (NIH), National Institute of Diabetes and Digestive and Kidney Diseases. USRDS 1999 annual data report. Bethesda (MD): United States Renal Data System; 1999a Apr. 994 p.
Verbrugge LM, Jette AM. The disablement process. Soc Sci Med. 1994 Jan;38(1):1-14.
Wadgymar A, Wu GG, Fenton SS, et al. Two year experience with continuous ambulatory peritoneal dialysis. Proc Clin Dial Transplant Forum. 1980;10:109-13. [pmid: 6810338].
Wilson DM, Hammer LD, Duncan PM, et al. Growth and intellectual development. Pediatrics. 1986 Oct;78(4):646-50.
Witten B. (Witten and Assoc., Overland Park, KS). Personal communication. 1999 Sep 27. 18 p.
Wolcott DL, Nissenson AR. Quality of life in chronic dialysis patients: a critical comparison of continuous ambulatory peritoneal dialysis (CAPD) and hemodialysis. Am J Kidney Dis. 1988 May;11(5):402-12.
Wolcott DL, Nissenson AR, Landsverk J. Quality of life in chronic dialysis patients. Factors unrelated to dialysis modality. Gen Hosp Psychiatry. 1988 Jul;10(4):267-77.
Wolcott DL, Wellisch DK, Marsh JT, et al. Relationship of dialysis modality and other factors to cognitive function in chronic dialysis patients. Am J Kidney Dis. 1988 Oct;12(4):275-84.
World Health Organization (WHO). ICIDH-2: international classification of impairments, activities and participation: a manual of dimensions of disablement and health [online]. 1980 [cited 1998 Jul 09]. [27 p.]. Available: http://www-nt.who.int/icidh/classification/icidh.cfm.