# References

Completeness and reliability of USRDS data: comparisons with the Michigan Kidney Registry. Am J Kidney Dis. 1992 Nov;20(5 Suppl 2):84-8.
Cook TD, Campbell DT. Quasi-experimentation: design and analysis issues for field settings. Boston: Houghton Mifflin Company; 1979. 405 p.
De-Nour AK, Czaczkes JW. Personality factors influencing vocational rehabilitation. Arch Gen Psychiatry. 1975 May;32(5):573-7.
Dowdney L, Skuse D, Morris K, et al. Short normal children and environmental disadvantage: a longitudinal study of growth and cognitive development from 4 to 11 years. J Child Psychol Psychiatry. 1998;39(7):1017-29. [pmid: 9804034].
Downie AB, Mulligan J, Stratford RJ, et al. Are short normal children at a disadvantage? The Wessex growth study. BMJ. 1997 Jan 11;314(7074):97-100. [pmcid: 167160].
Evans RW, Manninen DL, Garrison LP, et al. The use of rehabilitation services by patients with chronic renal failure: results from the National Kidney Dialysis and Kidney Transplantation Study. AANNT J. 1983 Oct;10(6):19-25.
Faber RL, Wilde SW, editors. The KT/DA patient handbook. 4th ed. Boston (MA): Kidney Transplant/Dialysis Association, Inc; 1993. 47 p.
Ferrans CE, Powers MJ. The employment potential of hemodialysis patients. Nurs Res. 1985 Sep-Oct;34(5):273-7.
Gutman RA, Stead WW, Robinson RR. Physical activity and employment status of patients on maintenance dialysis. N Engl J Med. 1981 Feb 5;304(6):309-13.
Hahn H. The political implications of disability definitions and data. J Disabil Policy Stud. 1993;4(2):41-52.
Hirth RA. (University of Michigan School of Public Health). Personal communication. 1999 Sep 30. 5 p.
Hu J, Lahiri K, Vaughan DR, et al. A structural model of Social Security's disability determination process. Washington (DC): Social Security Administration Division of Economic Research.; 1997 Aug. 61 p. (ORES working paper series; no. 72).
Improvements in data quality in the USRDS database: determining treatment modalities. Am J Kidney Dis. 1992 Nov;20(5 Suppl 2):89-94.
Kapron KA, Nix W, Smith-Wheelock L. Getting patients back to work: an update on the NKF Michigan Renal Rehabilitation Program. Nephrol News Issues. 1996 Nov;10(11):44-6 48, 53.
Kidney Dialysis Foundation. About kidney disease and dialysis. Vascular access [online]. Singapore: Kidney Dialysis Foundation; [cited 1999 Mar 24]. [13 p]. Available: http://www.kdf.org.sg/aboutkidney-main.html.
Kruger J, Dunning D. Unskilled and unaware of it: how difficulties in recognizing one's own incompetence lead to inflated self-assessments. J Pers Soc Psychol. 1999 Dec;77(6):1121-34.
Kutner NG, Brogan D, Fielding B. Employment status and ability to work among working-age chronic dialysis patients. Am J Nephrol. 1991;11(4):334-40. [pmid: 1799194].
Kutner NG, Brogan DR. Network vocational rehabilitation goals. Nephrol News Iss. 1989;3:28-9.
Lachman ME, Jelalian E. Self-efficacy and attributions for intellectual performance in young and elderly adults. J Gerontol. 1984 Sep;39(5):577-82.
LaPlante MP. The demographics of disability. Milbank Q. 1991;69 Suppl 1:55-77. [pmid: 1837839].
The Life Options Rehabilitation Advisory Council, Amgen, Inc. Building quality of life: a practical guide to renal rehabilitation. Thousand Oaks (CA): Amgen, Inc; 1997. 145 p.
The Life Options Rehabilitation Advisory Council. Oberley E, editor(s). Renal rehabilitation. Bridging the barriers. Madison (WI): Medical Eduction Institute, Inc; 1994. 144 p.
Lundin AP, Lundin MF. Some impediments to rehabilitation in dialysis patients. AANNT J. 1983 Oct;10(6):29-31, 57.
McKillop KJ Jr, Berzonsky MD, Schlenker BR. The impact of self-presentations on self-beliefs: effects of social identity and self-presentational context. J Pers. 1992 Dec;60(4):789-808.
Mitch WE, Maroni BJ. Nutritional considerations and the indications for dialysis. Am J Kidney Dis. 1998 Jan;31(1):185-9.
Morrison G. Kidney. In: Tierney LM Jr, McPhee SJ, Papadakis MA, editors. Current medical diagnosis and treatment. 36th ed. Stamford (CT): Appleton & Lange; 1997. p. 827-53.
Nagi SZ. The concept and measurement of disability. In: Berkowitz ED, editor. Disability policies and government programs. New York: Praeger; 1979. p. 1-15.
Nagi SZ. Disability concepts revisited: implications for prevention. In: Pope AM, Tarlov AR, editors. Disability in America: toward a national agenda for prevention. Washington (DC): National Academy Press; 1991. p. 309-27.
Nagi SZ. Some conceptual issues in disability and rehabilitation. In: Sussman MB, editor. Sociology and rehabilitation. Washington (DC): American Sociological Association; 1965. p. 100-13.
National Institute of Diabetes and Digestive and Kidney Diseases. End-stage renal disease: choosing a treatment that's right for you [online]. Bethesda (MD): National Kidney and Urologic Diseases Information Clearinghouse; 1994 Jun [updated 1997 Oct 17]; [cited 1998 Sep 22]. [17 p]. Available: http://www.niddk.nih.gov/health/kidney/pubs/esrd/esrd.html.
National Institute of Diabetes and Digestive and Kidney Diseases. Your kidneys and how they work [online]. Bethesda (MD): National Kidney and Urologic Diseases Information Clearinghouse; 1998 Mar [cited 1998 Nov 13]. [12 p.]. Available: http://www.niddk.nih.gov/health/kidney/pubs/yourkids/index.htm.
Pope AM, Tarlov AR, editors. Disability in America: toward a national agenda for prevention. Washington (DC): National Academy Press; 1991. 362 p.
Proposed rules. Federal old-age, survivors and disability insurance and supplemental security income for the aged, blind, and disabled; determining disability and blindness; clarification of "age" as a vocational factor. 20 CFR Parts 404 and 416. Fed Regist. 1999 Aug 4;64(149):42310-5.
Rettig RA, Levinsky NG, editors. Institute of Medicine, Division of Health Care Services, Committee for the Study of the Medicare End-Stage Renal Disease Program. Kidney failure and the federal government. Washington, DC: National Academy Press; 1991. 426 p.
Social Security Administration, Office of Disability, Office of Supplemental Security Income. Red book on work incentives -- a summary guide to Social Security and supplemental security income work incentives for people with disabilities. Baltimore (MD): Social Security Administration; 1995 Aug. 57 p.
Social Security Administration. Disability evaluation under Social Security. Washington DC: Social Security Administration, U.S. Government Printing Office; 1998 Jan. 205 p. (no. 64-039).
Social Security Administration. How we can help with vocational rehabilitation [online]. Baltimore, MD: Social Security Administration; 1997b [cited 1999 Mar 18]. Available: http://www.ssa.gov/pubs/10050.html.
Social Security Administration. Personal communication. 1999b Oct 1. 32 p.
Social Security Administration. Social Security Act. Vocational considerations. 20 CFR § 404.1562 (1997a). Available: http://www.ssa.gov/OP_Home/cfr20/404/404-1562.htm.
Social Security Administration. Social Security history page [online]. Baltimore (MD): Social Security Administration; 1999a [cited 1999 Mar 16]. [15 p]. Available: http://www.ssa.gov/history/history6.html.
Social Security Administration. 20 CFR Parts 404 and 416. Old-age, survivors, and disability insurance and supplemental security income for the aged, blind, and disabled; substantial gainful activity amounts [published erratum Fed Regist 1999 Apr 28 64(81);22903]. Fed Regist. 1999c Apr 15;64(72):18566-71.
Solomon CD. Major decisions in the House and Senate chambers on Social Security: 1935-1985. Washington (DC): Library of Congress, Congressional Research Service; 1986 Dec 29. 122 p. (CRS report for Congress; no. 86-193 EPW).
Stone DA. The disabled state. Philadelphia: Temple University Press; 1984. 241 p.
United Network for Organ Sharing (UNOS). The 1997 report of center specific graft and patient survival rates [online]. Richmond (VA): United Network for Organ Sharing; 1997 [cited 1999 Mar 25]. [33 p]. Available: http://www.unos.org/frame_Default.asp?category=resourcereport#centerspecific [order printed version only].
United States Congress. H.R. Res. 8423, 95th Cong., 1st Sess. (1977).
United States Renal Data System. Researcher's guide to the USRDS database. Bethesda (MD): The National Institutes of Health, National Institute of Diabetes and Digestive and Kidney Diseases; 1998.
United States Renal Data System, National Institutes of Health, National Institute for Diabetes and Digestive and Kidney Diseases. Researcher's guide to the USRDS database. Bethesda (MD): United States Renal Data System; 1999b Apr. 505 p.
United States Renal Data System, National Institutes of Health, National Institute of Diabetes and Digestive and Kidney Diseases. USRDS 1999 annual data report. Bethesda (MD): United States Renal Data System; 1999a Apr. 994 p.
Verbrugge LM, Jette AM. The disablement process. Soc Sci Med. 1994 Jan;38(1):1-14.
Wilson DM, Hammer LD, Duncan PM, et al. Growth and intellectual development. Pediatrics. 1986 Oct;78(4):646-50.
Witten B. (Witten and Assoc., Overland Park, KS). Personal communication. 1999 Sep 27. 18 p.
Wolcott DL, Nissenson AR, Landsverk J. Quality of life in chronic dialysis patients. Factors unrelated to dialysis modality. Gen Hosp Psychiatry. 1988 Jul;10(4):267-77.
World Health Organization (WHO). ICIDH-2: international classification of impairments, activities and participation: a manual of dimensions of disablement and health [online]. 1980 [cited 1998 Jul 09]. [27 p.]. Available: http://www-nt.who.int/icidh/classification/icidh.cfm.