# Future Research

This section discusses limitations of currently available evidence regarding disability criteria for patients with CRF. In the process, we also discuss how these limitations could be addressed in the future, though we acknowledge that addressing them is likely to be difficult because of the large number of patients that would likely be required.

In approaching the present evidence report, we first examined the published literature for information about predictors of disability in patients with CRF. Fourteen studies were identified that provided some limited information about the relationship between employment status and patient characteristics; however, there were several limitations to all of these studies.

One limitation encountered in these studies was that their designs did not allow one to evaluate the relationship between a health state at time 1 to an outcome at time 2, such as SSA is interested in. One step that can be taken to address this is to conduct a longitudinal study that specifically addresses disability, and to use the resulting data to identify "predictor" variables for the outcome of interest. This could be accomplished, for example, using the statistical methods we attempted with the DMMS Wave 2 database. While these methods do not ensure that the relationship is a causal one, such a relationship is much more likely to be identified from this sort of longitudinal analysis than from univariate analyses at a single point in time, and has the added ability to take covariates into account.

Another limitation of the published literature was that most of the variables examined were demographic or psychological, and therefore not ethically or easily incorporated into the SSA disability assessment process. Because patients on dialysis are constantly undergoing medical and physiological testing, collection of such information should be relatively easy for the interested researcher. The DMMS Wave 2 database includes many such variables of interest, such as BUN, serum creatinine, weight (which can be translated into body-mass index, a more meaningful measurement), and blood pressure. Researchers of smaller studies who are interested in addressing the SSA disability criteria should also be able to collect such data.

In many studies, vocational status was the only outcome measure reported that was relevant to "ability to work". This measure may not accurately reflect a patient's ability to work. This presents difficulties, because, as we discussed in the Methodology section of this report, the measurement of ability to work is not straightforward and indirect measures such as employment status and self-reported ability to work must be used.

Another difficulty (that was specific to the present evidence report) was that patients in clinical trials that studied the impact of ESRD on employment were examined at many different time intervals after the start of dialysis. Most patients were examined or interviewed 5 to 6 years after beginning dialysis. The results from these patients are likely not generalizable to patients interviewed within a year of beginning dialysis (as was of interest in this report). However, a study such as DMMS Wave 2, which prospectively identified incident dialysis patients, corrects for this problem.

Most studies used univariate statistical tests (e.g., chi-square, ANOVA). These tests do not control for the effects that other variables might have upon the outcomes. For example, one may find that diabetes patients with ESRD die sooner than those with glomerulonephritis, but this does not take into account that diabetes patients with ESRD are generally older than glomerulonephritis patients. Thus, age may play a contributory role in the death rate. Multivariate analysis and other modelling techniques are very useful for determining the effects of such covariates.

Because of the sparse information in the published literature, we examined data in the USRDS DMMS Wave 2 database. This is a database of 4,026 incident dialysis patients who were followed prospectively for approximately a year and asked questions about medical, functional, and demographic status. DMMS Wave 2 was a well-designed epidemiological study that, along with the USRDS as a whole, provides information for answering many questions. The researchers sought to address a broad range of issues, which allowed for the possibility of a multitude of different basic analyses. However, this database was not intended to study disability issues. There were, therefore, several problems with this database that precluded its use in the complex, multivariate analysis that we would need to conduct to answer the key questions of this project.

One problem we encountered was that few of the patients in this database were working or had worked at any point in the recent past, which was one inclusion criterion for our proposed final analysis. This, in turn did not allow us to pursue further analyses. There are, however, widely available statistics from USRDS about the initial working status of patients on dialysis. These statistics would allow one to estimate the proportion of the patient population that can be expected to work or to have previously been working. This proportion can then be used in a statistical power calculation to determine how many patients are needed for an adequate number of employed patients to be represented in future studies. Alternatively, if only the previously employed patients are of interest, then only those patients need be included in a future study, thus reducing the number of patients that need to be tracked over time.

Although the number of patients initially included in this database was 4,026, the number of patients under age 65 who actually had followup data on employment status or self-reported ability to work (the crucial outcome measures of this report) was reduced to 546. Because of the number of variables we would include in any multivariate analysis, this smaller subset limits the statistical power of any analysis we might conduct. Assuming that loss to followup is 50 percent, that there are 85 variables (see our sample analysis in Appendix E), and using the simplistic "rule of thumb" that there should be 10 patients for every variable, then at least 1,700 patients (under age 65) are needed at the start of the study.^3^ The DMMS Wave 2 data did not contain important information about which patients were receiving SSI or SSDI benefits, nor was it designed to collect such information (United States Renal Data System, 1999a). Such information was of particular interest to answer the key question of this project. DMMS Wave 2 included more than 300 questions in all, which were represented by these two questionnaires, covering many different aspect of the patient's life. In general, these questionnaires appeared to be very complete.

3 We have not performed a precise statistical power analysis here. Doing so awaits a detailed study design and is, therefore, premature.

An additional section of questions could be included that would specifically address the issues raised in this evidence report, but such an addition could be problematic, as the patient questionnaire is already quite long. Nevertheless, additional questions could include:

1 Are you currently receiving Social Security disability payments?
2 If so, when did your coverage begin?
  A. A. before dialysis began
  B. B. after dialysis began
3 If not, have you applied for SSA disability coverage?

There are also some symptom- and physiologically-related questions that were not included in the original DMMS Wave 2 study that may offer further information about the functioning and abilities of the patient. These include questions about chronic obstructive pulmonary disease (COPD), peptic ulcer disease, recurrent gastrointestinal bleeding, cerebrovascular accident, chronic arthritis, cardiomyopathies, angina, and bronchitis and emphysema.

One relatively insignificant problem encountered was that this database included only patients undergoing in-center hemodialysis and peritoneal dialysis; patients using at-home hemodialysis were excluded. Although this is a very minor problem as at-home hemodialysis is only used by a very small percentage of patients on dialysis, it is important that they be represented in a study that wishes to be generalizable to the overall population of patients with renal disease.