# Conclusions

The primary goal of this report was to assess current SSA disability criteria for patients with CRF and, if these were deemed insufficient or inaccurate for identifying those patients truly unable to work, to identify the best functional and medical predictors of disability. We determined that there are currently no data from the published literature or from unpublished registry sources that can answer the questions posed in this evidence report. Determining disability is a complex task that requires assessing several domains of functionality simultaneously. Research conducted thus far does not allow us to assess existing and potential disability criteria using the multivariate methods that are necessary for valid and reliable findings.

No data were found that addressed disability criteria for patients with pre-ESRD CRF, therefore, the remainder of the project focused solely on ESRD. Fourteen studies were identified that looked at the relationship between demographic and medical variables and employment status among adult ESRD patients; no studies were identified that addressed disability issues in pediatric patients. These 14 studies were limited by their use of univariate statistics, types of statistics that did not allow the distinction of cause and effect, and a time frame that was not appropriate for our analysis; therefore, we concluded that no data were available in the published literature for the purposes of this report.

We then explored the possibility of using raw data from the USRDS to conduct de novo statistical analyses on ability to predict employment status or ability to work using functional and medical status measurements as predictor variables. On initial evaluation, the USRDS Dialysis Morbidity and Mortality Study Wave 2 appeared to contain much of the data we required: a large patient pool, assessment of many functional and medical variables, and assessment at initialization of dialysis, as well as followup 9 to 12 months later. However, the subset of data from this database we intended to use for this analysis suffered from some flaws, most importantly, a high patient dropout rate, many missing individual data points, and few people who were working at the start of the study. These flaws rendered it difficult and unreliable to perform the planned multivariate statistical analyses on this database. However, we have provided an illustration of this planned analysis, which, though the exact results cannot be considered reliable, does provide some valuable information in pursuing future research on this topic.

As a result, the statistics we have presented in this report are purely descriptive, they offer a portrait of working versus nonworking patients with end-stage renal disease, and they compare patients in different types of employment positions. We have described the employment patterns of patients initializing dialysis therapy, noting that, as expected, the percentage of people employed full time drops dramatically after the onset of dialysis. Functional and laboratory correlations with employment status are also presented. These data may offer guidance for the development of future research.

We have also offered some complex illustrative analyses of predictors of working ability, which seem to indicate that even when many patient characteristics and conditions are examined in conjunction, there is still diagnostic error for prediction of working status, self-reported ability to work, and most severely, death. For prediction of the indirect measures of ability to work, it was particularly interesting that physiologic, laboratory, and comorbidity measures showed very low accuracy for prediction of working status and self-reported ability to work; however, if sociodemographic variables were added to the equation, predictive ability increased markedly. When analyzed as diagnostic tests, however, the real-life accuracy of these two models was similar.

However, these results cannot be considered a reliable foundation for disability coverage due to the uncertainties raised by unreliable data and the usefulness of the indirect measures of inability to work.