# Appendix D: Descriptive Statistics

Tables D-1 through D-6 show data pertaining just to those patients who were eligible for inclusion in our final data set, as described in Table 3, a subset of 546 patients who were working at some point in the past and for whom followup data were available. Table D-1, below, suggests that patients with inherent kidney disease are more likely to continue working than those with diabetes. Patients with any of several different forms of cardiac or vascular disease are less likely to be working than those not impaired with these diseases. It must be noted that these are univariate statistics that do not account for collinearity of other variables. A more specific breakdown of employment status for patients with these conditions is shown in Table D-2.

Table D-3 shows the laboratory test results for patients who continued to work full time versus those who did not, while Table D-4 shows aspects of quality of life as measured by the Kidney Disease Quality-of-Life (KDQOL^TM^) questionnaire. Table D-5 shows the laboratory results broken out by employment status at the beginning of the study. Because of the univariate nature of these statistics, we have not analyzed them and simply present them for perusal.

Table D-6 shows the breakdown of employment status for several different demographic, lifestyle, socioeconomic status, and employment-related measures. Again, because these are univariate summary statistics, we will not try to analyze their import here.

Table D-1. Categorical disease states by work statusAppendix D: Descriptive Statistics

Table D-1. Categorical disease states by work statusAppendix D: Descriptive Statistics

| | Work status
| | Continue to work | Do not continue to work | Total
Primary causal disease
Diabetes | Count | 43 | 102 | 145
| % | 29.66% | 70.34% | 100.00%
Hypertension | Count | 42 | 71 | 113
| % | 37.17% | 62.83% | 100.00%
Primary glomerulonephritis | Count | 20 | 30 | 50
| % | 40.00% | 60.00% | 100.00%
Polycystic kidney disease | Count | 53 | 57 | 110
| % | 48.18% | 51.82% | 100.00%
| Count | 158 | 260 | 418
| % | 37.80% | 62.20% | 100.00%
CHD/CAD
Yes | Count | 18 | 41 | 59
| % | 30.51% | 69.49% | 100.00%
Suspected | Count | 2 | 6 | 8
| % | 25.00% | 75.00% | 100.00%
No | Count | 136 | 209 | 345
| % | 39.42% | 60.58% | 100.00%
Total | Count | 156 | 256 | 412
| % | 37.86% | 62.14% | 100.00%
Angina
Yes | Count | 14 | 24 | 38
| % | 36.84% | 63.16% | 100.00%
Suspected | Count | 3 | 2 | 5
| % | 60.00% | 40.00% | 100.00%
No | Count | 140 | 227 | 367
| % | 38.15% | 61.85% | 100.00%
Total | Count | 157 | 253 | 410
| % | 38.29% | 61.71% | 100.00%
Myocardial infarct
Yes | Count | 9 | 15 | 24
| % | 37.50% | 62.50% | 100.00%
Suspected | Count | 1 | 3 | 4
| % | 25.00% | 75.00% | 100.00%
No | Count | 147 | 236 | 383
| % | 38.38% | 61.62% | 100.00%
Total | Count | 157 | 254 | 411
| % | 38.20% | 61.80% | 100.00%
CABG
Yes | Count | 8 | 12 | 20
| % | 40.00% | 60.00% | 100.00%
Suspected | Count | | 1 | 1
| % | 0.00% | 100.00% | 100.00%
No | Count | 149 | 242 | 391
| % | 38.11% | 61.89% | 100.00%
Total | Count | 157 | 255 | 412
| % | 38.11% | 61.89% | 100.00%
Abnormal angiography
Yes | Count | 9 | 11 | 20
| % | 45.00% | 55.00% | 100.00%
Suspected | Count | 1 | 2 | 3
| % | 33.33% | 66.67% | 100.00%
No | Count | 65 | 109 | 174
| % | 37.36% | 62.64% | 100.00%
Total | Count | 75 | 122 | 197
| % | 38.07% | 61.93% | 100.00%
Cardiac arrest
Yes | Count | 2 | 1 | 3
| % | 66.67% | 33.33% | 100.00%
Suspected | Count | | 1 | 1
| % | 0.00% | 100.00% | 100.00%
No | Count | 149 | 252 | 401
| % | 37.16% | 62.84% | 100.00%
Total | Count | 151 | 254 | 405
| % | 37.28% | 62.72% | 100.00%
Cerebrovascular disease
Yes | Count | 1 | 13 | 14
| % | 7.14% | 92.86% | 100.00%
Suspected | Count | 1 | 3 | 4
| % | 25.00% | 75.00% | 100.00%
No | Count | 155 | 241 | 396
| % | 39.14% | 60.86% | 100.00%
Total | Count | 157 | 257 | 414
| % | 37.92% | 62.08% | 100.00%
Transient ischemic attack
Yes | Count | 2 | 6 | 8
| % | 25.00% | 75.00% | 100.00%
Suspected | Count | | 8 | 8
| % | 0.00% | 100.00% | 100.00%
No | Count | 150 | 218 | 368
| % | 40.76% | 59.24% | 100.00%
Total | Count | 152 | 232 | 384
| % | 39.58% | 60.42% | 100.00%
Peripheral vascular disease
Yes | Count | 7 | 17 | 24
| % | 29.17% | 70.83% | 100.00%
Suspected | Count | | 5 | 5
| % | 0.00% | 100.00% | 100.00%
No | Count | 148 | 233 | 381
| % | 38.85% | 61.15% | 100.00%
Total | Count | 155 | 255 | 410
| % | 37.80% | 62.20% | 100.00%
Amputee
Yes | Count | 2 | 3 | 5
| % | 40.00% | 60.00% | 100.00%
Suspected | Count | 154 | 252 | 406
| % | 37.93% | 62.07% | 100.00%
No | Count | 156 | 255 | 411
| % | 37.96% | 62.04% | 100.00%
Total
Limb amputation
Yes | Count | 0 | 1 | 1
| % | 0.00% | 100.00% | 100.00%
Suspected | Count | 156 | 254 | 410
| % | 38.05% | 61.95% | 100.00%
No | Count | 156 | 255 | 411
| % | 37.96% | 62.04% | 100.00%
Total
Absent foot pulse
Yes | Count | | 6 | 6
| % | 0.00% | 100.00% | 100.00%
Suspected | Count | | 6 | 6
| % | 0.00% | 100.00% | 100.00%
No | Count | 155 | 242 | 397
| % | 39.04% | 60.96% | 100.00%
Total | Count | 155 | 254 | 409
| % | 37.90% | 62.10% | 100.00%
Claudication
Yes | Count | 1 | 8 | 9
| % | 11.11% | 88.89% | 100.00%
Suspected | Count | | 6 | 6
| % | 0.00% | 100.00% | 100.00%
No | Count | 155 | 239 | 394
| % | 39.34% | 60.66% | 100.00%
Total | Count | 156 | 253 | 409
| % | 38.14% | 61.86% | 100.00%
Congestive heart failure
Yes | Count | 16 | 39 | 55
| % | 29.09% | 70.91% | 100.00%
Suspected | Count | 3 | 4 | 7
| % | 42.86% | 57.14% | 100.00%
No | Count | 140 | 211 | 351
| % | 39.89% | 60.11% | 100.00%
Total | Count | 159 | 254 | 413
| % | 38.50% | 61.50% | 100.00%
Pericarditis
Yes | Count | 2 | 7 | 9
| % | 22.22% | 77.78% | 100.00%
Suspected | Count | | 1 | 1
| % | 0.00% | 100.00% | 100.00%
No | Count | 156 | 243 | 399
| % | 39.10% | 60.90% | 100.00%
Total | Count | 158 | 251 | 409
| % | 38.63% | 61.37% | 100.00%
Pulmonary edema
Yes | Count | 4 | 31 | 35
| % | 11.43% | 88.57% | 100.00%
Suspected | Count | 2 | 4 | 6
| % | 33.33% | 66.67% | 100.00%
No | Count | 152 | 217 | 369
| % | 41.19% | 58.81% | 100.00%
Total | Count | 158 | 252 | 410
| % | 38.54% | 61.46% | 100.00%
Diagnosis of diabetes
Yes | Count | 48 | 109 | 157
| % | 30.57% | 69.43% | 100.00%
Suspected | Count | | 2 | 2
| % | 0.00% | 100.00% | 100.00%
No | Count | 111 | 147 | 258
| % | 43.02% | 56.98% | 100.00%
Total | Count | 159 | 258 | 417
| % | 38.13% | 61.87% | 100.00%
Lung disease
Yes | Count | 2 | 11 | 13
| % | 15.38% | 84.62% | 100.00%
Suspected | Count | 3 | 8 | 11
| % | 27.27% | 72.73% | 100.00%
No | Count | 152 | 234 | 386
| % | 39.38% | 60.62% | 100.00%
Total | Count | 157 | 253 | 410
| % | 38.29% | 61.71% | 100.00%
Neoplasm
Yes | Count | 4 | 13 | 17
| % | 23.53% | 76.47% | 100.00%
Suspected | Count | 1 | 4 | 5
| % | 20.00% | 80.00% | 100.00%
No | Count | 154 | 237 | 391
| % | 39.39% | 60.61% | 100.00%
Total | Count | 159 | 254 | 413
| % | 38.50% | 61.50% | 100.00%
HIV
Yes | Count | 2 | 5 | 7
| % | 28.57% | 71.43% | 100.00%
Suspected | Count | 60 | 102 | 162
| % | 37.04% | 62.96% | 100.00%
No | Count | 66 | 117 | 183
| % | 36.07% | 63.93% | 100.00%
Cannot disclose | Count | 25 | 31 | 56
| % | 44.64% | 55.36% | 100.00%
Total | Count | 153 | 255 | 408
| % | 37.50% | 62.50% | 100.00%
Undernourished
Yes | Count | 10 | 18 | 28
| % | 35.71% | 64.29% | 100.00%
Suspected | Count | 1 | 10 | 11
| % | 9.09% | 90.91% | 100.00%
No | Count | 144 | 226 | 370
| % | 38.92% | 61.08% | 100.00%
Total | Count | 155 | 254 | 409
| % | 37.90% | 62.10% | 100.00%

CHD/CAD Coronary heart disease/coronary artery disease

CABG Coronary artery bypass graft

HIV Human immunodeficiency virus

Table D-2. Categorical disease states by employment statusAppendix D: Descriptive Statistics

Table D-2. Categorical disease states by employment statusAppendix D: Descriptive Statistics

| | Employed or student full time | Employed or student part time | Homemaker | Retired | Never employed | Unemployed | Disabled | Other | Total
Primary cause of disease
Diabetes | Count | 127 | 59 | 87 | 128 | 14 | 110 | 411 | 31 | 967
| % | 13.13% | 6.10% | 9.00% | 13.24% | 1.45% | 11.38% | 42.50% | 3.21% | 100%
Hypertension | Count | 102 | 36 | 30 | 47 | 11 | 89 | 131 | 9 | 455
| % | 22.42% | 7.91% | 6.59% | 10.33% | 2.42% | 19.56% | 28.79% | 1.98% | 100%
Primary glomerulonephritis | Count | 64 | 26 | 13 | 16 | 5 | 32 | 52 | 8 | 216
| % | 29.63% | 12.04% | 6.02% | 7.41% | 2.31% | 14.81% | 24.07% | 3.70% | 100%
Polycystic kidney disease/other | Count | 138 | 36 | 41 | 39 | 13 | 87 | 142 | 10 | 506
| % | 27.27% | 7.11% | 8.10% | 7.71% | 2.57% | 17.19% | 28.06% | 1.98% | 100%
Total | Count | 431 | 157 | 171 | 230 | 43 | 318 | 736 | 58 | 2144
| % | 20.10% | 7.32% | 7.98% | 10.73% | 2.01% | 14.83% | 34.33% | 2.71% | 100%
Coronary artery disease
Yes | Count | 53 | 18 | 34 | 77 | 4 | 43 | 201 | 11 | 441
| % | 12.02% | 4.08% | 7.71% | 17.46% | 0.91% | 9.75% | 45.58% | 2.49% | 100%
Suspected | Count | 13 | 7 | 7 | 18 | 2 | 5 | 30 | | 82
| % | 15.85% | 8.54% | 8.54% | 21.95% | 2.44% | 6.10% | 36.59% | 0.00% | 100%
No | Count | 355 | 130 | 122 | 129 | 36 | 267 | 487 | 42 | 1568
| % | 22.64% | 8.29% | 7.78% | 8.23% | 2.30% | 17.03% | 31.06% | 2.68% | 100%
Total | Count | 421 | 155 | 163 | 224 | 42 | 315 | 718 | 53 | 2091
| % | 20.13% | 7.41% | 7.80% | 10.71% | 2.01% | 15.06% | 34.34% | 2.53% | 100%
Angina
Yes | Count | 31 | 10 | 23 | 46 | 1 | 27 | 122 | 6 | 266
| % | 11.65% | 3.76% | 8.65% | 17.29% | 0.38% | 10.15% | 45.86% | 2.26% | 100%
Suspected | Count | 7 | 2 | 4 | 11 | 3 | 3 | 24 | 1 | 55
| % | 12.73% | 3.64% | 7.27% | 20.00% | 5.45% | 5.45% | 43.64% | 1.82% | 100%
No | Count | 381 | 140 | 137 | 162 | 37 | 285 | 563 | 44 | 1749
| % | 21.78% | 8.00% | 7.83% | 9.26% | 2.12% | 16.30% | 32.19% | 2.52% | 100%
Total | Count | 419 | 152 | 164 | 219 | 41 | 315 | 709 | 51 | 2070
| % | 20.24% | 7.34% | 7.92% | 10.58% | 1.98% | 15.22% | 34.25% | 2.46% | 100%
Myocardial infarct
Yes | Count | 14 | 8 | 13 | 51 | 3 | 16 | 94 | 3 | 202
| % | 6.93% | 3.96% | 6.44% | 25.25% | 1.49% | 7.92% | 46.53% | 1.49% | 100%
Suspected | Count | 7 | 3 | 2 | 7 | | 4 | 23 | 1 | 47
| % | 14.89% | 6.38% | 4.26% | 14.89% | 0.00% | 8.51% | 48.94% | 2.13% | 100%
No | Count | 398 | 143 | 148 | 164 | 39 | 292 | 595 | 49 | 1828
| % | 21.77% | 7.82% | 8.10% | 8.97% | 2.13% | 15.97% | 32.55% | 2.68% | 100%
Total | Count | 419 | 154 | 163 | 222 | 42 | 312 | 712 | 53 | 2077
| % | 20.17% | 7.41% | 7.85% | 10.69% | 2.02% | 15.02% | 34.28% | 2.55% | 100%
CABG
Yes | Count | 13 | 5 | 8 | 23 | | 7 | 58 | 3 | 117
| % | 11.11% | 4.27% | 6.84% | 19.66% | 0.00% | 5.98% | 49.57% | 2.56% | 100%
Suspected | Count | 1 | 1 | 2 | 1 | | 1 | 3 | | 9
| % | 11.11% | 11.11% | 22.22% | 11.11% | 0.00% | 11.11% | 33.33% | 0.00% | 100%
No | Count | 405 | 148 | 153 | 199 | 42 | 306 | 657 | 50 | 1960
| % | 20.66% | 7.55% | 7.81% | 10.15% | 2.14% | 15.61% | 33.52% | 2.55% | 100%
Total | Count | 419 | 154 | 163 | 223 | 42 | 314 | 718 | 53 | 2086
| % | 20.09% | 7.38% | 7.81% | 10.69% | 2.01% | 15.05% | 34.42% | 2.54% | 100%
Angioplasty
Yes | Count | 12 | 3 | 5 | 12 | | 3 | 37 | 2 | 74
| % | 16.22% | 4.05% | 6.76% | 16.22% | 0.00% | 4.05% | 50.00% | 2.70% | 100%
Suspected | Count | 1 | 1 | 2 | 1 | | 1 | 6 | | 12
| % | 8.33% | 8.33% | 16.67% | 8.33% | 0.00% | 8.33% | 50.00% | 0.00% | 100%
No | Count | 406 | 147 | 155 | 207 | 42 | 307 | 662 | 50 | 1976
| % | 20.55% | 7.44% | 7.84% | 10.48% | 2.13% | 15.54% | 33.50% | 2.53% | 100%
Total | Count | 419 | 151 | 162 | 220 | 42 | 311 | 705 | 52 | 2062
| % | 20.32% | 7.32% | 7.86% | 10.67% | 2.04% | 15.08% | 34.19% | 2.52% | 100%
Angiography abnormal
Yes | Count | 23 | 2 | 9 | 22 | | 14 | 57 | 7 | 134
| % | 17.16% | 1.49% | 6.72% | 16.42% | 0.00% | 10.45% | 42.54% | 5.22% | 100%
Suspected | Count | 2 | 2 | 3 | 2 | | | 14 | | 23
| % | 8.70% | 8.70% | 13.04% | 8.70% | 0.00% | 0.00% | 60.87% | 0.00% | 100%
No | Count | 169 | 66 | 72 | 70 | 17 | 139 | 270 | 17 | 820
| % | 20.61% | 8.05% | 8.78% | 8.54% | 2.07% | 16.95% | 32.93% | 2.07% | 100%
Total | Count | 194 | 70 | 84 | 94 | 17 | 153 | 341 | 24 | 977
| % | 19.86% | 7.16% | 8.60% | 9.62% | 1.74% | 15.66% | 34.90% | 2.46% | 100%
Cardiac arrest
Yes | Count | 2 | | 2 | 7 | 1 | 3 | 11 | 1 | 27
| % | 7.41% | 0.00% | 7.41% | 25.93% | 3.70% | 11.11% | 40.74% | 3.70% | 100%
Suspected | Count | 2 | 1 | 2 | 2 | | | 6 | | 13
| % | 15.38% | 7.69% | 15.38% | 15.38% | 0.00% | 0.00% | 46.15% | 0.00% | 100%
No | Count | 409 | 153 | 159 | 213 | 41 | 311 | 698 | 51 | 2035
| % | 20.10% | 7.52% | 7.81% | 10.47% | 2.01% | 15.28% | 34.30% | 2.51% | 100%
Total | Count | 413 | 154 | 163 | 222 | 42 | 314 | 715 | 52 | 2075
| % | 19.90% | 7.42% | 7.86% | 10.70% | 2.02% | 15.13% | 34.46% | 2.51% | 100%
Cerebrovascular disease
Yes | Count | 13 | 4 | 15 | 23 | 3 | 15 | 90 | 1 | 164
| % | 7.93% | 2.44% | 9.15% | 14.02% | 1.83% | 9.15% | 54.88% | 0.61% | 100%
Suspected | Count | 6 | 1 | 4 | 5 | | 3 | 14 | 1 | 34
| % | 17.65% | 2.94% | 11.76% | 14.71% | 0.00% | 8.82% | 41.18% | 2.94% | 100%
No | Count | 402 | 151 | 144 | 199 | 38 | 298 | 621 | 49 | 1902
| % | 21.14% | 7.94% | 7.57% | 10.46% | 2.00% | 15.67% | 32.65% | 2.58% | 100%
Total | Count | 421 | 156 | 163 | 227 | 41 | 316 | 725 | 51 | 2100
| % | 20.05% | 7.43% | 7.76% | 10.81% | 1.95% | 15.05% | 34.52% | 2.43% | 100%
Transient ischemic attack
Yes | Count | 6 | 2 | 3 | 10 | | 1 | 18 | | 40
| % | 15.00% | 5.00% | 7.50% | 25.00% | 0.00% | 2.50% | 45.00% | 0.00% | 100%
Suspected | Count | 6 | 1 | 2 | 7 | | 1 | 14 | | 31
| % | 19.35% | 3.23% | 6.45% | 22.58% | 0.00% | 3.23% | 45.16% | 0.00% | 100%
No | Count | 388 | 138 | 136 | 189 | 38 | 278 | 616 | 48 | 1831
| % | 21.19% | 7.54% | 7.43% | 10.32% | 2.08% | 15.18% | 33.64% | 2.62% | 100%
Total | Count | 400 | 141 | 141 | 206 | 38 | 280 | 648 | 48 | 1902
| % | 21.03% | 7.41% | 7.41% | 10.83% | 2.00% | 14.72% | 34.07% | 2.52% | 100%
Peripheral vascular disease
Yes | Count | 25 | 7 | 20 | 36 | 2 | 32 | 123 | 3 | 248
| % | 10.08% | 2.82% | 8.06% | 14.52% | 0.81% | 12.90% | 49.60% | 1.21% | 100%
Suspected | Count | 7 | 2 | 2 | 8 | | 3 | 24 | 2 | 48
| % | 14.58% | 4.17% | 4.17% | 16.67% | 0.00% | 6.25% | 50.00% | 4.17% | 100%
No | Count | 388 | 144 | 141 | 179 | 41 | 274 | 569 | 47 | 1783
| % | 21.76% | 8.08% | 7.91% | 10.04% | 2.30% | 15.37% | 31.91% | 2.64% | 100%
Total | Count | 420 | 153 | 163 | 223 | 43 | 309 | 716 | 52 | 2079
| % | 20.20% | 7.36% | 7.84% | 10.73% | 2.07% | 14.86% | 34.44% | 2.50% | 100%
Amputation
Yes | Count | 6 | 2 | 9 | 15 | 2 | 15 | 59 | 1 | 109
| % | 5.50% | 1.83% | 8.26% | 13.76% | 1.83% | 13.76% | 54.13% | 0.92% | 100%
Suspected | Count | 1 | 1 | 2 | 1 | | | 2 | | 7
| % | 14.29% | 14.29% | 28.57% | 14.29% | 0.00% | 0.00% | 28.57% | 0.00% | 100%
No | Count | 415 | 151 | 152 | 208 | 41 | 298 | 661 | 51 | 1977
| % | 20.99% | 7.64% | 7.69% | 10.52% | 2.07% | 15.07% | 33.43% | 2.58% | 100%
Total | Count | 422 | 154 | 163 | 224 | 43 | 313 | 722 | 52 | 2093
| % | 20.16% | 7.36% | 7.79% | 10.70% | 2.05% | 14.95% | 34.50% | 2.48% | 100%
Limb amputated
Yes | Count | 6 | 1 | 4 | 11 | 1 | 6 | 43 | 1 | 73
| % | 8.22% | 1.37% | 5.48% | 15.07% | 1.37% | 8.22% | 58.90% | 1.37% | 100%
Suspected | Count | 1 | 1 | 3 | 1 | | | 3 | | 9
| % | 11.11% | 11.11% | 33.33% | 11.11% | 0.00% | 0.00% | 33.33% | 0.00% | 100%
No | Count | 415 | 152 | 156 | 211 | 42 | 306 | 677 | 51 | 2010
| % | 20.65% | 7.56% | 7.76% | 10.50% | 2.09% | 15.22% | 33.68% | 2.54% | 100%
Total | Count | 422 | 154 | 163 | 223 | 43 | 312 | 723 | 52 | 2092
| % | 20.17% | 7.36% | 7.79% | 10.66% | 2.06% | 14.91% | 34.56% | 2.49% | 100%
Absent foot pulse
Yes | Count | 4 | 1 | 5 | 8 | | 6 | 39 | 1 | 64
| % | 6.25% | 1.56% | 7.81% | 12.50% | 0.00% | 9.38% | 60.94% | 1.56% | 100%
Suspected | Count | 5 | 2 | 3 | 3 | | 4 | 13 | 1 | 31
| % | 16.13% | 6.45% | 9.68% | 9.68% | 0.00% | 12.90% | 41.94% | 3.23% | 100%
No | Count | 411 | 148 | 153 | 211 | 43 | 300 | 647 | 49 | 1962
| % | 20.95% | 7.54% | 7.80% | 10.75% | 2.19% | 15.29% | 32.98% | 2.50% | 100%
Total | Count | 420 | 151 | 161 | 222 | 43 | 310 | 699 | 51 | 2057
| % | 20.42% | 7.34% | 7.83% | 10.79% | 2.09% | 15.07% | 33.98% | 2.48% | 100%
Claudication
Yes | Count | 7 | 2 | 2 | 10 | | 5 | 33 | 2 | 61
| % | 11.48% | 3.28% | 3.28% | 16.39% | 0.00% | 8.20% | 54.10% | 3.28% | 100%
Suspected | Count | 4 | 1 | 3 | 4 | 1 | 4 | 10 | | 27
| % | 14.81% | 3.70% | 11.11% | 14.81% | 3.70% | 14.81% | 37.04% | 0.00% | 100%
No | Count | 407 | 150 | 155 | 204 | 41 | 298 | 655 | 49 | 1959
| % | 20.78% | 7.66% | 7.91% | 10.41% | 2.09% | 15.21% | 33.44% | 2.50% | 100%
Total | Count | 418 | 153 | 160 | 218 | 42 | 307 | 698 | 51 | 2047
| % | 20.42% | 7.47% | 7.82% | 10.65% | 2.05% | 15.00% | 34.10% | 2.49% | 100%
Congestive heart failure
Yes | Count | 44 | 31 | 47 | 75 | 11 | 57 | 228 | 13 | 506
| % | 8.70% | 6.13% | 9.29% | 14.82% | 2.17% | 11.26% | 45.06% | 2.57% | 100%
Suspected | Count | 8 | 4 | 2 | 9 | | 3 | 19 | 1 | 46
| % | 17.39% | 8.70% | 4.35% | 19.57% | 0.00% | 6.52% | 41.30% | 2.17% | 100%
No | Count | 372 | 117 | 113 | 134 | 32 | 254 | 470 | 39 | 1531
| % | 24.30% | 7.64% | 7.38% | 8.75% | 2.09% | 16.59% | 30.70% | 2.55% | 100%
Total | Count | 424 | 152 | 162 | 218 | 43 | 314 | 717 | 53 | 2083
| % | 20.36% | 7.30% | 7.78% | 10.47% | 2.06% | 15.07% | 34.42% | 2.54% | 100%
Pericarditis
Yes | Count | 10 | 5 | 7 | 7 | 1 | 5 | 18 | | 53
| % | 18.87% | 9.43% | 13.21% | 13.21% | 1.89% | 9.43% | 33.96% | 0.00% | 100%
Suspected | Count | 1 | 1 | 1 | 3 | 2 | | 1 | | 9
| % | 11.11% | 11.11% | 11.11% | 33.33% | 22.22% | 0.00% | 11.11% | 0.00% | 100%
No | Count | 410 | 145 | 152 | 202 | 39 | 309 | 683 | 52 | 1992
| % | 20.58% | 7.28% | 7.63% | 10.14% | 1.96% | 15.51% | 34.29% | 2.61% | 100%
Total | Count | 421 | 151 | 160 | 212 | 42 | 314 | 702 | 52 | 2054
| % | 20.50% | 7.35% | 7.79% | 10.32% | 2.04% | 15.29% | 34.18% | 2.53% | 100%
Pulmonary edema
Yes | Count | 31 | 17 | 33 | 35 | 4 | 37 | 124 | 6 | 287
| % | 10.80% | 5.92% | 11.50% | 12.20% | 1.39% | 12.89% | 43.21% | 2.09% | 100%
Suspected | Count | 6 | 3 | 2 | 11 | 1 | 5 | 26 | | 54
| % | 11.11% | 5.56% | 3.70% | 20.37% | 1.85% | 9.26% | 48.15% | 0.00% | 100%
No | Count | 386 | 131 | 125 | 168 | 37 | 270 | 551 | 44 | 1712
| % | 22.55% | 7.65% | 7.30% | 9.81% | 2.16% | 15.77% | 32.18% | 2.57% | 100%
Total | Count | 423 | 151 | 160 | 214 | 42 | 312 | 701 | 50 | 2053
| % | 20.60% | 7.36% | 7.79% | 10.42% | 2.05% | 15.20% | 34.15% | 2.44% | 100%
Diagnosis of diabetes
Yes | Count | 131 | 64 | 89 | 147 | 16 | 123 | 437 | 31 | 1038
| % | 12.62% | 6.17% | 8.57% | 14.16% | 1.54% | 11.85% | 42.10% | 2.99% | 100%
Suspected | Count | 3 | 1 | | | | 1 | 6 | | 11
| % | 27.27% | 9.09% | 0.00% | 0.00% | 0.00% | 9.09% | 54.55% | 0.00% | 100%
No | Count | 296 | 91 | 76 | 80 | 26 | 197 | 286 | 24 | 1076
| % | 27.51% | 8.46% | 7.06% | 7.43% | 2.42% | 18.31% | 26.58% | 2.23% | 100%
Total | Count | 430 | 156 | 165 | 227 | 42 | 321 | 729 | 55 | 2125
| % | 20.24% | 7.34% | 7.76% | 10.68% | 1.98% | 15.11% | 34.31% | 2.59% | 100%
Lung disease
Yes | Count | 5 | 5 | 7 | 18 | 2 | 8 | 55 | 1 | 101
| % | 4.95% | 4.95% | 6.93% | 17.82% | 1.98% | 7.92% | 54.46% | 0.99% | 100%
Suspected | Count | 9 | | 1 | 8 | 1 | 8 | 21 | 2 | 50
| % | 18.00% | 0.00% | 2.00% | 16.00% | 2.00% | 16.00% | 42.00% | 4.00% | 100%
No | Count | 405 | 148 | 161 | 195 | 40 | 294 | 643 | 51 | 1937
| % | 20.91% | 7.64% | 8.31% | 10.07% | 2.07% | 15.18% | 33.20% | 2.63% | 100%
Total | Count | 419 | 153 | 169 | 221 | 43 | 310 | 719 | 54 | 2088
| % | 20.07% | 7.33% | 8.09% | 10.58% | 2.06% | 14.85% | 34.43% | 2.59% | 100%
Neoplasm
Yes | Count | 25 | 2 | 7 | 17 | 1 | 7 | 49 | 2 | 110
| % | 22.73% | 1.82% | 6.36% | 15.45% | 0.91% | 6.36% | 44.55% | 1.82% | 100%
Suspected | Count | 4 | | 3 | 3 | | 4 | 5 | 1 | 20
| % | 20.00% | 0.00% | 15.00% | 15.00% | 0.00% | 20.00% | 25.00% | 5.00% | 100%
No | Count | 392 | 153 | 157 | 199 | 42 | 300 | 669 | 50 | 1962
| % | 19.98% | 7.80% | 8.00% | 10.14% | 2.14% | 15.29% | 34.10% | 2.55% | 100%
Total | Count | 421 | 155 | 167 | 219 | 43 | 311 | 723 | 53 | 2092
| % | 20.12% | 7.41% | 7.98% | 10.47% | 2.06% | 14.87% | 34.56% | 2.53% | 100%
HIV
Positive | Count | 8 | 1 | | | 1 | 15 | 18 | 1 | 44
| % | 18.18% | 2.27% | 0.00% | 0.00% | 2.27% | 34.09% | 40.91% | 2.27% | 100%
Negative | Count | 172 | 59 | 56 | 71 | 17 | 118 | 250 | 21 | 764
| % | 22.51% | 7.72% | 7.33% | 9.29% | 2.23% | 15.45% | 32.72% | 2.75% | 100%
Unknown | Count | 187 | 70 | 95 | 131 | 18 | 152 | 345 | 22 | 1020
| % | 18.33% | 6.86% | 9.31% | 12.84% | 1.76% | 14.90% | 33.82% | 2.16% | 100%
Can't disclose | Count | 50 | 17 | 16 | 20 | 4 | 34 | 97 | 12 | 250
| % | 20.00% | 6.80% | 6.40% | 8.00% | 1.60% | 13.60% | 38.80% | 4.80% | 100%
Total | Count | 417 | 147 | 167 | 222 | 40 | 319 | 710 | 56 | 2078
| % | 20.07% | 7.07% | 8.04% | 10.68% | 1.92% | 15.35% | 34.17% | 2.69% | 100%
Undernourished
Yes | Count | 36 | 4 | 16 | 14 | 5 | 36 | 109 | 3 | 223
| % | 16.14% | 1.79% | 7.17% | 6.28% | 2.24% | 16.14% | 48.88% | 1.35% | 100%
Suspected | Count | 13 | 4 | 6 | 19 | 1 | 16 | 47 | 1 | 107
| % | 12.15% | 3.74% | 5.61% | 17.76% | 0.93% | 14.95% | 43.93% | 0.93% | 100%
No | Count | 368 | 145 | 144 | 192 | 35 | 259 | 569 | 53 | 1765
| % | 20.85% | 8.22% | 8.16% | 10.88% | 1.98% | 14.67% | 32.24% | 3.00% | 100%
Total | Count | 417 | 153 | 166 | 225 | 41 | 311 | 725 | 57 | 2095
| % | 19.90% | 7.30% | 7.92% | 10.74% | 1.96% | 14.84% | 34.61% | 2.72% | 100%
Patient status
Alive | Count | 349 | 130 | 135 | 179 | 33 | 236 | 558 | 42 | 1662
| % | 21.00% | 7.82% | 8.12% | 10.77% | 1.99% | 14.20% | 33.57% | 2.53% | 100%
Dead | Count | 13 | 4 | 14 | 23 | 2 | 23 | 87 | 6 | 172
| % | 7.56% | 2.33% | 8.14% | 13.37% | 1.16% | 13.37% | 50.58% | 3.49% | 100%
Lost to followup | Count | 21 | 5 | 6 | 6 | 3 | 19 | 37 | 1 | 98
| % | 21.43% | 5.10% | 6.12% | 6.12% | 3.06% | 19.39% | 37.76% | 1.02% | 100%
Total | Count | 383 | 139 | 155 | 208 | 38 | 278 | 682 | 49 | 1932
| % | 19.82% | 7.19% | 8.02% | 10.77% | 1.97% | 14.39% | 35.30% | 2.54% | 100%

CABG Coronary artery bypass graft

HIV Human immunodeficiency virus

Table D-3. Work status: descriptive statistics of symptoms and laboratory valuesAppendix D: Descriptive Statistics

Table D-3. Work status: descriptive statistics of symptoms and laboratory valuesAppendix D: Descriptive Statistics

Variables | Do not continue working | | Continue working | | Total
| N | Mean | N | Mean | N | Mean
Age | 262 | 47.03 | 160 | 43.97 | 422 | 45.87
Dialysate urea | 87 | 48.8 | 83 | 47.98 | 170 | 48.4
Dialysate creatinine | 88 | 6.06 | 83 | 6.29 | 171 | 6.17
Blood urea nitrogen (BUN) at start date | 92 | 49.78 | 82 | 57.07 | 174 | 53.21
Serum creatinine | 92 | 8.00 | 84 | 9.58 | 176 | 8.754
Serum calcium | 246 | 8.79 | 156 | 8.84 | 402 | 8.81
Phosphorus | 247 | 5.79 | 156 | 6.0782 | 403 | 5.9
Serum bicarbonate | 239 | 21.3611 | 149 | 22.455 | 388 | 21.78
Hematocrit | 253 | 30.0818 | 158 | 30.457 | 411 | 30.226
Hemoglobin | 248 | 10.3137 | 148 | 11.41 | 396 | 10.73
Creatinine before first reg dialysis | 255 | 9.21 | 158 | 11.33 | 413 | 10.02
Creatinine at day 60 of dialysis | 251 | 8.7948 | 155 | 9.8619 | 406 | 9.2022
BUN before start date | 256 | 86.59 | 158 | 92.19 | 414 | 88.73
Predialysis BUN | 211 | 57.13 | 122 | 62.41 | 333 | 59.07
Postdialysis BUN | 127 | 26.32 | 62 | 41.85 | 189 | 31.42
Predialysis weight | 194 | 174.25 | 112 | 175.57 | 306 | 174.73
Postdialysis weight | 127 | 171.18 | 61 | 176.71 | 188 | 172.97
Serum albumin | 235 | 3.61 | 147 | 3.71 | 382 | 3.65
Cholesterol | 242 | 199.33 | 149 | 194.66 | 391 | 197.55
High-density liproproteins (HDL) cholesterol | 64 | 58.91 | 31 | 39.16 | 95 | 52.46
LDL cholesterol | 74 | 162.74 | 30 | 144.2 | 104 | 157.39
Triglycerides | 201 | 208.09 | 131 | 210.96 | 332 | 209.22
Serum parathyroid hormone (PTH) | 218 | 319.87 | 131 | 474.6 | 349 | 377.95
Serum aluminum | 158 | 35.72 | 96 | 11.74 | 254 | 26.65
Urine creatinine | 92 | 126.04 | 68 | 273.54 | 160 | 188.73
Urine urea nitrogen | 87 | 325.78 | 70 | 538.03 | 157 | 420.41
Creatinine before urine collection | 82 | 7.91 | 54 | 8.47 | 136 | 8.13
BUN before urine collection | 85 | 55.41 | 57 | 54.7 | 142 | 55.13
Creatinine after urine collection | 32 | 7.7 | 26 | 8.41 | 58 | 8.02
BUN after urine collection | 48 | 41.38 | 30 | 86.23 | 78 | 58.63
Predialysis BUN at followup | 248 | 55.11 | 147 | 58.79 | 395 | 56.48
Predialysis weight at followup | 243 | 120.24 | 145 | 133.48 | 388 | 125.19
Postdialysis BUN at followup | 126 | 21.13 | 51 | 25.51 | 177 | 22.39
Postdialysis weight at followup | 128 | 97.35 | 56 | 99.96 | 184 | 98.15
Urine creatinine at followup | 76 | 107.7 | 55 | 124.09 | 131 | 114.58
Urine urea nitrogen at followup | 86 | 281.01 | 63 | 245.83 | 149 | 266.13
Serum creatinine at start of followup urine collection | 79 | 8.63 | 62 | 9.9 | 141 | 9.18
BUN at start of followup urine collection | 84 | 60.74 | 63 | 57.6 | 147 | 59.39
Median predialysis systolic blood pressure | 256 | 146.8164 | 155 | 146.7677 | 411 | 146.7981
Median predialysis diastolic blood pressure | 259 | 84.2162 | 155 | 86.129 | 414 | 84.9324
Median postdialysis systolic blood pressure | 119 | 142.0966 | 44 | 145.1818 | 163 | 142.9294
Median postdialysis diastolic blood pressure | 119 | 79.6975 | 44 | 82.8182 | 163 | 80.5399
Dry body mass index (BMI) | 219 | 26.5195 | 127 | 27.5954 | 346 | 26.9144
Predialysis BMI | 168 | 27.3117 | 89 | 28.1067 | 257 | 27.587
Postdialysis BMI | 107 | 26.566 | 44 | 28.6421 | 151 | 27.171
Median predialysis weight | 256 | 170.1039 | 154 | 177.7486 | 410 | 172.9753
Median postdialysis weight | 119 | 171.8538 | 44 | 178.7986 | 163 | 173.7285

Table D-4. Comparison of KDQOLTM subscales based on employment statusAppendix D: Descriptive Statistics

Table D-4. Comparison of KDQOLTM subscales based on employment statusAppendix D: Descriptive Statistics

Variables | Do not continue working | | Continue working | | Total
| N | Median | N | Median | N | Median
Symptoms | 190 | 900 | 126 | 975 | 316 | 925
Symptoms at followup | 215 | 900 | 141 | 975 | 356 | 925
Effects of kidney disease | 209 | 450 | 127 | 500 | 336 | 475
Effects of kidney disease at followup | 232 | 450 | 150 | 550 | 382 | 475
Burden of kidney disease | 216 | 150 | 133 | 200 | 349 | 175
Burden of kidney disease at followup | 250 | 150 | 157 | 250 | 407 | 175
Ability to work | 186 | 0 | 75 | 150 | 261 | 0
Work ability at followup | 222 | 0 | 103 | 150 | 325 | 0
Sleep | 212 | 160 | 136 | 240 | 348 | 180
Sleep at followup | 254 | 150 | 158 | 220 | 412 | 160
Social support | 220 | 150 | 137 | 150 | 357 | 150
Social support at followup | 258 | 150 | 160 | 150 | 418 | 150
Dialysis staff encouragement | 218 | 200 | 136 | 200 | 354 | 200
Dialysis staff encouragement at followup | 255 | 175 | 157 | 200 | 412 | 200
Physical functioning | 190 | 500 | 127 | 800 | 317 | 650
Physical functioning at followup | 232 | 500 | 152 | 800 | 384 | 600
Role -- physical | 214 | 0 | 135 | 200 | 349 | 0
Role -- physical at followup | 242 | 0 | 154 | 300 | 396 | 100
Pain | 216 | 135 | 136 | 145 | 352 | 135
Pain at followup | 247 | 130 | 156 | 155 | 403 | 135
General health | 205 | 200 | 129 | 250 | 334 | 225
General health at followup | 246 | 200 | 153 | 250 | 399 | 225
Emotional well-being | 211 | 360 | 130 | 380 | 341 | 360
Emotional well-being at followup | 243 | 340 | 152 | 380 | 395 | 360
Role -- emotional | 213 | 200 | 133 | 300 | 346 | 200
Role -- emotional at followup | 242 | 200 | 156 | 300 | 398 | 300
Social functioning | 216 | 125 | 134 | 150 | 350 | 125
Social functioning at followup | 251 | 125 | 157 | 150 | 408 | 150
Cognitive functioning | 214 | 240 | 134 | 260 | 348 | 260
Cognitive functioning at followup | 249 | 240 | 155 | 260 | 404 | 260
Sexual functioning | 200 | 125 | 129 | 150 | 329 | 150
Sexual functioning at followup | 234 | 100 | 146 | 175 | 380 | 125
Quality of social interaction | 217 | 220 | 135 | 240 | 352 | 220
Quality of social interaction at followup | 251 | 220 | 157 | 240 | 408 | 220
Energy/fatigue | 215 | 200 | 127 | 220 | 342 | 200
Energy/fatigue at followup | 235 | 180 | 150 | 220 | 385 | 200

Table D-5. Employment status at study start date by laboratory variablesAppendix D: Descriptive Statistics

Table D-5. Employment status at study start date by laboratory variablesAppendix D: Descriptive Statistics

Laboratory variables | Employed or student full time | | Employed or student part time | | Homemaker | | Retired | | Never employed | | Unemployed | | Disabled | | Other
| N | Mean | N | Mean | N | Mean | N | Mean | N | Mean | N | Mean | N | Mean | N | Mean
Dialysate urea | 193 | 48.78 | 66 | 50.43 | 43 | 41.54 | 60 | 54.62 | 6 | 40.50 | 72 | 48.17 | 193 | 51.30 | 23 | 44.65
Dialysate creatinine | 191 | 6.24 | 66 | 6.26 | 42 | 5.37 | 60 | 6.33 | 6 | 13.00 | 71 | 5.67 | 190 | 5.51 | 23 | 8.80
Serum calcium | 414 | 8.87 | 155 | 8.79 | 162 | 8.64 | 223 | 8.68 | 43 | 8.50 | 304 | 9.00 | 712 | 8.75 | 54 | 8.38
Serum phosphorus | 412 | 6.21 | 155 | 5.73 | 161 | 5.96 | 222 | 5.74 | 43 | 6.73 | 304 | 6.29 | 712 | 5.79 | 54 | 6.12
Serum bicarbonate | 393 | 22.21 | 146 | 22.14 | 159 | 21.61 | 217 | 22.40 | 42 | 20.78 | 293 | 20.71 | 663 | 22.40 | 53 | 22.10
Hematocrit | 423 | 30.51 | 153 | 30.00 | 164 | 30.59 | 224 | 30.76 | 43 | 28.87 | 309 | 29.69 | 716 | 30.23 | 54 | 31.09
Hemoglobin | 403 | 10.94 | 150 | 10.53 | 161 | 11.32 | 220 | 10.53 | 43 | 9.55 | 303 | 10.39 | 697 | 10.49 | 54 | 10.65
Predialysis BUN | 331 | 59.69 | 125 | 56.67 | 138 | 52.70 | 177 | 58.86 | 38 | 53.39 | 269 | 61.85 | 635 | 57.95 | 49 | 52.61
Postdialysis BUN | 165 | 39.17 | 63 | 32.02 | 95 | 24.41 | 131 | 27.08 | 28 | 18.75 | 192 | 26.39 | 428 | 26.66 | 23 | 29.35
Predialysis weight | 283 | 167.66 | 112 | 174.84 | 124 | 153.78 | 163 | 175.53 | 33 | 169.42 | 239 | 168.83 | 565 | 175.43 | 40 | 174.92
Pos-dialysis weight | 156 | 168.21 | 65 | 171.93 | 97 | 145.21 | 128 | 170.78 | 26 | 167.48 | 182 | 164.81 | 411 | 169.87 | 20 | 184.76
Serum albumin | 383 | 3.62 | 144 | 3.64 | 158 | 3.42 | 208 | 3.46 | 40 | 3.40 | 292 | 3.50 | 682 | 3.41 | 48 | 3.51
Cholesterol | 403 | 198.22 | 143 | 199.51 | 152 | 206.36 | 204 | 197.94 | 37 | 183.76 | 280 | 193.61 | 686 | 197.72 | 51 | 205.41
HDL cholesterol | 92 | 58.07 | 27 | 78.04 | 28 | 50.54 | 33 | 71.15 | 7 | 37.71 | 68 | 58.97 | 139 | 52.26 | 13 | 69.46
LDL cholesterol | 87 | 140.24 | 30 | 155.87 | 30 | 142.47 | 33 | 176.61 | 6 | 228.00 | 61 | 157.02 | 133 | 148.74 | 10 | 135.90
Triglycerides | 347 | 215.33 | 121 | 196.21 | 136 | 212.60 | 173 | 208.26 | 31 | 190.32 | 245 | 195.48 | 583 | 197.96 | 42 | 176.57
Serum intact PTH | 350 | 402.35 | 132 | 389.20 | 132 | 379.73 | 189 | 324.25 | 35 | 336.09 | 243 | 383.56 | 572 | 297.24 | 50 | 284.88
Serum aluminum | 228 | 12.44 | 93 | 13.06 | 90 | 11.14 | 144 | 26.96 | 23 | 5.74 | 199 | 19.84 | 409 | 12.57 | 33 | 6.48
Urine creatinine | 168 | 166.61 | 57 | 232.56 | 56 | 250.23 | 65 | 186.12 | 8 | 116.63 | 78 | 191.87 | 223 | 164.64 | 23 | 110.87
Urine urea nitrogen | 167 | 389.31 | 55 | 251.98 | 45 | 278.98 | 63 | 284.10 | 7 | 248.00 | 73 | 357.34 | 215 | 321.60 | 20 | 264.10
Predialysis creatinine | 142 | 8.51 | 49 | 9.30 | 47 | 7.21 | 58 | 7.64 | 6 | 8.13 | 75 | 9.20 | 190 | 7.36 | 19 | 6.62
Predialysis BUN2 | 143 | 61.92 | 51 | 56.98 | 45 | 53.18 | 62 | 59.52 | 8 | 58.25 | 77 | 61.87 | 197 | 56.92 | 21 | 51.38
Postdialysis creatinine | 55 | 9.17 | 16 | 7.94 | 26 | 6.15 | 29 | 6.62 | 4 | 7.95 | 28 | 7.65 | 85 | 6.74 | 3 | 12.47
Postdialysis BUN2 | 63 | 48.17 | 22 | 70.73 | 28 | 39.75 | 39 | 41.77 | 5 | 36.00 | 40 | 38.80 | 116 | 41.79 | 7 | 40.29
Median predialysis systolic BP | 426 | 146.43 | 150 | 148.11 | 164 | 147.37 | 229 | 145.38 | 43 | 146.16 | 310 | 144.62 | 715 | 146.12 | 56 | 146.39
Median predialysis diastolic BP | 424 | 85.32 | 156 | 84.13 | 163 | 80.89 | 229 | 79.21 | 42 | 83.81 | 316 | 83.40 | 732 | 82.86 | 57 | 84.82
Median postdialysis systolic BP | 110 | 143.27 | 55 | 143.82 | 82 | 141.18 | 119 | 144.80 | 28 | 144.79 | 191 | 141.72 | 408 | 141.05 | 18 | 144.06
Median postdialysis diastolic BP | 110 | 82.29 | 55 | 78.83 | 82 | 75.72 | 120 | 76.57 | 28 | 80.07 | 191 | 80.94 | 408 | 78.09 | 18 | 83.67
Dry BMI | 333 | 26.95 | 117 | 27.38 | 132 | 26.67 | 184 | 26.88 | 31 | 25.88 | 255 | 27.21 | 582 | 26.95 | 40 | 28.22
Predialysis BMI | 222 | 26.60 | 84 | 28.13 | 92 | 27.30 | 131 | 27.50 | 22 | 27.72 | 186 | 28.12 | 447 | 28.06 | 27 | 28.20
Postdialysis BMI | 119 | 26.40 | 48 | 27.29 | 73 | 26.10 | 102 | 26.26 | 18 | 26.94 | 140 | 27.23 | 331 | 27.30 | 13 | 32.28
Median predialysis weight | 418 | 170.87 | 155 | 170.09 | 163 | 151.59 | 226 | 171.46 | 42 | 160.06 | 313 | 166.68 | 725 | 173.02 | 57 | 181.34
Median postdialysis weight | 110 | 166.62 | 54 | 175.24 | 82 | 144.10 | 117 | 164.76 | 28 | 162.55 | 191 | 163.68 | 408 | 169.32 | 18 | 200.55
Predialysis GFR | 365 | 3.06 | 138 | 3.18 | 142 | 3.43 | 196 | 3.63 | 39 | 4.34 | 269 | 3.40 | 649 | 3.83 | 47 | 3.37

PTH = Parathyroid hormone

BP = Blood pressure

GFR = Glomerular filtration rate

BUN = Blood urea nitrogen

BMI = Body mass index

HDL = High-density lipoproteins

LDL = Low-density lipoproteins

Table D-6. Demographic and employment categorical variablesAppendix D: Descriptive Statistics

Table D-6. Demographic and employment categorical variablesAppendix D: Descriptive Statistics

| | Employed or student full time | Employed or student part time | Homemaker | Retired | Never employed | Unemployed | Disabled | Other | Total
Ethnicity
Hispanic origin | Count | 42 | 13 | 23 | 19 | 5 | 44 | 77 | 3 | 226
| % | 18.58% | 5.75% | 10.18% | 8.41% | 2.21% | 19.47% | 34.07% | 1.33% | 100%
Non-Hispanic | Count | 383 | 143 | 147 | 209 | 38 | 273 | 653 | 53 | 1899
| % | 20.17% | 7.53% | 7.74% | 11.01% | 2.00% | 14.38% | 34.39% | 2.79% | 100%
Total | Count | 425 | 156 | 170 | 228 | 43 | 317 | 730 | 56 | 2125
| % | 20.00% | 7.34% | 8.00% | 10.73% | 2.02% | 14.92% | 34.35% | 2.64% | 100%
Race
Caucasian | Count | 268 | 95 | 89 | 137 | 18 | 149 | 433 | 35 | 1224
| % | 21.90% | 7.76% | 7.27% | 11.19% | 1.47% | 12.17% | 35.38% | 2.86% | 100%
African/Carribean descent | Count | 121 | 44 | 57 | 74 | 19 | 145 | 252 | 20 | 732
| % | 16.53% | 6.01% | 7.79% | 10.11% | 2.60% | 19.81% | 34.43% | 2.73% | 100%
Asian | Count | 12 | 6 | 9 | 5 | 3 | 11 | 13 | 1 | 60
| % | 20.00% | 10.00% | 15.00% | 8.33% | 5.00% | 18.33% | 21.67% | 1.67% | 100%
Native American | Count | 6 | 2 | 3 | 3 | 2 | 5 | 8 | | 29
| % | 20.69% | 6.90% | 10.34% | 10.34% | 6.90% | 17.24% | 27.59% | 0.00% | 100%
Other | Count | 23 | 10 | 13 | 11 | 1 | 12 | 31 | 1 | 102
| % | 22.55% | 9.80% | 12.75% | 10.78% | 0.98% | 11.76% | 30.39% | 0.98% | 100%
Total | Count | 430 | 157 | 171 | 230 | 43 | 322 | 737 | 57 | 2147
| % | 20.03% | 7.31% | 7.96% | 10.71% | 2.00% | 15.00% | 34.33% | 2.65% | 100%
Smoking status
Active | Count | 58 | 12 | 23 | 38 | 11 | 74 | 148 | 11 | 375
| % | 15.47% | 3.20% | 6.13% | 10.13% | 2.93% | 19.73% | 39.47% | 2.93% | 100%
Former, <1 yr | Count | 16 | 7 | 7 | 14 | | 23 | 39 | 3 | 109
| % | 14.68% | 6.42% | 6.42% | 12.84% | 0.00% | 21.10% | 35.78% | 2.75% | 100%
Former, >1 yr | Count | 45 | 12 | 20 | 43 | 4 | 39 | 129 | 12 | 304
| % | 14.80% | 3.95% | 6.58% | 14.14% | 1.32% | 12.83% | 42.43% | 3.95% | 100%
Smoker, status unknown | Count | 10 | 3 | 1 | 9 | 2 | 20 | 27 | 2 | 74
| % | 13.51% | 4.05% | 1.35% | 12.16% | 2.70% | 27.03% | 36.49% | 2.70% | 100%
Nonsmoker | Count | 270 | 112 | 107 | 112 | 24 | 152 | 337 | 26 | 1140
| % | 23.68% | 9.82% | 9.39% | 9.82% | 2.11% | 13.33% | 29.56% | 2.28% | 100%
Total | Count | 399 | 146 | 158 | 216 | 41 | 308 | 680 | 54 | 2002
| % | 19.93% | 7.29% | 7.89% | 10.79% | 2.05% | 15.38% | 33.97% | 2.70% | 100%
Living alone?
Yes | Count | 79 | 27 | 11 | 34 | 7 | 47 | 119 | 2 | 326
| % | 24.23% | 8.28% | 3.37% | 10.43% | 2.15% | 14.42% | 36.50% | 0.61% | 100%
No | Count | 354 | 129 | 159 | 197 | 33 | 261 | 586 | 54 | 1773
| % | 19.97% | 7.28% | 8.97% | 11.11% | 1.86% | 14.72% | 33.05% | 3.05% | 100%
Nursing home/institution | Count | 1 | 1 | 1 | 1 | 1 | 12 | 31 | 1 | 49
| % | 2.04% | 2.04% | 2.04% | 2.04% | 2.04% | 24.49% | 63.27% | 2.04% | 100%
Homeless | Count | | | | | | 1 | 3 | 1 | 5
| % | | | | | | 20.00% | 60.00% | 20.00% | 100%
Total | Count | 434 | 157 | 171 | 232 | 41 | 321 | 739 | 58 | 2153
| % | 20.16% | 7.29% | 7.94% | 10.78% | 1.90% | 14.91% | 34.32% | 2.69% | 100%
Education
Less than 12 years | Count | 43 | 22 | 54 | 50 | 19 | 123 | 235 | 8 | 554
| % | 7.76% | 3.97% | 9.75% | 9.03% | 3.43% | 22.20% | 42.42% | 1.44% | 100%
High school grad | Count | 112 | 51 | 80 | 78 | 16 | 119 | 255 | 18 | 729
| % | 15.36% | 7.00% | 10.97% | 10.70% | 2.19% | 16.32% | 34.98% | 2.47% | 100%
Some college | Count | 106 | 44 | 23 | 49 | 4 | 44 | 126 | 16 | 412
| % | 25.73% | 10.68% | 5.58% | 11.89% | 0.97% | 10.68% | 30.58% | 3.88% | 100%
College grad | Count | 144 | 31 | 5 | 35 | | 17 | 66 | 11 | 309
| % | 46.60% | 10.03% | 1.62% | 11.33% | 0.00% | 5.50% | 21.36% | 3.56% | 100%
Total | Count | 405 | 148 | 162 | 212 | 39 | 303 | 682 | 53 | 2004
| % | 20.21% | 7.39% | 8.08% | 10.58% | 1.95% | 15.12% | 34.03% | 2.64% | 100%
Occupation
Professional | Count | 156 | 42 | 4 | 51 | | 19 | 83 | 10 | 365
| % | 42.74% | 11.51% | 1.10% | 13.97% | 0.00% | 5.21% | 22.74% | 2.74% | 100%
Clerical | Count | 65 | 19 | 6 | 25 | | 26 | 60 | 7 | 208
| % | 31.25% | 9.13% | 2.88% | 12.02% | 0.00% | 12.50% | 28.85% | 3.37% | 100%
Student | Count | 24 | 9 | | | 4 | 6 | 5 | 3 | 51
| % | 47.06% | 17.65% | 0.00% | 0.00% | 7.84% | 11.76% | 9.80% | 5.88% | 100%
Tradesperson | Count | 65 | 23 | 4 | 36 | | 42 | 82 | 8 | 260
| % | 25.00% | 8.85% | 1.54% | 13.85% | 0.00% | 16.15% | 31.54% | 3.08% | 100%
Manual labor | Count | 50 | 28 | 3 | 48 | 1 | 106 | 199 | 7 | 442
| % | 11.31% | 6.33% | 0.68% | 10.86% | 0.23% | 23.98% | 45.02% | 1.58% | 100%
Other | Count | 70 | 27 | 6 | 55 | 1 | 51 | 76 | 19 | 305
| % | 22.95% | 8.85% | 1.97% | 18.03% | 0.33% | 16.72% | 24.92% | 6.23% | 100%
Not employed | Count | 2 | 3 | 13 | 7 | 21 | 44 | 17 | 1 | 108
| % | 1.85% | 2.78% | 12.04% | 6.48% | 19.44% | 40.74% | 15.74% | 0.93% | 100%
Homemaker | Count | | 4 | 132 | 4 | 11 | 13 | 22 | 2 | 188
| % | 0.00% | 2.13% | 70.21% | 2.13% | 5.85% | 6.91% | 11.70% | 1.06% | 100%
Disabled | Count | 1 | 1 | 2 | 1 | 4 | 6 | 180 | | 195
| % | 0.51% | 0.51% | 1.03% | 0.51% | 2.05% | 3.08% | 92.31% | 0.00% | 100%
Total | Count | 433 | 156 | 170 | 227 | 42 | 313 | 724 | 57 | 2122
| % | 20.41% | 7.35% | 8.01% | 10.70% | 1.98% | 14.75% | 34.12% | 2.69% | 100%
Employed 24 to 6 mos before dialysis
Employed or student full time | Count | 426 | 65 | 3 | 40 | | 107 | 216 | 29 | 886
| % | 48.08% | 7.34% | 0.34% | 4.51% | 0.00% | 12.08% | 24.38% | 3.27% | 100%
Employed or student part time | Count | | 92 | 2 | 2 | | 27 | 19 | 5 | 147
| % | 0.00% | 62.59% | 1.36% | 1.36% | 0.00% | 18.37% | 12.93% | 3.40% | 100%
Homemaker | Count | | | 160 | | 1 | 5 | 11 | | 177
| % | 0.00% | 0.00% | 90.40% | 0.00% | 0.56% | 2.82% | 6.21% | 0.00% | 100%
Retired | Count | | | 1 | 181 | | | 2 | | 184
| % | 0.00% | 0.00% | 0.54% | 98.37% | 0.00% | 0.00% | 1.09% | 0.00% | 100%
Never employed | Count | | | 1 | | 42 | 2 | 1 | | 46
| % | 0.00% | 0.00% | 2.17% | 0.00% | 91.30% | 4.35% | 2.17% | 0.00% | 100%
Unemployed | Count | 1 | | 1 | 1 | | 171 | 16 | | 190
| % | 0.53% | 0.00% | 0.53% | 0.53% | 0.00% | 90.00% | 8.42% | 0.00% | 100%
Disabled | Count | 1 | | | | | | 460 | | 461
| % | 0.22% | 0.00% | 0.00% | 0.00% | 0.00% | 0.00% | 99.78% | 0.00% | 100%
Other | Count | 1 | | 1 | 1 | | 6 | 2 | 19 | 30
| % | 3.33% | 0.00% | 3.33% | 3.33% | 0.00% | 20.00% | 6.67% | 63.33% | 100%
Total | Count | 429 | 157 | 169 | 225 | 43 | 318 | 727 | 53 | 2121
| % | 20.23% | 7.40% | 7.97% | 10.61% | 2.03% | 14.99% | 34.28% | 2.50% | 100%
Looking for employment?
Yes | Count | 3 | 2 | 1 | | | 29 | 10 | 2 | 47
| % | 6.38% | 4.26% | 2.13% | 0.00% | 0.00% | 61.70% | 21.28% | 4.26% | 100%
No | Count | 44 | 37 | 118 | 108 | 40 | 274 | 454 | 21 | 1096
| % | 4.01% | 3.38% | 10.77% | 9.85% | 3.65% | 25.00% | 41.42% | 1.92% | 100%
Total | Count | 47 | 39 | 119 | 108 | 40 | 303 | 464 | 23 | 1143
| % | 4.11% | 3.41% | 10.41% | 9.45% | 3.50% | 26.51% | 40.59% | 2.01% | 100%
Sex
Male | Count | 251 | 86 | 2 | 144 | 11 | 167 | 448 | 29 | 1138
| % | 22.06% | 7.56% | 0.18% | 12.65% | 0.97% | 14.67% | 39.37% | 2.55% | 100%
Female | Count | 184 | 72 | 169 | 89 | 32 | 157 | 291 | 29 | 1023
| % | 17.99% | 7.04% | 16.52% | 8.70% | 3.13% | 15.35% | 28.45% | 2.83% | 100%
Total | Count | 435 | 158 | 171 | 233 | 43 | 324 | 739 | 58 | 2161
| % | 20.13% | 7.31% | 7.91% | 10.78% | 1.99% | 14.99% | 34.20% | 2.68% | 100%
Able to work part time?
Yes | Count | 127 | 63 | 17 | 22 | 3 | 40 | 38 | 13 | 323
| % | 39.32% | 19.50% | 5.26% | 6.81% | 0.93% | 12.38% | 11.76% | 4.02% | 100%
No | Count | 73 | 35 | 101 | 122 | 22 | 163 | 415 | 24 | 955
| % | 7.64% | 3.66% | 10.58% | 12.77% | 2.30% | 17.07% | 43.46% | 2.51% | 100%
Total | Count | 200 | 98 | 118 | 144 | 25 | 203 | 453 | 37 | 1278
| % | 15.65% | 7.67% | 9.23% | 11.27% | 1.96% | 15.88% | 35.45% | 2.90% | 100%
Able to work full time?
Yes | Count | 199 | 27 | 5 | 6 | 2 | 9 | 12 | 8 | 268
| % | 74.25% | 10.07% | 1.87% | 2.24% | 0.75% | 3.36% | 4.48% | 2.99% | 100%
No | Count | 70 | 61 | 102 | 129 | 22 | 179 | 429 | 30 | 1022
| % | 6.85% | 5.97% | 9.98% | 12.62% | 2.15% | 17.51% | 41.98% | 2.94% | 100%
Total | Count | 269 | 88 | 107 | 135 | 24 | 188 | 441 | 38 | 1290
| % | 20.85% | 6.82% | 8.29% | 10.47% | 1.86% | 14.57% | 34.19% | 2.95% | 100%
Able to work part time at followup?
Yes | Count | 70 | 32 | 11 | 13 | 5 | 36 | 46 | 10 | 223
| % | 31.39% | 14.35% | 4.93% | 5.83% | 2.24% | 16.14% | 20.63% | 4.48% | 100%
No | Count | 59 | 37 | 69 | 79 | 13 | 92 | 254 | 9 | 612
| % | 9.64% | 6.05% | 11.27% | 12.91% | 2.12% | 15.03% | 41.50% | 1.47% | 100%
Total | Count | 129 | 69 | 80 | 92 | 18 | 128 | 300 | 19 | 835
| % | 15.45% | 8.26% | 9.58% | 11.02% | 2.16% | 15.33% | 35.93% | 2.28% | 100%
Able to work full time at followup?
Yes | Count | 102 | 16 | 3 | 1 | | 8 | 15 | 5 | 150
| % | 68.00% | 10.67% | 2.00% | 0.67% | 0.00% | 5.33% | 10.00% | 3.33% | 100%
No | Count | 62 | 50 | 73 | 86 | 17 | 107 | 269 | 13 | 677
| % | 9.16% | 7.39% | 10.78% | 12.70% | 2.51% | 15.81% | 39.73% | 1.92% | 100%
Total | Count | 164 | 66 | 76 | 87 | 17 | 115 | 284 | 18 | 827
| % | 19.83% | 7.98% | 9.19% | 10.52% | 2.06% | 13.91% | 34.34% | 2.18% | 100%
Employment status at followup
Working full time | Count | 96 | 10 | | | | 3 | 9 | 4 | 122
| % | 78.69% | 8.20% | 0.00% | 0.00% | 0.00% | 2.46% | 7.38% | 3.28% | 100%
Working part time | Count | 18 | 12 | 1 | 2 | | 6 | 10 | 5 | 54
| % | 33.33% | 22.22% | 1.85% | 3.70% | 0.00% | 11.11% | 18.52% | 9.26% | 100%
In school | Count | 2 | | 1 | | | 4 | 4 | | 11
| % | 18.18% | 0.00% | 9.09% | 0.00% | 0.00% | 36.36% | 36.36% | 0.00% | 100%
Keeping house | Count | 4 | 7 | 27 | 5 | 4 | 16 | 6 | 1 | 70
| % | 5.71% | 10.00% | 38.57% | 7.14% | 5.71% | 22.86% | 8.57% | 1.43% | 100%
Retired | Count | 6 | 4 | 8 | 49 | 3 | 3 | 28 | | 101
| % | 5.94% | 3.96% | 7.92% | 48.51% | 2.97% | 2.97% | 27.72% | 0.00% | 100%
Unemployed, laid off, or looking for work | Count | 5 | | 1 | | 1 | 11 | 10 | | 28
| % | 17.86% | 0.00% | 3.57% | 0.00% | 3.57% | 39.29% | 35.71% | 0.00% | 100%
Disabled | Count | 34 | 33 | 33 | 28 | 7 | 61 | 203 | 8 | 407
| % | 8.35% | 8.11% | 8.11% | 6.88% | 1.72% | 14.99% | 49.88% | 1.97% | 100%
None of the above | Count | 3 | 4 | 13 | 4 | 2 | 20 | 15 | 2 | 63
| % | 4.76% | 6.35% | 20.63% | 6.35% | 3.17% | 31.75% | 23.81% | 3.17% | 100%
Total | Count | 168 | 70 | 84 | 88 | 17 | 124 | 285 | 20 | 856
| % | 19.63% | 8.18% | 9.81% | 10.28% | 1.99% | 14.49% | 33.29% | 2.34% | 100%