# Appendix C: Scoring of Kidney Disease Quality-of-Life Questionnaire

Table C-1. Scoring of Kidney Disease Quality-of-Life Questionnaire*Appendix C: Scoring of Kidney Disease Quality-of-Life Questionnaire

Table C-1. Scoring of Kidney Disease Quality-of-Life Questionnaire*Appendix C: Scoring of Kidney Disease Quality-of-Life Questionnaire

Scale | Item numbers | Coding | Direction recoded | Original value, recoded ^1^ | Interpretation of high score
Symptom/problem list | 47-58 | 1=Not at all bothered | 5=Not at all bothered | 1=100 | Not at all bothered
| | 5=Extremely bothered | 1=Extremely bothered | 5=0
Effects of kidney disease | 59-65 | 1=Not at all bothered | 5=Not at all bothered | 1=100 | Less negative effect of kidney disease
| | 5=Extremely bothered | 1=Extremely bothered | 5=0
Burden of kidney disease | 37-40 | 1=Definitely true | No change | 1=0 | Less burden of kidney disease
| | 5=Definitely false | | 5=100
Work status | 74 | 1=Yes | 2=Yes | 1=100 | Able to work
| | 2=No | 1=No | 2=0
| 75 | 1=Worked full time | No change | 1=100 | Employed
| | 2=Worked part time | | 2=50
| | 3-7=Not working | | 3-7=0
Cognitive function | 42, 44, 46 | 1=All of the time | No change | 1=0 | Better cognitive function
| | 6=None of the time | | 6=100
Sexual function | 66, 67 | 1=Not a problem | 5=Not a problem | 1=100 | Sexual function not a problem
| | 5=Severe problem | 1=Severe problem | 5=0
Quality of social interaction | 41, 43, 45 | 1=All of the time | 6=None of the time | 1=0 | Better social interaction
| | 6=None of the time | 1=All of the time | 6=100
Sleep | 71 | 0=Very bad | No change | 0=0 | Very good overall rating of sleep
| | 10=Very good | | 10=100
| 68, 70 | 1=Yes | No change | 1=0 | No trouble with sleep
| | 2=No | | 2=100
| NA ^2^ | 1=None of the time | No change | 1=0 | Receiving the amount of sleep needed
| | 6=All of the time | | 6=100
Social support | 72, 73 | 1=Very dissatisfied | No change | 1=0 | Very satisfied with social support
| | 4=Very satisfied | | 4=100
Dialysis staff encouragement | 77, 78 | 1=Definitely true | 5=Definitely true | 1=100 | Better staff encouragement
| | 5=Definitely false | 1=Definitely false | 5=0
Patient satisfaction | 76 | 1=Very poor | No change | 1=0 | Higher patient satisfaction
| | 7=The best | | 7=100
Physical functioning | 3 - 12 | 1=Limited a lot | No change | 1=0 | Not limited in physical functioning
| | 3=Not limited at all | | 3=100
Role-Physical | 13-16 | 1=Yes | No change | 1=0 | Better role functioning related to physical health
| | 2=No | | 2=100
Pain | 21 | 1=None | 6=None | 1=100 | No bodily pain
| | 6=Very severe | 1=Very severe | 6=0
| 22 | 1=Not at all | 5=Not at all | 1=100 | Pain did not interfere with normal work
| | 5=Extremely | 1=Extremely | 5=0
General health | 1 | 1=Excellent | 5=Excellent | 1=100 | Excellent health
| | 5=Poor | 1=Poor | 5=0
| 34, 36 | 1=Definitely true | 5=Definitely true | 1=100 | Best health
| | 5=Definitely false | 1=Definitely false | 5=0
| 33, 35 | 1=Definitely true | No change | 1=0 | Not sick
| | 5=Definitely false | | 5=100
Emotional well-being | 24, 25, 28 | 1=All of the time | No change | 1=0 | Good emotional well-being
| | 6=None of the time | | 6=100
| 26, 30 | 1=All of the time | 6=All of the time | 1=100
| | 6=None of the time | 1=None of the time | 6=0
Role-Emotional | 17-19 | 1=Yes | No change | 1=0 | Better role functioning related to mental health
| | 2=No | | 2=100
Social function | 20 | 1=Not at all | 5=Not at all | 1=100 | No interference with social activities
| | 5=Extremely | 1=Extremely | 5=0
| 32 | 1=All of the time | No change | 1=100
| | 5=None of the time | | 5=0
Energy/fatigue | 23, 27 | 1=All of the time | 6=All of the time | 1=100 | High energy
| | 6=None of the time | 1=None of the time | 6=0
| 29, 31 | 1=All of the time | No change | 1=0 | Not tired or fatigued
| | 6=None of the time | | 6=100

* This scoring table was adapted from KDQOLTM Scoring Instructions (Kamberg, 1999). Reproduced with permission from RAND Corporation. The numbers in the "Item Numbers" column, which differ from those in the original Scoring Table, correspond to item numbers in the DMMS Wave 2 documentation (United States Renal Data System, 1998) and reflect item numbering changes made by the DMMS Wave 2 researchers.

1 High score=better health

2 This KDQOLTM measure was not used in the DMMS Wave 2 Patient Questionnaire.