# Appendix B: Summary of Significant Correlations for Validity Analyses

Note: Unless otherwise noted, measurements below were taken at the beginning of the study, on patients about to undergo a dialysis session.

Few of these correlations were very high (above 0.3). Most fell in the 0.1 to 0.3 range, but were statistically significant nonetheless, at the p<0.001 level, due to the large subject population.

## Differences Between PD and HD Patients

Cholesterol higher among PD users

PD users have higher education

Pre-treatment BUN lower among PD patients, but post-treatment BUN higher among PD patients

PD patients have higher serum bicarbonate, higher hematocrit, higher hemoglobin, and are less likely to take EPO

Postdialysis creatinine higher among PD patients

PD patients health generally better

PD patients less limited in physical activities

HD patients have more difficulty performing tasks

Reduced work ability among PD patients (may reflect that these patients were more likely to be working to begin with?)

PD patients have less pain interference, and more general interference with life

PD patients have fewer problems with access or catheter

PD patients more likely to be working, but work is more limited

PD patients live further away from dialysis facility

PD patients less likely to take Vitamin D injections

### Correlations Among Laboratory Values

#### Positive Correlations

Serum creatinine and postdialysis weight

BUN and postdialysis weight

Serum albumin and postdialysis weight

Dialysate creatinine and dialysate urea

Dialysate urea, BUN, phosphorus, and serum creatinine

Serum creatinine, serum albumin

BUN, education level, and job status

Creatinine and education

Calcium and serum bicarbonate

Hematocrit, serum calcium, hemoglobin, serum bicarbonate

Serum albumin and hematocrit

Serum albumin and hemoglobin

Serum albumin and creatinine

Weight and BUN

Better general health, higher albumin

UUN and urine creatinine

Phosphorus and pre-treatment diastolic BP

Serum creatinine, post-treatment systolic BP

UUN higher among those with CHD or diabetes

#### Negative Correlations

Creatinine lower among patients with diabetes or CHD

Those with higher serum albumin less likely to be undernourished

Lower creatinine among those who are not independently mobile [indication of elderly?]

Higher serum creatinine, lower serum bicarbonate

Hematocrit and creatinine

Hemoglobin and creatinine

Dialysate creatinine and UUN

Serum calcium and phosphorus

Serum bicarbonate and phosphorus

Serum albumin and calcium

Serum albumin and serum bicarbonate

Those taking Vitamin D have lower post-treatment BUN and lower weight

Higher phosphorus, lower age

Dialysate urea nitrogen and postdialysis systolic and diastolic blood pressure

#### Miscellaneous Correlations

Higher creatinine among minorities

CHD and diabetes patients more likely to move independently and have been previously employed

Hematocrit and hemoglobin higher among Caucasians

Caucasians less likely to be taking Vitamin D injections

Minorities less likely to report problems with vigorous physical activities

Patients with CHD/CAD or diabetes are more likely to be limited in physical activities and work

No correlation between median pre-treatment systolic BP and median post-treatment systolic BP