# Flow Diagram

## Study retrieval and selection for diagnosis and management of occupational asthma

[image]