# Abbreviations

ACCP: | American College of Chest Physicians
AC: | Azodicarbonamide
BHR: | Bronchial hyper-responsiveness
C: | Current
CAP: | Developed by Pharmacia Diagnostics for measuring specific IgE
cbu: | Cumulative breath unit
CCT: | Controlled clinical trial
CI: | Confidence intervals
CO-HSA: | Conjugated human serum albumin
cpm: | Counts per minute
CS: | Corticosteroids
DCP: | Diagnostics products corp.
EAST: | Enzyme allergosorbent test
ECG: | Electrocardiogram
ECP: | Eosinophilic cationic protein
ECSC: | European coal and steel community
ED: | Emergency department
ELISA: | Enzyme-linked immuno sorbent assay
EIB: | Exercise-induced bronchoconstriction
eNO: | Exhaled nitric oxide
Ex: | Ex
FEF: | Forced expiratory flow
FEV_1_: | Forced expiratory volume in one second
FU: | Follow-up
FVC: | Forced vital capacity
H: | High
HDI: | Hexamethylene di-isocyanate
HHPA: | Hexahydrophthalic anhydride
HMW: | High molecular weight
ICS: | Inhaled corticosteroids
IL-8: | Interleukin-8
IQR: | Interquatrile range
kPa: | Kilopascal
L: | Low
LABA: | Long acting beta-agonists
LKTRA: | Leukotriene receptor antagonists
LMW: | Low molecular weight
LR: | Likelihood ratios
M: | Mixed
MCP-1: | Monocyte chemoattractant protein-1
MDI: | Diphenylmethane di-isocyanate
MEF: | Maximal expiratory flow
MEF_25_: | Maximal expiratory flow at 25% of vital capacity
MEF_50_: | Maximal expiratory flow at 50% of vital capacity
MPO: | Myeloperoxidase
MSDS: | Material safety data sheet
N: | Never
NDI: | Naphthalene di-isocyanate
NRL: | Natural rubber latex
NSBP test: | Non-specific bronchial provocation test
NSBR: | Non-specific bronchial reactivity
OA: | Occupational asthma
OASYS-2: | Occupational asthma systems
OD: | Optical density
PaO_2_: | Arterial oxygen partial pressure
PC_20_: | Provocative concentration causing a 20% drop in FEV_1_
PD_15_: | Provocative dose causing a 15% drop in FEV_1_
PD_20_: | Provocative dose causing a 20% drop in FEV_1_
PD_50_: | Provocative dose causing a 50% drop in FEV_1_
PEF: | Peak expiratory flow
PEFR: | Peak expiratory flow rate
PFT: | Pulmonary function test
PPE: | Personal protective equipment
PRIST: | Paper radioimmunosorbent test
PTRIA: | Polystyrene-tube radioimmunoassay
PRU: | Phadebas RAST units
QOL: | Quality of life
RADS: | Reactive airways dysfunction syndrome
RAST: | Radio allegro sorbent test
RCT: | Randomized controlled trial
REIA: | Reverse enzyme immunoassay
RIA: | Radioimmunoassay
RIACT: | Radioimmunoassay kit for measuring IgE
RV: | Residual volume
USD: | United States dollar
SABA: | Short acting beta-agonists
SD: | Standard deviation
SDS: | Sodium dodecyl sulphate
SEM: | Standard error of the mean
sGaw: | Specific airways conductance
SIC: | Specific inhalation challenge
SOB: | Shortness of breath
SPBRIA: | Solid-phase bead radioimmunoassay;
SPT: | Skin prick test
sRAW: | Specific airway resistance
SWORD: | Surveillance of work-related occupational respiratory disease
TCPA: | Tetrachlorophthalic anhydride
TCPA-HSA: | Tetrachlorophthalic anhydride human serum albumin
TDI: | Toluene di-isocyanates
TDI-HSA: | Toluene di-isocyanates human serum albumin
TEP: | Technical expert panel
TLco: | Single breath carbon monoxide
TMA: | Trimellitic anhydride
WCB: | Workers' Compensation Board
IU: | International unit
UniCAP: | Fluoroenzymeimmunoassay kit developed by Pharmacia Diagnostics
Vmax: | Maximum flow