# Excluded Studies

### References

Four hundred and sixty-one studies were excluded from the review. Reasons for exclusion include: study design (n=164), inappropriate topic (n=124), population (n=63), inadequate data (n=58), and no treatment or tests (n=13). The reports of 38 studies were unobtainable at the time of this writing and one was realized upon completion of the final report.

Study Design

1 Abramson MJ, Saunders NA, Hensley MJ. Analysis of bronchial reactivity in epidemiological studies. Thorax. 1990;45(12):924-9. [pmid: 2281424]. [pmcid: 462839].
2 Acero S, Alvarez MJ, Garcia BE, et al. Occupational asthma from natural rubber latex. Specific inhalation challenge test and evolution. J Investig Allergol Clin Immunol. 2003;13(3):155-61.
3 Acero S, Tabar AI, Alvarez MJ, et al. Occupational asthma and food allergy due to carmine. Allergy. 1998;53:897-901. [pmid: 9788693].
4 Agalliu I, Eisen EA, Hauser R, et al. Truncating the dose range for methacholine challenge tests: three occupational studies. J Occup Environ Med. 2003;45(8):841-7. [pmid: 12915785].
5 Alberts WM. Getting the most from the “gold standard”. Chest. 2003;123(4):987-9. [pmid: 12684283].
6 Alberts WM, Brooks SM. Occupational Asthma - Serious Consequences for Workers and Employers. Postgrad Med. 1995;97(6):93-104. [pmid: 7777449].
7 Anconetani JP, Badorrey MI, Monso E, et al. Occupational asthma caused by persulphates: limited usefulness of the measurement of peak expiratory flow at work place. Med Clin. 2001;116(9):355-6.
8 Anees W. Use of pulmonary function tests in the diagnosis of occupational asthma. Ann Allergy Asthma Immunol. 2003;90(5 Suppl 2):47-51. [pmid: 12772952].
9 Anonymous. [Normalization of the “occupational” specific bronchoreactive tests in occupational medicine, Study group of the Italian Society of Occupational Medicine and Industrial Hygiene] [Italian]. G Ital Med Lav. 1983;5(3):117-21. [pmid: 6676112].
10 Anonymous. Sputum cell profile: No help in occupational asthma (Echo). Occup Environ Med. 2002;59(8):561.
11 Bain EI. Perils in the air: Avoiding occupational asthma triggers in the workplace. AJN. 2000;100(6):88. [pmid: 10892334].
12 Banks DE, Barkman HW Jr, Butcher BT, et al. Absence of hyperresponsiveness to methacholine in a worker with methylene diphenyl diisocyanate (MDI)-induced asthma. Chest. 1986;89(3):389-93. [pmid: 3512187].
13 Banks DE, Tarlo SM, Masri F, et al. Bronchoprovocation tests in the diagnosis of isocyanate-induced asthma. Chest. 1996;109(5):1370-9. [pmid: 8625691].
14 Bardana EJ Jr. Meatwrappers' asthma: clinical and pathogenetic observations. Book chapter 2 1980;14–32.
15 Bardana EJ Jr. Reactive airways dysfunction syndrome (RADS): Guidelines for diagnosis and treatment and insight into likely prognosis. Ann Allergy Asthma Immunol. 1999;83:583-6. [pmid: 10619325].
16 Barnhart S. Evaluation of impairment and disability in occupational lung disease. Occup Med. 1987;2(2):227-41. [pmid: 3303378].
17 Bascom R, Ford E. Don't just “do spirometry”--closing the loop in workplace spirometry programs. Occup Med. 1992;7(2):347-63. [pmid: 1615367].
18 Beeson MJ, Dewdney JM, Edwards RG, et al. Prevalence and diagnosis of laboratory animal allergy. Clin Allergy. 1983;13:433-42. [pmid: 6627621].
19 Bernstein DI, Jolly A. Current diagnostic methods for diisocyanate induced occupational asthma. Am J Ind Med. 1999;36(4):459-68. [pmid: 10470011].
20 Brhel P. Principles of diagnosis of occupational character of bronchial asthma. Prac Lek. 1997;49(2):93-7.
21 Bright P, Burge PS. The diagnosis of occupational asthma from serial measurements of lung function at and away from work. Thorax. 1996;51(8):857-3. [pmid: 8795680]. [pmcid: 472574].
22 Bright P, Burge PS. Occupational lung disease. The diagnosis of occupational asthma from serial measurements of lung function at and away from work. Thorax. 1996;51(8):857-3. [pmid: 8795680]. [pmcid: 472574].
23 Bright P, Newton DT, Gannon PF, et al. OASYS-3: improved analysis of serial peak expiratory flow in suspected occupational asthma. Monaldi Arch Chest Dis. 2001;56(3):281-8. [pmid: 11665511].
24 Brooks SM, Edwards JJ Jr, Apol A, et al. An epidemiologic study of workers exposed to western red cedar and other wood dusts. Chest. 1981;80(Suppl):30S-2S.
25 Brooks SM, Weiss MA, Bernstein IL. Reactive Airways Dysfunction Syndrome (RADS) Persistent asthma syndrome after high level irritant exposures. Chest. 1985;88(3):376-84. [pmid: 4028848].
26 Burge PS. Chapter 9: Physiologic assessment of occupational asthma. 171–88.
27 Burge PS. Occupational asthma due to soft soldering fluxes containing colophony (rosin, pine resin). Eur J Respir Dis. 1982;123(Suppl):65-77.
28 Burge PS. Single and serial measurements of lung function in the diagnosis of occupational asthma. Eur J Respir Dis. 1982;63(Supplement 123):47-59. [pmid: 6279420].
29 Burge PS, Edge G, O'Brien IM, et al. Occupational asthma in a research centre breeding locusts. Clin Allergy. 1980;10(4):355-63. [pmid: 7449072].
30 Burge PS, Pantin CF, Newton DT, et al. Development of an expert system for the interpretation of serial peak expiratory flow measurements in the diagnosis of occupational asthma. Occup Environ Med. 1999;56(11):758-64. [pmid: 10658562]. [pmcid: 1757688].
31 Bush RK. Assessment and treatment of laboratory animal allergy. ILARJ. 2001;42(1):55-64.
32 Butcher B, Salvaggio JE, O'Neil CE, et al. Toluene diisocyanate pulmonary disease: Immunopharmacologic and mecholyl challenge studies. J Allergy Clin Immunol. 1977;59(3):223-7. [pmid: 65373].
33 Butcher BT. Inhalation challenge testing with toluene diisocyanate. J Allergy Clin Immunol. 1979;64(6 pt 2):655-7. [pmid: 229144].
34 Butcher BT. Isocyanate induced asthma. Eur J Respir Dis. 1982;123(Suppl):78-81.
35 Butcher BT, Bernstein IL, Schwartz HJ. Guidelines for the clinical evaluation of occupational asthma due to small molecular weight chemicals. Report of the Subcommittee on the Clinical Evaluation of Occupational Asthma due to Small Molecular Weight Chemicals. J Allergy Clin Immunol. 1989;84(5 Pt 2):834-8. [pmid: 2809033].
36 Butcher BT, Karr RM, O'Neil CE, et al. Inhalation challenge and pharmacologic studies of toluene diisocyanate (TDI)-sensitive workers. J Allergy Clin Immunol. 1979;64(2):146-52. [pmid: 222827].
37 Canadian Thoracic Society Ad Hoc Committee on Occupational Asthma of the Standards Committee. Occupational asthma: Recommendations for diagnosis, management, and assessment of impairment. CMAJ. 1989;140:1029-32. [pmid: 2650835]. [pmcid: 1268975].
38 Cartier A. Definition and Diagnosis of Occupational Asthma. Eur Respir J. 1994;7(1):153-60. [pmid: 8143815].
39 Cartier A. Investigation of occupational asthma. Can Respir J. 1998;5(Suppl A):71A-6A.
40 Cartier A, Bernstein IL, Burge PS, et al. Guidelines for bronchoprovocation on the investigation of occupational asthma. Report of the Subcommittee on Bronchoprovocation for Occupational Asthma. J Allergy Clin Immunol. 1989;84(5 Pt 2):823-9. [pmid: 2809031].
41 Cartier A, L'Archeveque J, Malo JL. Exposure to a sensitizing occupational agent can cause a long-lasting increase in bronchial responsiveness to histamine in the absence of significant changes in airway calibre. J Allergy Clin Immunol. 1986;78:1185-9. [pmid: 3782680].
42 Cartier A, Malo JL. Chapter 12: Occupational challenge tests. 211–33.
43 Cartier A, Pineau L, Malo JL. Monitoring of maximum expiratory peak flow rates and histamine inhalation tests in the investigation of occupational asthma. Clin Allergy. 1984;14:193-6. [pmid: 6705182].
44 Chan-Yeung M. Assessment of asthma in the workplace. ACCP Consensus Statement. Chest. 1995;108:1084-117. [pmid: 7555124].
45 Chan-Yeung M. Evaluation of impairment/disability in patients with occupational asthma. Am Rev Respir Dis. 1987;135(4):950-1. [pmid: 3565943].
46 Chan-Yeung M. Immunological and nonimmunologic mechanism in asthma due to Western red cedar (Thuja plicata). J Allergy Clin Immunol. 1982;70(32):32-7. [pmid: 6177724].
47 Chan-Yeung M, Ashley MJ, Corey P, et al. A respiratory survey of cedar mill workers: Prevalence of symptoms and pulmonary function abnormalities. J Occup Med. 1978;20(5):323-7. [pmid: 650305].
48 Chan-Yeung M, Barton GM, McLean L, et al. Bronchial reactions to western red cedar (Thuja plicata). CMAJ. 1971;105(1):56-8. [pmid: 5088476]. [pmcid: 1931066].
49 Clark NM, Evans D, Mellins RB. Patient use of peak flow monitoring. Am Rev Respir Dis. 1992;145:722-5. [pmid: 1546857].
50 Clini E, Vitaca CM, Scalvini S, et al. Methacholine inhaled challenge: study of correlation among different indices expressing the result. Monaldi Arch Chest Dis. 1996;51(3):194-8. [pmid: 8766192].
51 Cloutier Y, Lagier F, Cartier A, et al. Validation of an exposure system to particles for the diagnosis of occupational asthma. Chest. 1992;102(2):402-7. [pmid: 1643922].
52 Coeli Mendonca EM, Algranti E, Cruz da Silva RC. Occupational asthma - Objective diagnosis by peak flow rate records [Portuguese]. G Pneumol. 1990;16(4):181-6.
53 Conner PR. Experience with early detection of toluene diisocyanate-associated occupational asthma. Appl Occup Environ Hyg. 2002;17(12):856-62. [pmid: 12495596].
54 Curran AD, Fishwick D. Occupational asthma: Research, change and the 30% target. Ann Occup Hyg. 2003;47(6):433-6. [pmid: 12890652].
55 De Zotti R, Muran A, Zambon F. Two cases of paraoccupational asthma due to toluene diisocyanate (TDI). Occup Environ Med. 2000;57(12):837-9. [pmid: 11077013]. [pmcid: 1739890].
56 Desjardins A, Malo JL, L'Archeveque J, et al. Occupational IgE-mediated sensitization and asthma caused by clam and shrimp. J Allergy Clin Immunol. 1995;96(5 Pt 1):608-17. [pmid: 7499677].
57 Dodge R. Sensitivity of methacholine testing in occupational asthma. Chest. 1986;89(3):324-5. [pmid: 3512185].
58 Drexler H, Weber A, Letzel S, et al. Detection and clinical relevance of a type I allergy with occupational exposure to hexahydrophthalic anhydride and methyltetrahydrophthalic anhydride. Int Arch Occup Environ Health. 1994;65(5):279-83. [pmid: 8175180].
59 Eiser NM, Kerrebijn KF, Quanjer PH. Guidelines for standardization of bronchial challenges with (nonspecific) bronchoconstricting agents. Bull Eur Physiopathol Respir. 1983;19:495-515. [pmid: 6357313].
60 Fabbri LM. Inhalational challenge reactions to isocyanates [3]. J Allergy Clin Immunol. 1991;87(2):600. [pmid: 2036111].
61 Fabbri LM, Danieli D, Crescioli S, et al. Fatal asthma in a subject sensitized to toluene diisocyanate. Am Rev Respir Dis. 1988;137:1494-8. [pmid: 2849334].
62 Fabbri LM, Saetta M, Picotti G, et al. Late asthmatic reactions, airway inflammation and chronic asthma in toluene-diisocyanate-sensitized subjects. Respiration. 1991;58(Suppl 1):18-21. [pmid: 1656502].
63 Fitzgerald ST, Hill M, Santamari B, et al. Diagnosis and management of asthma: occupational health nurses' awareness and use of national consensus practice guidelines. AAOHN Journal. 1996;44(2):78-83. [pmid: 8694979].
64 Fitzgerald ST, Huss K, Huss RW. The diagnosis and management of asthma: an update. AAOHN Journal. 1996;44(2):94-104. [pmid: 8694981].
65 Friedman-Jimenez G, Beckett WS, Szeinuk J, et al. Clinical evaluation, management, and prevention of work-related asthma. Am J Ind Med. 2000;37:121-41. [pmid: 10573601].
66 Fruhmann G. [Occupational asthma. New findings on work related obstructive respiratory diseases (author's transl)] German. MMW Munch Med Wochenschr. 1981;123(8):299-303. [pmid: 6163981].
67 Fung F, Tappen D, Wood G. Alternaria-associated asthma. Appl Occup Environ Hyg. 2000;15(12):924-7. [pmid: 11141604].
68 Gadon ME, Melius JM, McDonald GJ, et al. New-onset asthma after exposure to the steam system additive 2-diethylaminoethanol. A descriptive study. J Occup Med. 1994;36(6):623-6. [pmid: 8071723].
69 Gannon PFG, Burge PS. Serial peak expiratory flow measurement in the diagnosis of occupational asthma. Eur Respir J. 1997;10(Suppl 24):57s-63s.
70 Gerblich AA, Horowitz J, Chester EH, et al. A proposed standardized method for bronchoprovocation tests in toluene diisocyanate-induced asthma. J Allergy Clin Immunol. 1979;64(6 pt 2):658-61. [pmid: 229145].
71 Gonsior E. [Significance of the inhalation provocation test for the diagnosis of occupational allergic bronchial asthma][German]. Hefte zur Unfallheilkunde 1975;(121):536–40.
72 Gorski P, Krajewska E. The usefulness of functional test of the respiratory system for the diagnosis of occupational bronchial asthma. Czechoslovakian. Medycyna-Pracy. 1990;41(6):435-8.
73 Grammer LC, Patterson R. Immunologic evaluation of occupational asthma. In: Bernstein IL, Chan-Yeung M, Malo J-L, Bernstein DI, editors. Asthma in the Workplace. New York: Marcel Dekker Inc;1993:125–43.
74 Guidotti TL for The Occupational and Environmental Health Committee of the American Lung Association of San Diego and Imperial Counties. Taking the occupational history. Ann Int Med 1983;99:641–51.
75 Harber P, Rappaport S. Clinical decision analysis in occupational medicine. Choosing the optimal FEV1 criterion for diagnosing occupational asthma. J Occup Med. 1985;27(9):651-8. [pmid: 4045576].
76 Heaney LG, McCrea P, Buick B, et al. Brewer's asthma due to malt contamination. Occup Med. 1997;47(7):397-400.
77 Hendrick DJ. Diagnostic tests for occupational asthma. Am J Respir Crit Care Med. 2002;166(4):436-7. [pmid: 12186815].
78 Hendrick DJ. Management of occupational asthma. Eur Respir J. 1994;7:961-8. [pmid: 8050555].
79 Hendrick DJ, Rando RJ, Lane DJ, et al. Formaldehyde asthma: Challenge exposure levels and fate after 5 years. J Occup Med. 1982;24(11):893-7. [pmid: 7175584].
80 Jarvis JQ. Occupational Asthma - Diagnosis and prognosis. Sem Respir Med. 1993;14(3):234-9.
81 Karol MH. Respiratory effects of inhaled isocyanates. Crit Rev Toxicol. 1986;16(4):349-79. [pmid: 3519088].
82 Karr RM. Bronchoprovocation studies in coffee worker's asthma. J Allergy Clin Immunol. 1979;64(6 pt 2):650-4. [pmid: 512261].
83 Kimmel SR. Use of the peak flow meter in office practice. AFP. 1986;34(6):107-11.
84 Koper I, Ruff T, Heise D, et al. The estimation of unspecific and specific provocation by means of forced expiratory volume and specific conductance in bakers [German]. Atemwegs- und Lungenkrankheiten. 1990;16(7):265-6.
85 Kopferschmitt-Kubler MC, Ameille J, Popin E, et al. Occupational asthma in France: A 1-yr report of the Observatoire National de Asthmes Professionnels project. Eur Respir J. 2002;19:84-9. [pmid: 11843332].
86 Kopferschmitt-Kubler MC, Dietemann A, Mahr L et al. Significant changes in non-specific hyperresponsiveness after negative isocyanate bronchial challenge tests in exposed symptomatic workers. A504.
87 Kurtz KM, Hamilton RG, Adkinson NF Jr. Role and application of provocation in the diagnosis of occupational latex allergy. Ann Allergy Asthma Immunol. 1999;83:634-9. [pmid: 10619335].
88 Kuschner WG, Chitkara RK, Sarinas PSA. Occupational asthma: Practical points for diagnosis and management. West J Med. 1998;169(6):342-50. [pmid: 9866431]. [pmcid: 1305401].
89 Lemiere C. Persistence of bronchial reactivity to occupational agents after removal from exposure and identification of associated factors. Ann Allergy, Asthma, Immunol. 2003;90(Suppl):52-5. [pmid: 12772953].
90 Lemiere C, Efthimiadis A, Hargreave FE. Occupational esosinophilic bronchitis without asthma: an unknown occupational airway disease. J Allergy Clin Immunol. 1997;100:852-3. [pmid: 9438499].
91 Lemiere C, Malo JL, Boulet M. Reactive airways dysfunction syndrome due to chlorine: sequential bronchial biopsies and functional assessment. Eur Respir J. 1997;10:241-4. [pmid: 9032521].
92 Leroyer C, Perfetti L, Cartier A, et al. Can reactive airways dysfunction syndrome (RADS) transform into occupational asthma due to “sensitization” to isocyanates?. Thorax. 1998;53:152-3. [pmid: 9624303]. [pmcid: 1758718].
93 Leroyer C, Perfetti L, Trudeau C, et al. Comparison of serial monitoring of peak expiratory flow and FEV1 in the diagnosis of occupational asthma. Am J Respir Crit Care Med. 1998;158(3):827-32. [pmid: 9731012].
94 Lewis J, Morgan WKC. Tea asthma: Response to specific and non-specific challenges. Br J Ind Med. 1989;46:350-1. [pmid: 2751935]. [pmcid: 1009780].
95 Lieutier-Colas F, Kopferschmitt MC, Pauli G, et al. Do bronchial provocation tests correspond to reality in asthma patients? [French]. Rev Fr Allergol Immunol Clin. 2003;43(5):310-3.
96 Longbottom JL. Occupational allergy due to animal allergens. Clin Immunol Allergy. 1984;4(1):19-24.
97 Lopez-Rubio A, Rodriguez J, Crespo JF, et al. Occupational asthma caused by exposure to asparagus: Detection of allergens by immunoblotting. Allergy. 1998;53(12):1216-20. [pmid: 9930601].
98 Maestrelli P, Saetta M, Mapp C, et al. Diagnostic basis of occupational asthma. J Investig Allergol Clin Immunol. 1997;7(5):316-7.
99 Malo JL. The case for confirming occupational asthma: Why, how much, how far?. J Allergy Clin Immunol. 1993;91(5):967-70. [pmid: 8491945].
100 Malo JL, Cartier A. Occupational Reactions in the Seafood Industry. Clin Rev Allergy. 1993;11(2):223-40. [pmid: 8221510].
101 Malo JL, Cartier A, Lemiere C, et al. Exaggerated bronchoconstriction due to inhalation challenges with occupational agents. Eur Respir J. 2004;23:300-3. [pmid: 14979507].
102 Marek W, Marczynski B, Ammon J, et al. Blood gas changes in comparison to mechanical breathing parameters after workplace-related provocations with diisocyanates [German]. Atemw Lungenkrankh. 1994;20(8):454-6.
103 Marks GB, Salome CM, Woolcock AJ. Asthma and allergy associated with occupational exposure to ispaghula and senna products in a pharmaceutical work force. Am Rev Respir Dis. 1991;144(5):1065-9. [pmid: 1952432].
104 Merget R, Schultze-Werninghaus G, Bode F, et al. Quantitative skin prick and bronchial provocation tests with platinum salt. Br J Ind Med. 1991;48:830-7. [pmid: 1772797]. [pmcid: 1035464].
105 Mihalas LS. An approach to the diagnosis of occupational asthma. Ann Allergy Asthma Immunol. 1999;83:577-82. [pmid: 10619324].
106 Miller MR. Potential problems in peak expiratory flow data used to diagnose occupational asthma. Occup Med. 1996;46(3):239-41.
107 Moller DR, Mckay RT, Bernstein IL, et al. Persistent airways disease caused by toluene diisocyanate. Am Rev Respir Dis. 1986;134(1):175-6. [pmid: 3014935].
108 Moscato G. Features and severity of occupational asthma upon diagnosis: an Italian multicentric case review. Allergy. 2002;57:236-42. [pmid: 11906338].
109 Moscato G, Galdi E, Perfetti L. Early detection of occupational asthma and reactive airways dysfunction syndrome. Monaldi Arch Chest Dis. 2000;55(5):66-9. [pmid: 10786429].
110 Moscato G, Godnic-Cvar J, Maestrelli P, et al. Statement on self-monitoring of peak expiratory flow in the investigation of occupational asthma. Allergy. 1995;50(9):711-7. [pmid: 8546264].
111 Moscato G, Malo JL, Bernstein D. Series "Controversies in occupational asthma: Diagnosing occupational asthma: How, how much, how far?. Eur Respir J. 2003;21:879-85. [pmid: 12765438].
112 Musk AW, Peach S, Ryan G. Occupational asthma in a mineral analysis laboratory. Br J Ind Med. 1988;45:381-6. [pmid: 3395574]. [pmcid: 1009616].
113 Newman LS. Occupational asthma - diagnosis, management, and prevention. Clin Chest Med. 1995;16(4):621-36. [pmid: 8565404].
114 O'donnell TV. Chemical poisoning and occupational asthma: Diagnosis and/or acceptance for current compensation. N Z Med J. 1998;111(1074):372-3. [pmid: 11039833].
115 Paggario PL, Bacci E, Dente FL, et al. Prognosis of occupational asthma induced by isocyanates. Bull Eur Physiopathol Respir. 1988;23:565-9.
116 Palma-Carlos AG, Palma-Carlos ML. [Relation between bronchial sensitivity to provocation tests and reaction to later-histamine in asthma] [French]. Rev Fr Allergol. 1970;10(4):313-25. [pmid: 5517608].
117 Papenfuss F, Baur X, Kraus G. Allergy to silk [German]. Arbeitsmed Sozialmed Umweltmed. 2000;35(7):316-8.
118 Park HS, Cho SH, Hong CS, et al. Isocyanate-induced occupational asthma in far-east Asia: pathogenesis to prognosis. Clin Exp Allergy. 2002;32:198-204. [pmid: 11929482].
119 Park HS, Cho YS, Park JN, et al. Significant changes of bronchial responsiveness to methacholine after early asthmatic reaction to toluene diisocyanate tdi in a tdi-sensitive asthmatic worker. J Korean Med Sci. 1990;5(4):185-8. [pmid: 1966034].
120 Picon SJ, Carmona JGB, Del Mar Garces Sotillos M. Occupational asthma caused by vetch (Vicia sativa). J Allergy Clin Immunol. 1991;88(1):135. [pmid: 2071777].
121 Piirila P, Kanerva L, Alanko K, et al. Occupational IgE-mediated asthma, rhinoconjunctivitis, and contact urticaria caused by Easter lily (Lilium longiflorum) and tulip. Allergy. 1999;54:273-7. [pmid: 10321564].
122 Piirila PL, Nordman H, Keskinen HM, et al. Long-term follow-up of hexamethylene diisocyanate-, biphenylmethane diisocyanate-, and toluene diisocyanate-induced asthma. Am J Respir Crit Care Med. 2000;162(2):516-22. [pmid: 10934080].
123 Polio JC, Dalphin JC, Simon-Rigaud ML, et al. The diagnostic value of provocation tests with mouldy hay in occupational respiratory disease in dairy farmers [French]. Rev Med Interne. 1991;12(Suppl 3):S52.
124 Pouchelle C, Dewitte JD, Leroyer C, et al. Limit of peak-flow in occupational asthma: Concerning a case of asthma to formaldehyde [French]. Arch Mal Prof. 1989;50(8):838-9.
125 Quinn TJ, Donham KJ, Merchant JA, et al. Peak flow as a measure of airway dysfunction in swine confinement operators. Chest. 1995;107(5):1303-8. [pmid: 7750323].
126 Rabajin JT, Cowl CT. A guide to the diagnosis and treatment of occupational asthma. Mayo Clinic Proceedings. 2001;76(6):633-40. [pmid: 11393503].
127 Redlich CA, Cain H, Wisnewski AV. The immunology and prevention of isocyanate asthma: A model for low molecular weight asthma. Sem Respir Crit Care Med. 1999;20(6):591-9.
128 Reed CE. Clinical management when the environment can be changed. Chest. 1990;98(5 Suppl):216S-9S. [pmid: 2226014].
129 Reif VE. [What contribution is made by the individual methods of pulmonary function testing to the clinical judgment in the evaluation of occupational diseases] [German]. Zentralblatt Arbeitsmedizin Arbeitsschutz Erogon. 1967;17(8):240-3.
130 Renzetti AD Jr, Bleecker ER, Epler GB, et al. For the American Thoracic Society. Evaluation of impairment/disability secondary to respiratory disorders. Am Rev Respir Dis. 1986;133(6):1205-9. [pmid: 3509148].
131 Rischitelli DG. A workers' compensation primer. Ann Allergy Asthma Immunol. 1999;83:614-7. [pmid: 10619331].
132 Rosenthal RR. Workshop proceedings on bronchoprovocation techniques for the evaluation of asthma. J Allergy Clin Immunol. 1979;64(6 Part 2):561-692. [pmid: 512245].
133 Saia B, Marcer G, Mastrangelo G. [Specific bronchial provocation tests in the diagnosis of occupational lung diseases of allergic origin (author's transl)] [Italian]. Med Lav. 1980;71(1):48-61. [pmid: 7453642].
134 Sarlo K. Control of occupational asthma and allergy in the detergent industry. Ann Allergy Asthma Immunol. 2003;90(Suppl):32-4. [pmid: 12772949].
135 Savonius B, Keskinen H, Tuppurainen M, et al. Occupational asthma caused by ethanolamines. Allergy. 1994;49:877-81. [pmid: 7709998].
136 Schenker MB. Occupational asthma: Eight questions physicians often ask. Consultant 1991 Apr:74–7.
137 Schmidt-Nowara WW, Murphy RLH, Atkinson JD. Lung function after acute toluene di-isocyanate inhalation. Chest. 1973;63(6):1039-40. [pmid: 4711854].
138 Schultze-Werninghaus G, Rust M. Bronchial asthma and allergic alveolitis due to occupational allergens [German]. Allergolo J. 1988;11(11):437-45.
139 Schwartz HJ. Effect of chronic chromolyn sodium therapy in a beautician with occupational asthma. J Occup Med. 1989;31(2):112-4. [pmid: 2496209].
140 SHP News. Company had a duty to dismiss employee suffering from occupational asthma. The Safety & Health Practitioner 2002 Dec:3.
141 Smith AB, Bernstein DI, Aw TC, et al. Occupational asthma from inhaled egg protein [erratum appears in Am J Med 1988;13(4):527]. Am J Ind Med. 1987;12(2):205-18. [pmid: 3661573].
142 Smith AB, Brooks SM, Blanchard J, et al. Absence of airway hyper reactivity to methacholine in a worker sensitized to toluene di iso cyanate. J Occup Med. 1980;22(5):327-31. [pmid: 6247471].
143 Soderlund N, Rees D, Wasserfall C, et al. A survey of a small group of workers exposed to toluene di-isocyanate. S Afr Med J. 1993;83(2):100-3. [pmid: 8383881].
144 Tabar AI, Alvarez MJ, Acero S, et al. Reactive Airways Dysfunction Syndrome: Two Case Reports. J Investig Allergol Clin Immunol. 1998;8(2):119-22.
145 Tabar-Purroy AI, Alvarez-Puebla MJ, Acero-Sainz S, et al. Carmine (E-120)-Induced Occupational Asthma Revisited. J Allergy Clin Immunol. 2003;111(2):415-9. [pmid: 12589365].
146 Tan R, Spector SL. Diagnostic testing in occupational asthma. Ann Allergy Asthma Immunol. 1999;83(6 Pt 2):587-92. [pmid: 10619326].
147 Tan RA, Spector SL. Provocation studies in the diagnosis of occupational asthma. Immunol Allergy Clin North Am. 2003;23(2):251-66. [pmid: 12803362].
148 Tarlo SM. Recent advances in occupational asthma. Curr Opin Pulm Med. 2000;6:145-50. [pmid: 10741775].
149 Tarlo SM, Boulet LP, Cartier A, et al. Canadian Thoracic Society guidelines for occupational asthma. Can Respir J. 1998;5(4):289-300. [pmid: 9753529].
150 Tarlo SM, Liss G. Highlights of the Canadian Thoracic Society guidelines for occupational asthma. Can Fam Physician. 1999;45:1541-4. [pmid: 10386219]. [pmcid: 2328447].
151 Tarlo SM, Liss GM. Can medical surveillance measures improve the outcome of occupational asthma?. J Allergy Clin Immunol. 2001;107(4):583-5. [pmid: 11295642].
152 Tarlo SM, Liss GM. Diisocyanate-induced asthma: Diagnosis, prognosis, and effects of medical surveillance measures. Appl Occup Environ Hyg. 2002;17(12):902-8. [pmid: 12495601].
153 Tee RD, Gordon DJ, Lacey J, et al. Occupational allergy to the common house fly (Musca domestica): Use of immunologic response to identify atmospheric allergen. J Allergy Clin Immunol. 1985;76:826-31. [pmid: 4067132].
154 Turato G, Saetta M. Why does airway obstruction persist in asthma due to low-molecular-weight agents? A pathologist's view. Occup Med. 2000;15(2):445-53. [pmid: 10769349].
155 Vandenplas O, Malo JL. Inhalation challenges with agents causing occupational asthma. Eur Respir J. 1997;10(11):2612-29. [pmid: 9426105].
156 Vandenplas O, Toren K, Blanc PD. Health and socioeconomic impact of work-related asthma. Eur Respir J. 2003;22(4):689-97. [pmid: 14582924].
157 Vanderslice R, Bibeault L. Asthma and the environment: A physician's guide to resources, research and data. Med Health. 1999;82(7):255-9.
158 Voelker R. Latex-induced asthma among health care workers. JAMA. 1995;273(10):764. [pmid: 7861555].
159 Waldburger R, Hofmann M, Ruegger M, et al. Peak Flow profile and expert evidence: The significance of self-measured peak flow in expert evidence on pulmonary function. Schweiz Med Wochenschr. 1992;122(29):1070-8. [pmid: 1386475].
160 Wallenstein G, Rebohle E, Bergmann I. Experiences with the provocative inhalation test in occupationally induced allergic diseases of the respiratory tract. Allergie u Immunol. 1979;25:140-5.
161 Wass U, Belin L, Eriksson NE. Immunological specificity of chloramine-T-induced IgE antibodies in serum from a sensitized worker. Clin Exp Allergy. 1989;19:463-71. [pmid: 2758361].
162 Weiss ST. A framework for assessing impairment from asthma. Chest. 1990;98(5):225S-31S. [pmid: 2226015].
163 Weissman DN, Lewis DM. Is specific antibody determination diagnostic for asthma attributable to low-molecular-weight agents?. Occup Med. 2000;15(2):385-97. [pmid: 10769344].
164 Wittczak T, Walusiak J, Krakowiak A, et al. Occupational asthma and interstitial cobalt-induced changes in a dental technician: A case report [Zlozona postac kobaltozy (zmiany srodmiazszowe i astma oskrzelowa) u technika dentystycznego: Opis przypadku klinicznego] Czechoslovakian. Medycyna-Pracy. 2003;54(2):159-64. [pmid: 12923999].

### Inappropriate Topic

1 Abramson MJ, Hensley MJ, Saunders NA, et al. Evaluation of a new asthma questionnaire. J Asthma. 1991;28(2):129-39. [pmid: 2013560].
2 Adams WG. Long-term effects on the health of men engaged in the manufacture of toluene diisocyanate. Br J Ind Med. 1975;32:72-8. [pmid: 164881]. [pmcid: 1008026].
3 Alanko K. Farmer's lung--an acute or chronic disease?. Scand J Respir Dis. 1970;72(Supple):120-6.
4 Alberts WM. Using inhalation challenge tests to evaluate occupational asthma. J Respir Dis. 1999;20(7):464-5.
5 Alberts WM, Ramsdell JW. Bronchial provocation testing in occupational asthma. Respir Ther. 1983;13(2):41-2.
6 Allmers H, Chen Z, Barbinova L, et al. Challenge from methacholine, natural rubber latex, or 4,4′-diphenylmethane diisocyanate in workers with suspected sensitization affects exhaled nitric oxide [change in exhaled NO levels after allergen challenges]. Int Arch Occup Environ Health. 2000;73(3):181-6. [pmid: 10787133].
7 American Thoracic Society. Guidelines for the evaluation of impairment/disability in patients with asthma. Am Rev Respir Dis. 1993;147:1056-61. [pmid: 8466106].
8 Andersen P, Schonheyder H. Antibodies to hen and duck antigens in poultry workers. Clin Allergy. 1984;14:421-8. [pmid: 6488512].
9 Anees W, Huggin SV, Burge S. Peak expiratory flow records for the diagnosis of occupational asthma: the effect of data quantity on diagnostic sensitivity and specificity. Eur Respir Society 2001.
10 Anees W, Huggin SV, Pavord ID, et al. Occupational asthma due to low molecular weight agents: eosinophilic and non-eosinophilic variants. Thorax. 2002;57(3):231-36. [pmid: 11867827]. [pmcid: 1746281].
11 Anees W, Sibblies S, Spencer S et al. Fev1 decline in workers with occupational asthma in response to continued workplace exposure. American Thoracic Society 2002.
12 Anibarro B, Fontela JL, De La Hoz F. Occupational asthma induced by garlic dust. J Allergy Clin Immunol. 1997;100(6 Pt 1):734-8. [pmid: 9438479].
13 Aul DJ, Bhaumik A, Kennedy AL, et al. Specific IgG response to monomeric and polymeric diphenylmethane diisocyanate conjugates in subjects with respiratory reactions to isocyanates. J Allergy Clin Immunol. 1999;103(5 Pt 1):749-55. [pmid: 10329805].
14 Baldwin DR, Gannon P, Bright P, et al. Interpretation of occupational peak flow records: level of agreement between expert clinicians and Oasys-2. Thorax. 2002;57(10):860-4. [pmid: 12324671]. [pmcid: 1746200].
15 Bardy JD, Malo JL, Seguin P, et al. Occupational asthma and IgE sensitization in a pharmaceutical company processing psyllium. Am Rev Respir Dis. 1987;135(5):1033-8. [pmid: 3579003].
16 Barker RD, van Tongeren MJ, Harris JM, et al. Risk factors for bronchial hyperresponsiveness in workers exposed to acid anhydrides. Eur Respir J. 2000;15:710-5. [pmid: 10780763].
17 Baur X. Nasal challenge tests with flour extracts [German]. Allergologie. 1993;16(12):507-9.
18 Baur X, Chen Z, Flagge A, et al. EAST and CAP specificity for the evaluation of IgE and IgG antibodies to diisocyanate-HSA conjugates. Int Arch Allergy Immunol. 1996;110(4):332-8. [pmid: 8768800].
19 Belin L, Wass U, Audunsson G, et al. Amines: Possible causative agents in the development of bronchial hyperreactivity in workers manufacturing polyurethanes from isocyanates. Br J Ind Med. 1983;40(3):251-7. [pmid: 6307337]. [pmcid: 1069319].
20 Beritic-Stahuljak D, Valic F, Cigula M, et al. Aerosol analysis, respiratory function and skin sensitivity testing in workers exposed to soft and hardwood dust. Arhiv Za Higijenu Rada i Toksikologiju. 1988;39(4):387-403. [pmid: 3273129].
21 Bernstein DI, Korbee L, Stauder T, et al. The low prevalence of occupational asthma and antibody-dependent sensitization to diphenylmethane diisocyanate in a plant engineered for minimal exposure to diisocyanates. J Allergy Clin Immunol. 1993;92:387-96. [pmid: 8360389].
22 Berren SL, Edwards JH. Antibodies to bird serum proteins in confectionery workers exposed to egg spray. Clin Allergy. 1987;17:405-8. [pmid: 3119251].
23 Berube D, Cartier A, L'Archeveque J, et al. Comparison of peak expiratory flow rate and FEV1 in assessing bronchomotor tone after challenges with occupational sensitizers. Chest. 1991;99(4):831-6. [pmid: 2009783].
24 Bohadana AB, Massin N, Teculescu D, et al. Tracheal wheezes during methacholine airway challenge (MAC) in workers exposed to occupational hazards. Respir Med. 1994;88(8):581-7. [pmid: 7991882].
25 Boschetto P, Fabbri LM, Zocca E, et al. Prednisone inhibits late asthmatic reactions and airway inflammation induced by toluene diisocyanate in sensitized subjects. J Allergy Clin Immunol. 1987;80:261-7. [pmid: 3040835].
26 Brooks SM, Baker DB, Gann PH, et al. Cold air challenge and platinum skin reactivity in platinum refinery workers. Bronchial reactivity precedes skin prick response. Chest. 1990;97(6):1401-7. [pmid: 2347226].
27 Brooks SM, McCluskey JD. When to suspect reactive airways dysfunction syndrome: preexisting asthma rules out the diagnosis of RADS. J Respir Dis. 2002;23(10):506-14.
28 Chai H, Farr RS, Froehlich LA, et al. Standardization of bronchial inhalation challenge procedures. J Allergy Clin Immunol. 1975;56(4):323-7. [pmid: 1176724].
29 Choudat D, Villette C, Tabka F, et al. Dose-response to flour in occupational asthma [French]. Arch Mal Prof. 1998;59(6):417-8.
30 Cipolla C, Lugo G, Sassi C, et al. A new risk of occupational disease: allergic asthma and rhinoconjunctivitis in persons working with beneficial arthropods. Int Arch Occup Environ Health. 1996;68(2):133-5. [pmid: 8720284].
31 Cloutier Y, Lagier F, Lemieux R, et al. New methodology for specific inhalation challenges with occupational agents in powder form. Eur Respir J. 1989;2(8):769-77. [pmid: 2806499].
32 Conrad E, Lo W, deBoisblanc B, et al. Reactive airways dysfunction syndrome after exposure to dinitrogen tetroxide. South Med J. 1998;91(4):338-42. [pmid: 9563423].
33 Cross D, Nelson HS. The role of the peak flow meter in the diagnosis and management of asthma. J Allergy Clin Immunol. 1991;87(1):120-8. [pmid: 1825099].
34 Cullen MR, Redlich CA, Beckett WS, et al. Feasibility study of respiratory questionnaire and peak flow recordings in autobody shop workers exposed to isocyanate-containing spray paint: observations and limitations. Occup Med. 1996;46:197-204.
35 Curran AD. Flow cytometry in the exploration of the physiopathology of occupational lung disease. Occup Environ Med. 1999;56:742-6. [pmid: 10658559]. [pmcid: 1757683].
36 Dykewicz MS, Fineman S. Executive summary of Joint Task Force Practice Parameters on Diagnosis and Management of Rhinitis. Ann Allergy Asthma Immunol. 1998;81(Part II):463-8. [pmid: 9860024].
37 Dykewicz MS, Fineman S, Skoner DP, et al. Diagnosis and management of rhinitis: Complete guidelines of the Joint Task Force on Practice Parameters in Allergy, Asthma and Immunology. Ann Allergy Asthma Immunol. 1998;81:478-518. [pmid: 9860027].
38 Edwards JH, McConnochie K, Trotman DM, et al. Allergy to inhaled egg material. Clin Allergy. 1983;13(5):427-32. [pmid: 6627620].
39 Eisen EA, Wegman DH, Louis TA. Effects of selection in a prospective study of forced expiratory volume in Vermont granite workers. Am Rev Respir Dis. 1983;128:587-91. [pmid: 6625337].
40 Enarson DA, Vedal S, Schulzer M, et al. Asthma, asthmalike symptoms, chronic bronchitis, and the degree of bronchial hyperresponsiveness in epidemiologic surveys. Am Rev Respir Dis. 1987;136(3):613-7. [pmid: 3498414].
41 Fabries JF, Choudat D, Wrobel R, et al. Computerized equipment for the delivery of inhaled doses of solid particles in specific bronchial challenge. J Aerosol Med. 2000;13(1):1-10. [pmid: 10947318].
42 Finnegan MJ, Little S, Gordon DJ, et al. The effect of smoking on the development of allergic disease and specific immunological responses in a factory workforce exposed to humidifier contaminants. Br J Ind Med. 1991;48(1):30-3. [pmid: 1993157]. [pmcid: 1035308].
43 Fourgaut G, Popin E, Kopferschmitt MC, et al. Baker's asthma: Clinical study of 27 cases and the need for a decisional algorithm [French]. Rev Fr Allergol Immunol Clin. 2002;42:633-9.
44 Franklin PJ, Goldenberg WS, Ducatman AM, et al. Too hot to handle: An unusual exposure of HDI in specialty painters. Am J Ind Med. 2000;37(4):431-7. [pmid: 10706755].
45 Gautrin D, Boulet LP, Boutet M, et al. Is reactive airways dysfunction syndrome a variant of occupational asthma?. J Allergy Clin Immunol. 1994;93:12-22. [pmid: 8308178].
46 Gautrin D, Ghezzo H, Infante-Rivard C, et al. Natural history of sensitization, symptoms and occupational diseases in apprentices exposed to laboratory animals. Eur Respir J. 2001;17(5):904-8. [pmid: 11488324].
47 Godnic-Cvar J, Plavec D, Jovanovic J. Moving average - An objective assessment of peak expiratory flow rate monitoring records in diagnosing occupational asthma. Atemw-Lungenkrkh Jahrgang. 1994;20(Suppl 1):S67-S9.
48 Godnic-Cvar J, Plavec D, Somogyi-Zalud E, et al. Non-specific nasal and bronchial reactivity are not correlated in non- asthmatic subjects occupationally exposed to irritants and in healthy subjects. Am J Ind Med. 1999;35(4):426-31. [pmid: 10086204].
49 Goldstein MF, Veza BA, Dunsky EH, et al. Comparisons of peak diurnal expiratory flow variation, postbronchodilator Fev1 responses, and methacholine inhalation challenges in the evaluation of suspected asthma. Chest. 2001;119(4):1001-10. [pmid: 11296161].
50 Gordon SB, Curran AD, Murphy J, et al. Screening questionnaires for bakers' asthma--are they worth the effort?. Occup Med. 1997;47(6):361-6.
51 Gorski P. Nasal provocation test in diagnosis of occupational allergy. Int Rev Allergol Clin Immunol. 2002;8(2):81-6.
52 Grammer L, Shaughnessy M, Kenamore B. Utility of antibody in identifying individuals who have or will develop anhydride-induced respiratory disease. Chest. 1998;114(4):1199-202. [pmid: 9792595].
53 Grammer LC, Shaughnessy M, Hogan MB, et al. Value of antibody level in diagnosing anhydride-induced immunologic respiratory disease. J Lab Clin Med. 1995;125(5):650-3. [pmid: 7738429].
54 Grammer LC, Shaughnessy MA, Lowenthal M, et al. Risk factors for immunologically mediated disease in workers with respiratory symptoms when exposed to hexahydrophthalic anhydride. J Lab Clin Med. 1996;127(5):443-7. [pmid: 8621981].
55 Hadjiliadis D, Khan K, Tarlo SM. Skin test responses to latex in an allergy and asthma clinic. J Allergy Clin Immunol. 1995;96(3):431-2. [pmid: 7560650].
56 Hankinson JL. Beyond the peak flow meter: Newer technologies for determining and documenting changes in lung function in the workplace. Occup Med. 2000;15(2):411-9. [pmid: 10769346].
57 Harber P, Scanlon PD, do Pico G, et al. Role of chest physicians in detection and treatment of occupational and environmental respiratory disease: a practice survey. Chest. 1995;107:1156-61. [pmid: 7705130].
58 Hargreave FE, Ryan G, Thomson C, et al. Bronchial responsiveness to histamine or methacholine in asthma: measurement and clinical significance. Eur J Respir Dis. 1982;121(Suppl):79-88.
59 Hendrick DJ. Epidemiological measurement of bronchial responsiveness in polyurethane workers. Bull Eur Physiopathol Respir. 1987;23(6):555-9. [pmid: 2840137].
60 Hendrick DJ, Fabbri LM, Hughes JM, et al. Modification of the methacholine inhalation test and its epidemiologic use in polyurethane workers. Am Rev Respir Dis. 1986;133:600-4. [pmid: 3516038].
61 Henneberger PK, Stanbury MJ, Trimbath LS, et al. The use of portable peak flowmeters in the surveillance of occupational asthma. Chest. 1991;100(6):1515-21. [pmid: 1835690].
62 Hollander A, Heederik D, Brunekreef B. Work-related changes in peak expiratory flow among laboratory animal workers. Eur Respir J. 1998;11:929-36. [pmid: 9623699].
63 Huy T, De Schipper K, Chan-Yeung M, et al. Grain dust and lung function: Dose-response relationships. Am Rev Respir Dis. 1991;144:1314-21. [pmid: 1741544].
64 Innocenti A, Cirla AM, Pisati G, et al. Cross-reaction between aromatic isocyanates (TDI and MDI): a specific bronchial provocation test study. Clin Allergy. 1988;18(4):323-9. [pmid: 2843304].
65 Iversen M, Pedersen B, Dahl R. Relationship between respiratory symptoms and bronchial hyperreactivity in pig farmers. Am J Ind Med. 1990;17(1):64-5. [pmid: 2305792].
66 Jedrychowski W, Jagielsk E, Ksiezyk M. [Correlation between FEV 0 75 and FEV 1 0 in the populations at 2 different places of employment] [Polish]. Przeglad. 1971;27(4):314-6.
67 Juniper EF, Frith P, Dunnett C, et al. Reproducibility and comparison of responses to inhaled histamine and methacholine. Thorax. 1978;33:705-10. [pmid: 746496]. [pmcid: 470967].
68 Karol MH, AlarieY. Antigens which detect IgE antibodies in workers sensitive to toluene diisocyanate. Clin Allergy. 1980;10:101-9. [pmid: 6244907].
69 Kopferschmitt-Kubler MC, Pauli G. [Specific provocation tests] French. Rev Pneumol Clin. 1991;47(4):171-6. [pmid: 1775873].
70 Kowalska S, Krakowiak A, Sulkowski W, et al. Nasal lavage, rhinomanometry and rhinoscopy in diagnosing occupational airway allergy. Otolaryngologia Polska. 2001;3:279-86.
71 Kurtz JM, Hamilton RG, Schaefer JA, et al. A hooded exposure chamber method for semiquantitative latex aeroallergen challenge. J Allergy Clin Immunol. 2001;107:178-4. [pmid: 11150009].
72 Kus J, Krakowka P. The effectiveness of nasal provocation tests for the diagnosis of atopic bronchial asthma. Allergol Immunopathol. 1983;11(4):233-41.
73 Kus L, Milanowski J, Fafrowicz B. [Significance of exposure tests in diagnosis of occupational asthma] [Polish]. Pneumonol Pol. 1990;58(78):370-3. [pmid: 8614662].
74 Lee HS. Serial peak expiratory flow rate monitoring: A useful tool in epidemiological studies on occupational asthma. Ann Acad Med Singapore. 1994;23(5):725-30. [pmid: 7847754].
75 Liss GM, Bernstein D, Genesove L, et al. Assessment of risk factors for IgE-mediated sensitization to tetrachlopophthalic anhydride. J Allergy Clin Immunol. 1993;92:237-47. [pmid: 8349934].
76 Malo JL, Cartier A, Ghezzo H, et al. Compliance with peak expiratory flow readings affects the within- and between-reader reproducibility of interpretation of graphs in subjects investigated for occupational asthma. J Allergy Clin Immunol. 1996;98(6 Pt 1):1132-4. [pmid: 8977521].
77 Malo JL, Ghezzo H, Elie R. Occupational asthma caused by isocyanates: Patterns of asthmatic reactions to increasing day-to-day doses. Am J Respir Crit Care Med. 1999;159:1879-83. [pmid: 10351934].
78 Malo JL, L'Archeveque J, Trudeau C, et al. Should we monitor peak expiratory flow rates or record symptoms with a simple diary in the management of asthma?. J Allergy Clin Immunol. 1993;91(3):702-9. [pmid: 8454792].
79 Malo JL, Pineau L, Cartier A, et al. Reference values of the provocative concentrations of methacholine that cause 6% and 20% changes in forced expiratory volume in 1 second in a normal population. Am Rev Respir Dis. 1983;128:8-11. [pmid: 6870071].
80 Malo JL, Trudeau C, Ghezzo H, et al. Do subjects investigated for occupational asthma through serial peak expiratory flow measurements falsify their results. J Allergy Clin Immunol. 1995;96(5):601-7. [pmid: 7499676].
81 Mapp C, Dal Vecchio L, Boschetto P, et al. Toluene dissocyanate-induced asthma without airway hyperresponsiveness. Eur Respir J. 1986;68:89-95.
82 Marin-Blazquez MF, Abad IG, Puente PH, et al. [Occupational asthma] [Spanish]. Atención Primaria. 1995;15(1):33-5.
83 Mastrangelo G, Bombana S, Priante E, et al. Repeated case-control studies as a method of surveillance for asthma in occupations. J Occup Environ Med. 1997;39(1):51-7. [pmid: 9029431].
84 Merget R, Caspari C, Dierkes-Globisch A, et al. Effectiveness of a medical surveillance program for the prevention of occupational asthma caused by platinum salts: A nested case-control study. J Allergy Clin Immunol. 2001;107(4):707-12. [pmid: 11295662].
85 Merget R, Caspari C, Korb-Bangang A, et al. Spontaneous variability of the bronchial histamine reactivity in chemical industry workers [German]. Atemwegs- und Lungenkrankheiten. 1994;20(8):441-2.
86 Monkare S, Haahtela T, Vilkka V et al. A double blind-trial comparing the clinical efficacy of DSCG and placebo in prophylaxis of farmer's lung.:473.
87 Moscato G, Danna P, Dorigo N, et al. Effect of nifedipine on hyperreactive bronchial responses to methacholine. Ann Allergy. 1986;56:145-9. [pmid: 3946848].
88 Navratil M, Lebedova J. Unfavourable reactions after inhalations tests in the evaluation of occupational character of bronchial asthma. Cheche. Prac Lek. 1985;37(4):130-2.
89 Nemery B, Van Leemputten R, Goemaere E, et al. Lung-function measurements over 21 days shiftwork in steelworkers from a strandcasting department. Br J Ind Med. 1985;42(9):601-11. [pmid: 4041389]. [pmcid: 1007542].
90 Nguyen B, Weytjens K, Cloutier Y, et al. Determinants of the bronchial response to high molecular weight occupational agents in a dry aerosol form. Eur Respir J. 1998;12:885-8. [pmid: 9817163].
91 Norrish AE, Beasley R, Hodgkinson EJ, et al. A study of New Zealand wood workers - exposure to wood dust, respiratory symptoms, and suspected cases of occupational asthma. N Z Med J. 1992;105(934):185-7. [pmid: 1625823].
92 Oliver LC. Occupational and environmental asthma: Legal and ethical aspects of patient management. Chest. 1990;98(5Supp):220S-224S. [pmid: 2146094].
93 Ortega HG, Weissman DN, Carter DL, et al. Use of specific inhalation challenge in the evaluation of workers at risk for occupational asthma: A survey of pulmonary, allergy, and occupational medicine residency training programs in the United States and Canada. Chest. 2002;121(4):1323-28. [pmid: 11948069].
94 Ostapkovich VE, Pankova VB. [Diagnosis of pre-asthmatic conditions in workers in chemical plants][Russian]. Vestn Otorinolaringol 1980;(6):64–7.
95 Panzani R, Johansson SGO. Results of skin test and RAST in allergy to a clinically potent allergen (castor bean). Clin Allergy. 1986;16:259-66. [pmid: 3719938].
96 Perdrix A, Gauthier-David F, Romazini S, et al. Asthme professionnel Intéret de la débitmétrie de longue durée pour l'approche diagnostique individuelle [Occupational asthma Interest of a longitudinal peak flow trend for an individual diagnosis] [French]. Arch Mal Prof. 1992;53(2):103-9.
97 Perfetti L, Brame B, Ferrari M, et al. Occupational asthma (OA) with sensitization to diphenylmethane diisocyanate (MDI) presenting at the onset like a reactive airways dysfunction syndrome (RADS). Am J Ind Med. 2003;44:325-8. [pmid: 12929154].
98 Phillips VL, Goodrich M, Sullivan TJ. Health care worker disability due to latex allergy and asthma: A cost analysis. Am J Public Health. 1999;89(7):1024-8. [pmid: 10394310]. [pmcid: 1508827].
99 Pickering CA. Inhalation tests with chemical allergens: complex salts of platinum. Proc R Soc Med. 1972;65(3):272-4. [pmid: 5083317]. [pmcid: 1644009].
100 Piipari R, Keskinen H, Nordman H. Experiences of exhaled nitric oxide measurements in diagnostics of occupational asthma. Eur Respir Society 2001.
101 Portengen L, Hollander A, Doekes G, et al. Lung function decline in laboratory animal workers: The role of sensitisation and exposure. Occup Environ Med. 2003;60(11):870-5. [pmid: 14573718]. [pmcid: 1740423].
102 Promisloff RA, Lenchner GS, Phan A, et al. Reactive airway dysfunction syndrome in three police officers following a roadside chemical spill. Chest. 1990;98:928-9. [pmid: 2209150].
103 Quirce S, Contreras G, Dybuncio A, et al. Peak expiratory flow monitoring is not a reliable method for establishing the diagnosis of occupational asthma. Am J Respir Crit Care Med. 1995;152(3):1100-2. [pmid: 7663790].
104 Revsbech P, Andersen G. Diurnal variation in peak expiratory flow rate among grain elevator workers. Br J Ind Med. 1989;46(8):566-9. [pmid: 2775676]. [pmcid: 1009827].
105 Ryan G, Dolovich MGB, Roberts RS, et al. Standardization of inhalation provocation tests: Two techniques of aerosol generation and inhalation compared. Am Rev Respir Dis. 1981;123:195-9. [pmid: 7235358].
106 Saak A, Lenaerts-Langanke H, Stresemann E. Specific IgE, IgG and IgG4 antibodies in allergic asthma due to isocyanate as compared to test persons and employees of different occupational groups exposed to isocyanate [German]. Zbl Arbeitsmed. 1996;46(9):326-37.
107 Sarlo K, Clark ED, Ryan CA, et al. ELISA for human IgE antibody to subtilisin A (Alcalase): Correlation with RAST and skin test results with occupationally exposed individuals. J Allergy Clin Immunol. 1990;86:393-99. [pmid: 2212411].
108 Schiller-Fruhwirth I. RADS - Occupational irritant-induced asthma - BK 41 [German]. Atemw-Lungenkrkh Jahrgang. 2002;28(6):311-3.
109 Schultebraucks R, Frank W, Loddenkemper R. Investigation of gastransfer in non-specific bronchial challenge [German]. Pneumologie. 1990;44(1):362-3. [pmid: 2367417].
110 Shapiro SM, Hendler JM, Ogirala RG, et al. An evaluation of the accuracy of Assess and Mini-Wright peak flowmeters. Chest. 1991;99:358-62. [pmid: 1989795].
111 Sheffer A, Taggart V. The National Asthma Education Program: Expert panel report guidelines for the diagnosis and management of asthma. Med Care 1993;31(3):MS20–28 Suppl.
112 Tarlo SM, Easty A, Eubanks K, et al. Outcomes of a natural rubber latex control program in an Ontario teaching hospital. J Allergy Clin Immunol. 2001;108:628-33. [pmid: 11590392].
113 Townley RG, Bewtra AK, Nair NM, et al. Methacholine inhalation challenge studies. J Allergy Clin Immunol. 1979;64(6, pt 2):569-74. [pmid: 512247].
114 Vandenplas O, Cartier A, Ghezzo H, et al. Response to isocyanates: Effect of concentration, duration of exposure and dose. Am Rev Respir Dis. 1993;147:1290-3.
115 Vandenplas O, Delwiche JP, Jamart J, et al. Increase in non-specific bronchial hyperresponsiveness as an early marker of bronchial response to occupational agents during inhalation challenges. Thorax. 1996;51:472-8. [pmid: 8711673]. [pmcid: 473590].
116 Vandenplas O, Malo JL, Cartier A, et al. Closed-circuit methodology for inhalation challenge tests with isocyanates. Am Rev Respir Dis. 1992;145(3):582-7. [pmid: 1546838].
117 Vedal S, Chan-Yeung M, Enarson D, et al. Symptoms and pulmonary function in western red cedar workers related to duration of employment and dust exposure. Arch Environ Health. 1986;41(3):179-83. [pmid: 3740958].
118 Venables KM, Burge PS, Davison AG, et al. Peak flow rate records in surveys: Reproducibility of observers' reports. Thorax. 1984;39:828-32. [pmid: 6505990]. [pmcid: 459932].
119 Wass U, Belin L. Immunologic specificity of isocyanate-induced IgE antibodies in serum from 10 sensitized workers. J Allergy Clin Immunol. 1989;83:126-35. [pmid: 2536411].
120 Wass U, Nilssn R, Nordinder R, et al. An optimized assay of specific IgE antibodies to reactive dyes and studies of immunologic responses in exposed workers. J Allergy Clin Immunol. 1990;85:642-8. [pmid: 2312995].
121 Wergeland E, Lund E, Waage JE. Respiratory dysfunction after potroom asthma. Am J Ind Med. 1987;11(6):627-36. [pmid: 3605101].
122 Weytjens K, Malo JL, Cartier A, et al. Comparison of peak expiratory flows and FEV1 in assessing immediate asthmatic reactions due to occupational agents. Allergy. 1999;54(6):621-5. [pmid: 10435478].
123 Winck JC, Delgado L, Vanzeller M, et al. Monitoring of Peak Expiratory Flow Rates in Cork Workers' Occupational Asthma. J Asthma. 2001;38(4):357-62. [pmid: 11456389].
124 Zock JP, Brederode D, Heederik D. Between- and within-observer agreement for expert judgment of peak flow graphs from a working population. J Occup Environ Med. 1998;40(11):969-72. [pmid: 9830603].

### Population

1 Alexandersson R, Hedenstierna G. Pulmonary function in wood workers exposed to formaldehyde: A prospective study. Arch Environ Health. 1989;44(1):5-11. [pmid: 2916856].
2 Amaducci S, Arossa W, Mastrangelo G, et al. [Survey on the sensitivity and reproducibility of forced expiration indices used in epidemiological investigations of obstructive lung disease carried out at local occupational health centres (author's transl)] [Italian]. Med Lav. 1979;70(4):266-75. [pmid: 545107].
3 Ameille J, Villoingt L. [Valeur pronostique de l'hyperréactivité bronchique chez des peintres automobiles exposés aux isocyanates] Prognostic value of bronchial hyperresponsiveness in car painters exposed to isocyanates [French]. Arch Mal Prof. 1994;55(5):317-21.
4 Baldo BA, Krilis S, Wrigley CW. Hypersensitivity to inhaled flour allergens. Ann Allergy. 1980;35:45-56.
5 Baur X, Czuppo A. Diagnostic validation of specific IgE antibody concentrations, skin prick testing, and challenge tests in chemical workers with symptoms of sensitivity to different anhydrides. J Allergy Clin Immunol. 1995;96:489-94. [pmid: 7560660].
6 Baur X, Konig G, Bencze K, et al. Clinical symptoms and results of skin test, RAST and bronchial provocation test in thirty-three papain workers: evidence for strong immunogenic potency and clinically relevant ‘proteolytic effects of airborne papain’. Clin Allergy. 1982;12(1):9-17. [pmid: 7039863].
7 Belin LGA, Norman PS. Diagnostic tests in the skin and serum of workers sensitized to Bacillus subtilis enzymes. Clin Allergy. 1977;7:55-68. [pmid: 406100].
8 Berlin CM. Challenges in conducting pediatric drug trials. J Allergy Clin Immunol. 2000;106:S125-27. [pmid: 10984392].
9 Bernstein DI, Patterson R, Zeiss CR. Clinical and immunologic evaluation of trimellitic anhydride-and phthalic anhydride-exposed workers using a questionnaire with comparative analysis of enzyme-linked immunosorbent and radioimmunoassay studies. J Allergy Clin Immunol. 1982;69(3):311-8. [pmid: 7061772].
10 Bernstein DI, Zeiss CR, Wolkonsky P, et al. The relationship of total serum IgE and blocking antibody in trimellitic anhydride--induced occupational asthma. J Allergy Clin Immunol. 1983;72(6):714-9. [pmid: 6643876].
11 Bohadana AB, Peslin R, Megherbi SE, et al. Dose-response slope of forced oscillation and forced expiratory parameters in bronchial challenge testing. Eur Respir J. 1999;13(2):295-300. [pmid: 10065671].
12 Brisman J, Lillienberg L, Belin L, et al. Sensitisation to occupational allergens in bakers' asthma and rhinitis: a case-referent study. Int Arch Occup Environ Health. 2003;76:167-70. [pmid: 12733091].
13 Burge PS, Finnegan M, Horsefield N, et al. Occupational asthma in a factory with a contaminated humidifier. Thorax. 1985;40:248-54. [pmid: 4023974]. [pmcid: 460041].
14 Chatham M, Bleecker ER, Norman P, et al. A screening test for airways reactivity: an abbreviated methacholine inhalation challenge. Chest. 1982;82(1):15-8. [pmid: 7083928].
15 Cockcroft DW, Berscheid BA. Measurement of responsiveness to inhaled histamine: comparison of FEV1 and SGaw. Ann Allergy. 1983;51:374-7. [pmid: 6614600].
16 Cockcroft DW, Murdock KY, Kirby J, et al. Prediction of airway responsiveness to allergen from skin sensitivity to allergen and airway responsiveness to histamine. Am Rev Respir Dis. 1987;135:264-7. [pmid: 3800152].
17 de Jong NW, Vermeulen AM, Gerth van Wijk R, et al. Occupational allergy caused by flowers. Allergy. 1998;53(2):204-9. [pmid: 9534922].
18 Dolovich J, Little DC. Correlates of skin test reactions to bacillus-subtilis enzyme preparations. J Allergy Clin Immunol. 1972;49(1):43-53. [pmid: 4257104].
19 El-Zein M, Malo JL, Infante-Rivard C, et al. Incidence of probable occupational asthma and changes in airway calibre and responsiveness in apprentice welders. Eur Respir J. 2003;22:513-8. [pmid: 14516144].
20 Gobba F, Ghittori S, Imbriani M, et al. Evaluation of half-mask respirator protection in styrene-exposed workers. Int Arch Occup Environ Health. 2000;73:56-60. [pmid: 10672492].
21 Gorski P, Bilewicz P, Krakowiak A. [Objective evaluation of respiratory ventilation at work by measuring peak expiratory flow rate (PEFR)] [Polish]. Medycyna Pracy. 1992;43:1-5. [pmid: 1635441].
22 Gorski P, Krakowiak A, Pazdrak K, et al. Nasal challenge test in the diagnosis of allergic respiratory diseases in subjects occupationally exposed to a high molecular allergen (flour). Occup Med. 1998;48(2):91-7.
23 Hadjiliadis D, Banks DE, Tarlo SM. The relationship between latex skin prick test responses and clinical allergic responses. J Allergy Clin Immunol. 1996;97(6):1202-6. [pmid: 8648013].
24 Hilvering C, de Vries K, Orie NG. [Farmer's lung;respiratory function, allergological and serological tests including inhalation tests] [Dutch]. Ned Tijdschr Geneeskd. 1966;110(29):1297-307. [pmid: 5944132].
25 Huggin SV, Anees W, Blainey D et al. Grain workers: relationship between serial peak expiratory flow measurements, symptoms and lung function. Eur Respir Society 2002.
26 Ivanova IS. [Allergic skin tests in cotton spinners] [Russian]. Gig Tr Prof Zabol. 1966;10(5):48. [pmid: 5990604].
27 Karol MH. Concentration-dependent immunologic response to toluene diisocyanates (TDI) following inhalation exposure. Toxicol Appl Pharmacol. 1983;68:229-41. [pmid: 6304938].
28 Karol MH, Sandberg T, Riley EJ, et al. Longitudinal study of tolyl-reactive IgE antibodies in workers hypersensitive to TDI. J Occup Med. 1979;21(5):354-8. [pmid: 224155].
29 Karr RM, Lehrer SB, Butcher BT, et al. Coffee worker's asthma: a clinical appraisal using the radioallergosorbent test. J Allergy Clin Immunol. 1978;62(3):143-8. [pmid: 681627].
30 Kennedy SM, Burrows B, Vedal S, et al. Methacholine responsiveness among working populations: Relationship to smoking and airway calibre. Am Rev Respir Dis. 1990;142:1377-83. [pmid: 2252256].
31 Kline JN, Jagielo PJ, Watt JL, et al. Bronchial hyperactivity is associated with enhanced grain dust-induced airflow obstruction. J Appl Physiol. 2000;89:1172-8. [pmid: 10956366].
32 Kongerud J, Rambjor O. The influence of helmet respirator on peak flow rate in aluminium potroom. Am Ind Hyg Assoc J. 1991;52(6):243-8. [pmid: 1858666].
33 Kongerud J, Soyseth V. Methacholine responsiveness, respiratory symptoms and pulmonary function in aluminium potroom workers. Eur Respir J. 1991;4(2):159-66. [pmid: 2044731].
34 Kongerud J, Vale JR, Aalen OO. Questionnaire reliability and validity for aluminium potroom workers. Scand J Work Environ Health. 1989;15:364-70. [pmid: 2799323].
35 Leynadier F, Herman D, Vervloet D, et al. Specific immunotherapy with a standardized latex extract versus placebo in allergic healthcare workers. J Allergy Clin Immunol. 2000;106:585-90. [pmid: 10984382].
36 Liss GM, Bernstein DI, Moller DR, et al. Pulmonary and immunologic evaluation of foundery workers exposed to methylene diphenyldiisocyanate (MDI). J Allergy Clin Immunol. 1988;82:55-61. [pmid: 3392370].
37 Losada Cosmes E. Occupational asthma caused by enzyme sensitization: Results of a clinical questionnaire and of the skin tests [Spanish]. Revista Espanola de Alergologia e Inmunologia Clinica. 1991;6(Suppl 3):2-12.
38 McGarth KG, Roach D, Zeiss CR, et al. Four-year evaluation of workers exposed to trimellitic anhydride. J Occup Med. 1984;26(9):671-5. [pmid: 6481502].
39 Meijer E, Grobbee DE, Heederik D. Detection of workers sensitised to high molecular weight allergens: a diagnostic study in laboratory animal workers. Occup Environ Med. 2002;59:189-95. [pmid: 11886950]. [pmcid: 1763629].
40 Murray AB, Hardwick DF, Pirie GE, et al. Assessing the severity of asthma with Wright peak-flow meter. Lancet. 1977;1:708. [pmid: 66511].
41 Musk AW, Venables KM, Crook B, et al. Respiratory symptoms, lung function, and sensitisation to flour in a British bakery. Br J Ind Med. 1989;46:636-42. [pmid: 2789967]. [pmcid: 1009839].
42 Obase Y, Shimoda T, Mitsuta K, et al. Two patients with occupational asthma who returned to work with dust respirators. Occup Environ Med. 2000;57:62-4. [pmid: 10711271]. [pmcid: 1739853].
43 Ofner B, Marelja J. [Bronchial hyperreactivity to methacholine in workers in an aluminium electrolysis potroom] [Croatian]. Arhiv Za Higijenu Rada i Toksikologiju. 1986;37(3):301-9. [pmid: 3304219].
44 Ortega HG, Daroowalla F, Petsonk EL, et al. Respiratory symptoms among crab processing workers in Alaska: epidemiological and environmental assessment. Am J Ind Med. 2001;39:598-607. [pmid: 11385644].
45 Pavlovic M, Spasojevic M, Tasic Z, et al. Bronchial hyperactivity in bakers and its relation to atopy and skin reactivity. Science of the Total Environment. 2001;270:71-5. [pmid: 11327401].
46 Pham QT, Mur JM, Massin N, et al. Longitudinal five year study of respiratory symptoms and pulmonary function in truck factory painters [Évolution clinique et fonctionnelle respiratoire sur une période de cinq ans chez les peintres d'une usine de véhicules industriels] French. Arch Mal Prof. 1989;50(5):421-5.
47 Pien LC, Zeiss CR, Leach CL, et al. Antibody response to trimellityl hemoglobin in trimellitic anhydride-induced lung injury. J Allergy Clin Immunol. 1988;82:1098-103. [pmid: 3204253].
48 Pisati G, Bernabeo F, Cirla AM. Utilizzo di un test di broncostimolazione specifica verso cobalto nella diagnosi dell'asma da metalli duri [A bronchial challenge test specific for cobalt in the diagnosis of asthma due to hard metals]. [Italian] Medicina del Lavoro. 1986;77(5):538-46. [pmid: 3796437].
49 Pollini G, Biscaldi G, Malamani T, et al. Value of efficacy of salbutamol aerosol administration by intermittent positive pressure breathing in patients affected by small airway obstruction. G Ital Med Lav. 1982;4:107-8.
50 Raulf-Heimsoth M, Wirtz C, Papenfuss F, et al. Nasal lavage mediator profile and cellular composition of nasal brushing material during latex challenge tests. Clin Exp Allergy. 2000;30:110-21. [pmid: 10606938].
51 Ryan G, Cookson WO, Musk AW. Allergy and nonallergic bronchial reactivity as determinants of work-related respiratory symptoms in seasonal grain handlers. Chest. 1985;87(5):215S.
52 Saric M, Marelja J. Bronchial hyperreactivity in potroom workers and prognosis after stopping exposure. Br J Ind Med 191;48:653–5.
53 Schlunssen V, Schaumburg I, Heederik D, et al. Indices of asthma among atopic and non-atopic woodworkers. Occup Environ Med. 2004;61:504-11. [pmid: 15150389]. [pmcid: 1763653].
54 Sunyer J, Anto JM, Rodrigo MJ, et al. Case-control study of serum immunoglobulin-E antibodies reactive with soybean in epidemic asthma. Lancet. 1989;1(8631):179-82. [pmid: 2563097].
55 Talini D, Benvenuti A, Carrara M, et al. Diagnosis of flour-induced occupational asthma in a cross-sectional study. Respir Med. 2002;96(4):236-43. [pmid: 12000002].
56 Tse KS, Johnson A, Chan H, et al. A study of serum antibody activity in workers with occupational exposure to diphenylmethane diisocyanate. Allergy. 1985;40:314-20. [pmid: 4037253].
57 Vedal S, Chan-Yeung M, Enarson D, et al. Plicatic acid-specific IgE and nonspecific bronchial hyperresponsiveness in western red-cedar workers. J Allergy Clin Immunol. 1986;78:1103-9. [pmid: 3782674].
58 Vrcelj J. Comparative value of allergen tests and immunoglobulin for diagnosing allergic diseases. Medicinski Podmladak. 1969;21(34):21-30.
59 Walls AF, Longbottom JL. Comparison of rat fur, urine, saliva, and other rat allergen extracts by skin testing, RAST, and RAST inhibition. J Allergy Clin Immunol. 1985;75:242-51. [pmid: 3968335].
60 Wieslander G, Norback D, Janson C, et al. Validation of a self-administered questionnaire on asthmatic symptoms and atopy in house painters. J Occup Health. 1997;39(4):331-8.
61 Zaikov SV, Pukhlik BM, Zaikova AA et al. [The diagnosis of allergy to industrial chemical compounds using a method of immunothermistometry][Russian]. Likarska Sprava 1996;(3–4):148–50.
62 Zeiss CR, Leach CL, Smith LJ, et al. A serial immunologic and histopathologic study of lung injury induced by trimellitic anhydride. Am Rev Respir Dis. 1988;137:191-6. [pmid: 3337462].
63 Zetterstrom O. Challenge and exposure test reactions to enzyme detergents in subjects sensitized to subtilisin. Clin Allergy. 1977;7:355-63. [pmid: 589771].

### Inadequate Data

1 Adisesh LA, Kharitonov SA, Yates DH, et al. Exhaled and nasal nitric oxide is increased in laboratory animal allergy. Clin Exp Allergy. 1998;28(7):876-80. [pmid: 9720822].
2 Anees W, Huggin SV, Burge PS. Changes in induced sputum in workers with occupational asthma one year after initial assessment. Am J Crit Care Med. 2002;165:8. :a524.
3 Banks DE, Sastre J, Butcher BT, et al. Role of inhalation challenge testing in the diagnosis of isocyanate-induced asthma. Chest. 1989;95(2):414-23. [pmid: 2644091].
4 Baur X, Barbinova L. Correlation between bronchial hyperreativity and exhaled nitric oxide concentration [German]. Atemwegs- und Lungenkrankheiten. 2000;26(8):401-4.
5 Baur X, Marczynski B, Barbinova L, et al. Arbeitspatzbezogene expositionsteste mit dem diisocyanat MDI. Atemw Lungenkrkh. 2001;27(7):346-8.
6 Bherer L, Cushman R, Courteau JP et al. Survey of construction workers repeatedly exposed to chlorine over a three to six month period in a pulpmill: II. Follow up of affected workers by questionnaire, spirometry, and assessment of bronchial responsiveness 18 to 24 months after exposure ended. Occup Environ Med 51(4), 225–8. 1994.
7 Borchert J. [Observations on the development of allergic asthma and allergic rhinitis in bakers] [German]. Acta Allergologica. 1972;27(3):195-211. [pmid: 4678805].
8 Boulet LP, Boutet M, Laviolette M, et al. Airway inflammation after removal from the causal agent in occupational asthma due to high and low molecular weight agents. Eur Respir J. 1994;7:1567-75. [pmid: 7995383].
9 Bruckner HC, Avery SB, Stetson DM et al. Clinical and immunologic appraisal of workers exposed to diisocyanates. Arch Environ Health 968;16:619–25.
10 Burge PS, Edge G, Hawkins R, et al. Occupational asthma in a factory making flux-cored solder containing colophony. Thorax. 1981;36:828-34. [pmid: 7330804]. [pmcid: 471823].
11 Cadrin D, Fedeli U, Gemigani C, et al. Follow-up of occupational asthma induced by wheat flour. G Ital Med Lav. 2003;25:207.
12 Cannon J, Cullinan P, Newman Taylor AJ. Consequences of occupational asthma (effect on income and employment). BMJ. 1995;311:602-3. [pmid: 7663255]. [pmcid: 2550663].
13 Choudat D, Fabries JF, Martin JC, et al. Bronchial challenge with flour: early response is dependent on the dose of activated allergen inhaled. Eur Respir J. 2002;20(2):409-16. [pmid: 12212975].
14 Cocco G, D'Amato G, Liccardi G, et al. [The bronchial provocation test (BPT) in the diagnosis of occupational asthma caused by chemical substances] [Italian]. Archivio Monaldi Per la Tisiologia e Le Malattie dell'Apparato Respiratorio. 1978;33(12):31-8.
15 Cullinan P, Harris JM, Newman Taylor AJ, et al. An outbreak of asthma in a modern detergent factory. Lancet. 2000;356:1899-900. [pmid: 11130389].
16 Danks JM, Cromwell O, Buckingham JA, et al. Toluene-diisocyanate induced asthma: evaluation of antibodies in the serum of affected workers against a tolyl mono-isocyanate protein conjugate. Clin Allergy. 1981;11(2):161-8. [pmid: 6263516].
17 De Zotti R, Bovenzi M, Negro C, et al. Specific inhalation challenge with wheat flour in workers with suspected baker's asthma. Int Arch Occup Environ Health. 1999;72(5):335-7. [pmid: 10447665].
18 Di Franco A, Vagaggini B, Bacci E, et al. Leukocyte counts in hypertonic saline-induced sputum in subjects with occupational asthma. Respir Med. 1998;92(3):550-7. [pmid: 9692121].
19 Di Gioacchino M, Cavallucci E, Di Stefano F, et al. Influence of total IgE and seasonal increase of eosinophil cationic protein on bronchial hyperreactivity in asthmatic grass-sensitized farmers. Allergy. 2000;55:1030-4. [pmid: 11097312].
20 Douglas JDM, McSharry C, Blaikie L, et al. Occupational asthma caused byautomated salmon processing. Lancet. 1995;346:737-40. [pmid: 7658875].
21 Dueva LA, Grishina TI, Ozhiganova VN. [Specific immunological tests with industrial chemical allergens in occupational bronchial asthma][Russian]. Gig Tr Prof Zabol 1981;(8):20–3.
22 Durda M, Skublewski A, Zimecka-Rakowska E, et al. Results of inhalation tests with the allergen of Erwinia herbicola in subjects with occupational exposure to organic dust [Czech]. Studia Pneumologica et Phtiseologica Cechoslovaca. 1989;49(7):419-22.
23 Fuortes LJ, Kiken S, Makowsky J. An outbreak of naphthalene diisocyanate-induced asthma in a plastics (factory). Arch Environ Health. 1995;50(5):337-40. [pmid: 7574886].
24 Gandevia B, Milne J. Occupational asthma and rhinitis due to Western red cedar (Thuja plicata), with special reference to bronchial reactivity. Br J Ind Med. 1970;27(3):235-44. [pmid: 5448121]. [pmcid: 1009138].
25 Green RH, Brightling CE, Woltmann G et al. The use of induced sputum in the diagnosis of occupational asthma. ATS meeting 2001.
26 Huber H, Allmers H, Ammon J, et al. Vergleich von methacholintest, arbeismedizinischer asthma-anamnese und spezifischer provokation bei patienten mit verdacht auf berufsasthma. Atemw Lungenkrkh. 1996;22(6):314-7.
27 Kentner M, Hartung M, Thurauf J et al. Zur wertigkeit immunologischer und inhalativ-provokativer testverfahren in der diagnostik beruflich bedingter mehlstauballergien des respirationstraktes [The value of immunological and inhalation challenge tests in the diagnosis of occupational flour allergies of the respiratory system]. Prax Klin Pneumol 36(4), 183–9. 1982.
28 Larbanois A, Jamart J, Delwiche JP, et al. Socioeconomic outcome of subjects experiencing asthma symptoms at work. Eur Respir J. 2002;19:1107-13. [pmid: 12108864].
29 Lemiere C, Chaboilliez S, Trudeau C, et al. Characterization of airway inflammation after repeated exposures to occupational agents. J Allergy Clin Immunol. 2000;106(6):1163-70. [pmid: 11112901].
30 Lemiere C, Pizzichini MM, Balkissoon R, et al. Diagnosing occupational asthma: use of induced sputum. Eur Respir J. 1999;13(3):482-8. [pmid: 10232413].
31 Lin FJ, Chan-Yeung M. New method for an occupational dust challenge test. Occup Environ Med. 1995;52(1):54-6. [pmid: 7697142]. [pmcid: 1128151].
32 Losada E, Hinojosa M, Quirce S, et al. Occupational asthma caused by alpha-amylase inhalation: clinical and immunologic findings and bronchial response patterns. J Allergy Clin Immunol. 1992;89:118-25. [pmid: 1730831].
33 Malo JL, Dewitte JD, Cartier A, et al. [The Quebec system of indemnification for occupational asthma. Description, efficacy, and costs]. Rev Mal Respir. 1993;10(4):313-23. [pmid: 8235022].
34 Marabini A, Brugnami G, Curradi F, et al. [The response to a specific bronchial provocation test and the evolution of occupational asthma. A longitudinal study in subjects with toluene diisocyanate-induced asthma] Italian. Med Lav. 1994;85(2):134-41. [pmid: 8072441].
35 Merget R, Caspari C, Kulzer R, et al. Effective secondary prevention in occupational asthma: Results of a prospective study of subjects exposed to platinum salts in the manufacture of catalysts over a 4-year period. Allergische und chemisch-toxische Atemw Lungenkrkh. 1995;21(8):418.
36 Merget R, Schultze-Werninghaus G, Muthorst T, et al. Asthma due to the complex salts of platinum- a cross-sectional survey of workers in a platinum refinery. Clin Allergy. 1988;18:569-80. [pmid: 2468431].
37 Nakladalova M, Fialova J. Reexposure bronchoprovocation tests on the working place of the patient- proposal of procedure. Alergie 2000;Suppl 1:38–9.
38 Padoan M, Pozzato V, Simoni M, et al. Long-term follow-up of toluene diisocyanate-induced asthma. Eur Respir J. 2003;21:637-40. [pmid: 12762349].
39 Padoan M, Pozzato V, Zedda L, et al. A follow-up study of patients with occupational asthma due to diisocyanates. Eur Respir J. 2003;21(4):637. [pmid: 12762349].
40 Palczynski C, Walusiak J, Ruta U, et al. Nasal provocation test in the diagnosis of natural rubber latex allergy. Allergy. 2000;55:34-41. [pmid: 10696854].
41 Palczynski C, Walusiak J, Ruta U, et al. Occupational asthma and rhinitis due to glutaraldehyde: changes in nasal lavage fluid after specific inhalatory challenge test. Allergy. 2001;56(12):1186-91. [pmid: 11736748].
42 Petrozzino M, Carletti A, Macchioni P et al. Increasing duration of exposure and dose during challenge test can change the airway response to toluendiisocyanates (TDI) in hyperreactive workers. Eur Respir J Suppl 1995;Suppl 8:19220S.
43 Pham QT, Meyer-Bisch C, Mur JM, et al. Etude de l'evolution clinique et fontionnelle respiratoire sur 5 ans, d'ouvriers exposes a de faibles teneurs de diisocyanate de diphenylmethane. Arch Mal Prof. 1986;47:311-20.
44 Piipari R, Piirila P, Keskinen H, et al. Exhaled nitric oxide in specific challenge tests to assess occupational asthma. Eur Respir J. 2002;20(6):1532-7. [pmid: 12503715].
45 Schwarting HH. [Significance of skin testing in allergic occupational asthma][German]. Hefte zur Unfallheilkunde 1975;(121):533–6.
46 Shirai T, Reshad K, Yoshitomi CK et al. Green tea-induced asthma: Skin sensitivity and airway responsiveness to epigallocatechin gallate and airway responsiveness to methacholine. ATS conference Poster 2003.
47 Sikora R, Harris KE, Kenamore B, et al. Immunoglobulin E antibody against environmental allergens in subjects with trimellitic anhydride-induced asthma. J Occup Environ Med. 1999;41(3):190-4. [pmid: 10091142].
48 Tarlo SM, Banks D, Liss G, et al. Outcome determinants for isocyanate induced occupational asthma among compensation claimants. Occup Environ Med. 1997;54:756-61. [pmid: 9404325]. [pmcid: 1128932].
49 Tarlo SM, Liss G, Corey P, et al. A workers' compensation claim population for occupational asthma: comparison of subgroups. Chest. 1995;107(3):634-41. [pmid: 7874929].
50 Topping MD, Forster HW, Ide CW, et al. Respiratory allergy and specific immunoglobin E and immunoglobin G antibodies to reactive dyes used in the wool industry. J Occup Med. 1989;31(10):857-62. [pmid: 2607384].
51 Ucgun I, Ozdemir N, Metintas M, et al. Prevalence of occupational asthma among automobile and furniture painters in the center of Eskisehir (Turkey): the effects of atopy and smoking habits on occupational asthma. Allergy. 1998;53(11):1096-100. [pmid: 9860245].
52 Ulrik CS, Backer V, Skov PG. Usefulness of repeated measurements of bronchial hyperresponsiveness for the diagnosis of occupational asthma. J Asthma. 1994;31(1):35-42. [pmid: 8175623].
53 Valentino M, Pizzichini MA, Monaco F, et al. Latex-induced asthma in four healthcare workers in a regional hospital. Occup Med. 1994;44:161-4.
54 Venables KM, Davison AG, Newman-Taylor AJ. Consequences of occupational asthma. Respiratory Medicine. 1989;83:437-40. [pmid: 2616829].
55 Wheeler S, Rosenstock SW, Barnhart S. A case series of 71 patients referred to a hospital-based occupational and environmental medicine clinic for occupational asthma. West J Med. 1998;168:98-104. [pmid: 9499743]. [pmcid: 1304837].
56 White WG, Morris MJ, Sugden E, et al. Isocyanate-induced asthma in a car factory. Lancet. 1980;1(8171):756-60. [pmid: 6103170].
57 Wirtz C, Allmers H, Papenfuss F, et al. Nitric oxide in expired air - A suitable parameter for the assessment of occupation-related inhalation challenge tests? [German]. Atemwegs- und Lungenkrankheiten. 1997;23(8):436-7.
58 Woitowitz HJ, Woitowitz RH. [Occupational allergic bronchial asthma. Reliability of inhalation tests] [German]. Praxis der Pneumologie Vereinigt Mit der Tuberkulosearzt. 1971;25(4):185-93. [pmid: 5555349].

### No Treatment or Tests

1 Balland S, Grosclaude M, Jarsaillon E, et al. [Challenge provocation tests and non-specific bronchial hyperactivity in occupational asthma] French. J Toxicol Clin Exp. 1989;9(1 Suppl Pt 2):15-23.
2 Banauch GI, Alleyne D, Sanchez R, et al. Persistent hyperreactivity and reactive airway dysfunction in firefighters at the World Trade Center. Am J Respir Crit Care Med. 2003;168(1):54-62. [pmid: 12615613].
3 Baur X, Dewair M, Fruhmann G. Detection of immunologically sensitized isocyanate workers by RAST and intracutaneous skin tests. J Allergy Clin Immunol. 1984;73(5 pt 1):610-8. [pmid: 6609183].
4 Bernstein DI, Smith AB, Moller DR, et al. Clinical and immunologic studies among egg-processing workers with occupational asthma. J Allergy Clin Immunol. 1987;80(6):791-7. [pmid: 3693757].
5 Budanova LF, Makarova VN. [Occupational bronchial asthma] Russian. Med Tr Prom Ekol. 1998;11:1-4. [pmid: 9885492].
6 Cipolla C, Belisario A, Auletti G, et al. Studio della iperreattivita bronchiale alla metacolina in un grouppo di panificatori sensibilizzati alle polveri di farina di frumento [Bronchial hyperreactivity to methacholine in a group of bakers sensitized to wheat flour]. Med Lav. 2002;93(1):20-5. [pmid: 11987498].
7 Fabbri LM, Chiesura-Corona P, Dal Vecchio L, et al. Prednisone inhibits late asthmatic reactions and the associated increase in airway responsiveness induced by toluene diisocyanate in sensitized subjects. Am Rev Respir Dis. 1985;132:1010-4. [pmid: 2998242].
8 Irsigler GB, Visser PJ, Spangenberg PAL. Asthma and chemical bronchitis in Vanadium plant workers. Am J Ind Med. 1999;35:366-74. [pmid: 10086213].
9 Kurosawa M, Kobayashi S, Yanagihara Y, et al. Antigen-induced histamine release from peripheral leukocytes of “Konnyaku asthmatic patients”. Ann Allergy. 1990;64(3):319-21. [pmid: 1689973].
10 Prezant DJ, Weiden M, Banauch GI, et al. Cough and bronchial responsiveness in firefighters at the World Trade Center site. N Engl J Med. 2002;347(11):806-15. [pmid: 12226151].
11 Smith AB, Bernstein DI, London MA, et al. Evaluation of occupational asthma from airborne egg protein exposure in multiple settings. Chest. 1990;98(2):398-404. [pmid: 2376172].
12 Thiel H, Zimmermann I, Rasche B, et al. Allergen-specific histamine release from whole blood in flour-sensitive bakers. Respiration. 1982;43(3):208-20. [pmid: 7111867].
13 Zedda S, Cirla A, Aresini G, et al. Occupational type test for the etiological diagnosis of asthma due to toluene di-isocyanate. Respiration. 1976;33(1):14-21. [pmid: 173001].

### Unobtainable

1 al Jarad N. Occupational asthma. J R Coll Physicians Lond. 1999;33(6):537-40. [pmid: 10633331].
2 Baur X. Baker's asthma: causes and prevention. Int Arch Occup Environ Health. 1999;72(5):292-6. [pmid: 10447658].
3 Baur X, Dorsch W, von Liebe V. [Comparative studies between RAST, skin test and inhalation provocation test in patients with baker's asthma and moniliales asthma] German. Z Hautkr. 1979;54(7):301-5. [pmid: 571652].
4 Budanova LF, Makarova VN. [Occupational bronchial asthma] Russian. Med Tr Prom Ekol. 1998;11:1-4. [pmid: 9885492].
5 Burge PS. Prolonged and frequent recordings of peak expiratory flow rate in workers with suspected occupational asthma due to colophony and isocyanates. 1978.
6 Davies RJ. Respiratory Hypersensitivity to Diisocyanates. Clinics in Immunology and Allergy. 1984;4(1):103-123.
7 De Meer G, Heederik D, Postma DS. Bronchial responsiveness to adenosine 5′-monophosphate (AMP) and methacholine differ in their relationship with airway allergy and baseline FEV(1). Am J Respir Crit Care Med. 2002;165(3):327-31. [pmid: 11818315].
8 Di Franco A, Giannini D, Kotopulos C, et al. Effect of inhaled corticosteroids on induced sputum cell counts in subjects with occupational asthma and persistent exposure [abstract]. American Journal of Respiratory and Critical Care Medicine. 2000;161(3 Suppl):A761.
9 Dueva LA. [Micromodification of the complement fixation test with chemical allergens] Russian. Lab Delo. 1979;7:440-1. [pmid: 89245].
10 Dueva LA. [Value of immunomodulators in complex treatment of occupational bronchopulmonary diseases] Russian. Med Tr Prom Ekol. 2002;12:37-44. [pmid: 12593155].
11 Fleming MJ. Agricultural Health Program.
12 Hendrick DJ, Lane DJ. Formalin asthma in hospital staff. Br Med J. 1975;1(5958):607-8. [pmid: 1125625]. [pmcid: 1672777].
13 Hinojosa Macias M. Occupational asthma caused by wood. [Spanish]. Revista Espanola de Alergologia e Inmunologia Clinica. 1991;6(Suppl 3):19-24.
14 Jyo T, Kuwabara M, Kodomari Y, et al. Effects of improvements in working conditions on occupational asthma. Japanese Journal of Allergology. 1986;35(10):1003-10. [pmid: 3813893].
15 Kido T, Yamada Y, Teranishi H, et al. Toluene di iso cyanate asthma 1. clinico allergological tests. Japanese Journal of Allergology. 1983;32(2):111-20. [pmid: 6311143].
16 Kolacinska B, Gorski P. [Clinical state, bronchial reactivity and atopic symptoms in patients with occupational bronchial asthma 3–4 years after cessation of occupational exposure]. [Polish]. Medycyna. 1996;47(4):347-52.
17 Kotlinowska T, Obtulowicz K, Lapczuk T. Bronchial provocation test (BPT) and skin patch test in diagnosis of professional allergy. International Review of Allergology & Clinical Immunology. 1996;2(4):142-144.
18 Lebedova J, Navratil M, Hykes P, et al. The role of provocation bronchoconstriction test for the diagnosis of bronchial asthma in patients examined for suspected occupational bronchial asthma. Pracovni-Lekarstvi. 1987;39(10):440-2.
19 Lind P. Biomarkers of aromatic isocyanates in exposed workers [dissertation]. Lund, Sweden: Lund University;1997.
20 Mannix ET, Dresser KS, Aukley D, et al. Cardiopulmonary exercise testing in the evaluation of patients with occupational asthma and reactive airways dysfunction syndrome. J Investig Med. 1998;46(5):236-42.
21 May JJ. New York Center for Agricultural Medicine & Health Institution.
22 Mazaeva L, Shmelev E, Aisanov Z. Comparative efficacy of different treatment regimens in mild asthmatic patients with hypersensitivity to rye and wheat. European Respiratory Society Annual Congress 2002. 2002;abstract P453.
23 Merget R, Zachgo W, Schultze-Werninghaus G, et al. [Quantitative skin test and inhalation provocation test in asthma using platinum salts] German. Pneumologie. 1990;44(Suppl 1):226-8. [pmid: 2367372].
24 Moller DR, McKay RTK, Bernstein IL, et al. Long term follow-up of workers with TDI asthma [abstract]. Am Rev Respir Dis. 1984;129:A159.
25 Nakamura S. [Investigation on the long-term prognosis of occupational asthma] Japanese. Arerugi. 1990;39(1):12-20. [pmid: 2350242].
26 National Asthma Education Program. US Dept of Health and Human Services, National Heart, Lung and Blood Institute, National Institutes of Health.
27 NIOSH. Criteria for a Recommended Standard. Occupational exposure to diisocyanates. US Dept of Health, Education and Welfare 1978;(PHS CDC publication No. 78–215).
28 Paggiaro PL, Loi AM, Rossi O, et al. Outcome of specific and nonspecific bronchial challenge tests in TDI bronchial asthma. Folia Allergol Immunol Clin. 1983;30(suppl 4):118-22.
29 Palczynski C, Walusiak J, Wittczak T et al. Specific nasal challenge test in the diagnostics of occupational asthma and rhinitis due to glutaraldehyde. European Respiratory Society 1999.
30 Park HS, Nahm DH. Isocyanate-induced occupational asthma: challenge and immunologic studies. Korean Med Sci. 1996;11(4):314-8.
31 Pepys J. Occupational Allergy Due to Platinum Complex Salts. Clinics in Immunology and Allergy. 1984;4(1):131-57.
32 Pepys J, Hutchcroft BJ. Bronchial provocation tests in etiologic diagnosis and analysis of asthma. Am Rev Respir Dis. 1975;112(6):829-59. [pmid: 173214].
33 Shida T, Mimaki K, Sasaki N, et al. Studies on western red cedar asthma part 3 a research by inquiry in Oume city Tokyo and inhalation tests with nezucone into asthma. Japanese Journal of Allergology. 1971;20:915-21. [pmid: 5147615].
34 Soyseth V, Kongerud J, Boe J, et al. Bronchial responsiveness and work-related asthma in aluminium potroom workers: effect of removal from exposure. Eur Respir J. 1992;5(7):829-33. [pmid: 1499706].
35 Tarlo SM. Occupational allergies and asthma. Can Fam Physician. 1999;45:1516-22. [pmid: 10386216]. [pmcid: 2328476].
36 Torres Da Costa J, Ferreira JA, Castro E, et al. Occupational asthma in the cotton textile industry: Assessment by bronchial hyperreactivity and peak expiratory flow recording. Revista Portuguesa de Pneumologia. 2002;8(2):115-29.
37 van der Zee JS, de Jager KS, Kuipers BF, et al. Outbreak of occupational allergic asthma in a Stephanotis floribunda nursery. J Allergy Clin Immunol. 1999;103(5 Pt 1):950-2. [pmid: 10329834].
38 Zuskin E, Kanceljak B, Mataija M, et al. [Specific bronchial reactivity in unripe coffee processing workers] Croatian. Arh Hig Rada Toksikol. 1989;40(1):3-8. [pmid: 2803008].

### Addendum

After the review was completed, the authors were made aware of the following study:

1 Sastre J, Fernandez-Nieto M, Rico P, et al. Specific immunotherapy with a standardized latex extract in allergic workers: a double-blind, placebo-controlled study. J Allergy Clin Immunol. 2003;111:985-94. [pmid: 12743562].