# References and Included Studies

1 Banks DE, Wang ML. Occupational asthma: “the big picture”. Occup Med. 2000;15(2):335-58. [pmid: 10769341].
2 Chan-Yeung M, Malo JL. Occupational asthma. N Engl J Med. 1995;333(2):107-12. [pmid: 7777015].
3 Brooks SM, Weiss MA, Bernstein IL. Reactive airways dysfunction syndrome (RADS). Persistent asthma syndrome after high level irritant exposures. Chest. 1985;88:376-84. [pmid: 4028848].
4 Malo JL, Cartier A, Boulet LP, et al. Bronchial hyperresponsiveness can improve while spirometry plateaus two to three years after repeated exposure to chlorine causing respiratory symptoms. Am J Respir Crit Care Med. 1994;150(4):1142-5. [pmid: 7921449].
5 Chan-Yeung M, Malo JL, Tarlo SM, et al. Proceedings of the first Jack Pepys Occupational Asthma Symposium. Am J Respir Crit Care Med. 2003;167(3):450-71. [pmid: 12554630].
6 McDonald JC, Keynes HL, Meredith SK. Reported incidence of occupational asthma in the United Kingdom, 1989-97. Occup Environ Med. 2000;57(12):823-9. [pmid: 11077011]. [pmcid: 1739897].
7 Tarlo SM, Broder I. Irritant-induced occupational asthma. Chest. 1989;96(2):297-300. [pmid: 2666043].
8 American Thoracic Society. Guidelines for assessing and managing asthma risk at work, school, and recreation. Am J Respir Crit Care Med. 2004;169(7):873-81. [pmid: 15044221].
9 Meredith S, Nordman H. Occupational asthma: measures of frequency from four countries. Thorax. 1996;51(4):435-40. [pmid: 8733501]. [pmcid: 1090684].
10 Ameille J, Pauli G, Calastreng-Crinquand A, et al. Reported incidence of occupational asthma in France, 1996-99: the ONAP programme. Occup Environ Med. 2003;60(2):136-41. [pmid: 12554842]. [pmcid: 1740458].
11 Milton DK, Solomon GM, Rosiello RA, et al. Risk and incidence of asthma attributable to occupational exposure among HMO members. Am J Ind Med. 1998;33(1):1-10. [pmid: 9408523].
12 Blanc PD, Toren K. How much adult asthma can be attributed to occupational factors?. Am J Med. 1999;107:580-7. [pmid: 10625027].
13 Meredith SK, Taylor VM, McDonald JC. Occupational respiratory disease in the United Kingdom 1989: a report to the British Thoracic Society and the Society of Occupational Medicine by the SWORD project group. Br J Ind Med. 1991;48:292-8. [pmid: 2039741]. [pmcid: 1012037].
14 Contreras GR, Rousseau R, Chan-Yeung M. Occupational respiratory diseases in British Columbia, Canada in 1991. Occup Environ Med. 1994;51:710-2. [pmid: 8000498]. [pmcid: 1128082].
15 Chan-Yeung M. Assessment of asthma in the workplace. ACCP consensus statement. American College of Chest Physicians. Chest. 1995;108:1084-117. [pmid: 7555124].
16 van Kampen V, Merget R, Baur X. Occupational airway sensitizers: an overview on the respective literature. Am J Ind Med. 2000;38(2):164-218. [pmid: 10893510].
17 Tarlo SM, Liss G, Corey P, et al. A workers' compensation claim population for occupational asthma. Comparison of subgroups. Chest. 1995;107:643-41.
18 Saarinen K, Karjalainen A, Martikainen R, et al. Prevalence of work-aggravated symptoms in clinically established asthma. Eur Respir J. 2003;22(2):305-9. [pmid: 12952265].
19 Goe SK, Henneberger PK, Reilly MJ, et al. A descriptive study of work aggravated asthma. Occup Environ Med. 2004;61(6):512-7. [pmid: 15150390]. [pmcid: 1763647].
20 Leigh JP, Romano PS, Schenker MB, et al. Costs of Occupational COPD and Asthma. Chest. 2002;121:264-72. [pmid: 11796461].
21 Chan-Yeung M. Occupational asthma. Chest. 1990;98:148S-61S. [pmid: 2226002].
22 Ross DJ, Mcdonald JC. Health and employment after a diagnosis of occupational asthma: a descriptive study. Occup Med (Oxf). 1998;48(4):219-25. [pmid: 9800419].
23 Ortega HG, Weissman DN, Carter DL, et al. Use of specific inhalation challenge in the evaluation of workers at risk for occupational asthma: a survey of pulmonary, allergy, and occupational medicine residency training programs in the United States and Canada. Chest. 2002;121(4):1323-8. [pmid: 11948069].
24 Sterk PJ, Fabbri LM, Quanjer PH, et al. Airway responsiveness. Standardized challenge testing with pharmacological, physical and sensitizing stimuli in adults. Report Working Party Standardization of Lung Function Tests, European Community for Steel and Coal. Official Statement of the European Respiratory Society. Eur Respir J Suppl. 1993;16:53-83. [pmid: 8499055].
25 Pepys J, Hutchcroft BJ. Bronchial provocation tests in etiologic diagnosis and analysis of asthma. Am Rev Respir Dis. 1975;112(6):829-59. [pmid: 173214].
26 Burge PS, Harries MG, O'Brien IM, et al. Respiratory disease in workers exposed to solder flux fumes containing colophony (pine resin). Clin Allergy. 1978;8(1):1-14. [pmid: 414855].
27 Vandenplas O, Malo JL. Inhalation challenges with agents causing occupational asthma. Eur Respir J. 1997;10:2612-29. [pmid: 9426105].
28 Cartier A, Bernstein IL, Burge PS, et al. Guidelines for bronchoprovocation on the investigation of occupational asthma. Report of the Subcommittee on Bronchoprovocation for Occupational Asthma. J Allergy Clin Immunol. 1989;84(5 Pt 2):823-9. [pmid: 2809031].
29 Malo JL, Cartier A, Lemiere C, et al. Exaggerated bronchoconstriction due to inhalation challenges with occupational agents. Eur Respir J. 2004;23(2):300-3. [pmid: 14979507].
30 Minette A. Questionnaire of the European Community for Coal and Steel (ECSC) on respiratory symptoms. 1987--updating of the 1962 and 1967 questionnaires for studying chronic bronchitis and emphysema. Eur Respir J. 1989;2(2):165-77. [pmid: 2703044].
31 Burney PG, Chinn S, Britton JR, et al. What symptoms predict the bronchial response to histamine? Evaluation in a community survey of the bronchial symptoms questionnaire (1984) of the International Union Against Tuberculosis and Lung Disease. Int J Epidemiol. 1989;18(1):165-73. [pmid: 2656559].
32 Ferris BG. Epidemiology Standardization Project (American Thoracic Society). Am Rev Respir Dis. 1978;118(6 Pt 2):1-120. [pmid: 742764].
33 Cotes JE. Medical Research Council Questionnaire on Respiratory Symptoms (1986). Lancet. 1987;2:1028. [pmid: 2889937].
34 Anees W, Gannon PF, Huggins V, et al. Effect of Peak Expiratory Flow Data Quantity on Diagnostic Sensitivity and Specificity in Occupational Asthma. Eur Respir J. 2004;23(5):370-4.
35 Liss GM, Tarlo SM. Peak expiratory flow rates in possible occupational asthma. Chest. 1991;100(1):63-9. [pmid: 2060392].
36 Cote J, Kennedy S, Chan-Yeung M. Sensitivity and specificity of PC20 and peak expiratory flow rate in cedar asthma. J Allergy Clin Immunol. 1990;85(3):592-8. [pmid: 2179365].
37 American Thoracic Society. Medical Section of the American Lung Association. Guidelines for the evaluation of impairment/disability in patients with asthma. Am Rev Respir Dis. 1993;147:1056-61. [pmid: 8466106].
38 Crapo RO, Casaburi R, Coates AL, et al. Guidelines for methacholine and exercise challenge testing-1999. Am J Respir Crit Care Med. 2000;161:309-29. [pmid: 10619836].
39 Dreborg S. Bronchial hyper-reactivity and skin sensitivity. Clin Exp Allergy. 1991;21(5):529. [pmid: 1742642].
40 Kuschner WG, Chitkara RK, Sarinas PS. Occupational asthma. Practical points for diagnosis and management. West J Med. 1998;169(6):342-50. [pmid: 9866431]. [pmcid: 1305401].
41 Newman Taylor AJ, Nicholson PJ (Editors). Guidelines for the prevention, identification, and management of occupational asthma: Evidence review and recommendations. British Occupational Health Research Foundation. London 2004.
42 Kharitonov SA, Yates D, Robbins RA, et al. Increased nitric oxide in exhaled air of asthmatic patients. Lancet. 1994;343:133-5. [pmid: 7904001].
43 Obata H, Dittrick M, Chan H, et al. Sputum eosinophils and exhaled nitric oxide during late asthmatic reactions in patients with western red cedar asthma. Eur Respir J. 1999;13(3):489-95. [pmid: 10232414].
44 Kharitonov SA, Yates DH, Barnes PJ. Inhaled glucocorticoids decrease nitric oxide in exhaled air of asthmatic patients. Am J Respir Crit Care Med. 1996;153(1):454-7. [pmid: 8542158].
45 Belda J, Leigh R, Parameswaran K, et al. Induced sputum cell counts in healthy adults. Am J Respir Crit Care Med. 2000;161:475-8. [pmid: 10673188].
46 Pizzichini E, Pizzichini MM, Efthimiadis A, et al. Indices of airway inflammation in induced sputum: reproducibility and validity of cell and fluid-phase measurements. Am J Respir Crit Care Med. 1996;154:307-17.
47 Vlachos-Mayer H, Leigh R, Sharon RF, et al. Success and safety of sputum induction in the clinical setting. Eur Respir J. 2000;16:997-1000. [pmid: 11153606].
48 Gibson PG. How to measure airway inflammation: induced sputum. Can Respir J. 1998;5(Suppl A):22A-6A.
49 Lam S, LeRiche J, Phillips D, et al. Cellular and protein changes in bronchial lavage fluid after late asthmatic reaction in patients with red cedar asthma. J Allergy Clin Immunol. 1987;80(1):44-50. [pmid: 3598029].
50 Marabini A, Dimich-Ward H, Kwan SY, et al. Clinical and socioeconomic features of subjects with red cedar asthma. A follow-up study. Chest. 1993;104(3):821-4. [pmid: 8365295].
51 United States of America. American with Disabilities Act of 1990. 1990;Pub. L.:101–336.
52 Martyny J, Glazer CS, Newman LS. Respiratory protection. N Engl J Med. 2002;347(11):824-30. [pmid: 12226154].
53 Ortega HG, Kreiss K, Schill DP, et al. Fatal asthma from powdering shark cartilage and review of fatal occupational asthma literature. Am J Ind Med. 2002;42(1):50-4. [pmid: 12111690].
54 Tarlo SM, Boulet LP, Cartier A, et al. Canadian Thoracic Society guidelines for occupational asthma. Can Respir J. 1998;5(4):289-300. [pmid: 9753529].
55 Lin FJ, Dimich-Ward H, Chan-Yeung M. Longitudinal decline in lung function in patients with occupational asthma due to western red cedar. Occup Environ Med. 1996;53(11):753-6. [pmid: 9038799]. [pmcid: 1128593].
56 Pisati G, Zedda S. Outcome of occupational asthma due to cobalt hypersensitivity. Sci Total Environ. 1994;150(13):167-71. [pmid: 7939592].
57 Ameille J, Pairon JC, Bayeux MC, et al. Consequences of occupational asthma on employment and financial status: a follow-up study. Eur Respir J. 1997;10(1):55-8. [pmid: 9032492].
58 Gannon PF, Weir DC, Robertson AS, et al. Health, employment, and financial outcomes in workers with occupational asthma. Br J Ind Med. 1993;50(6):491-6. [pmid: 8329312]. [pmcid: 1035473].
59 Dewitte JD, Chan-Yeung M, Malo JL. Medicolegal and compensation aspects of occupational asthma. Eur Respir J. 1994;7:969-80. [pmid: 8050556].
60 Walters EH, Walters JA, Gibson M. Inhaled long acting beta agonists for stable chronic asthma. The Cochrane Database of Systematic Reviews 2004, Issue 4. Published by John Wiley & Sons, Ltd.
61 Westby M, Benson M, Gibson P. Anticholinergic agents for chronic asthma in adults. The Cochrane Database of Systematic Reviews 2004, Issue 4. Published by John Wiley & Sons, Ltd.
62 National Asthma Council Australia. Asthma Management Handbook 2002. 2002.
63 The British Thoracic Society SIGN. British Guideline on the Management of Asthma. Thorax, i1–94. 2003. London & Edinburgh, UK, Scottish Intercollegiate Guidelines Network.
64 Boulet LP, Becker A, Berube D et al. Canadian asthma consensus report, 1999. CMAJ 161[11 Suppl], s1–s62. 1999.
65 New Zealand Guidelines Group. The diagnosis and treatment of adult asthma. 2002. Wellington, NZ, 2002 New Zealands Guidelines Group.
66 National Institutes of Health. Global Initiative for Asthma: Global Strategy for Asthma Management and Prevention. NHLBI/WHO Workshop. 1995. National Heart, Lung, and Blood Institute (U.S.) World Health Organization.
67 Keistinen T. Long-term management of asthma (Finnish Medical Society). P06031 (006.031), 1–9. 2001. Duodecim Medical Publications Ltd.
68 Williams SG, Schmidt DK, Redd SC et al. Recommendations of the National Asthma Education and Prevention Program. 1–14. 2003. National Center for Environmental Health;National Heart, Lung, and Blood Institute.
69 North of England Evidence Based Guideline Development project. The primary care management of asthma in adults. Centre for Health Services Research at the University of Newcastle upon Tyne 1999;99.
70 Lijmer JG, Mol BW, Heisterkamp S, et al. Empirical evidence of design-related bias in studies of diagnostic tests. JAMA. 1999;282(11):1061-6. [pmid: 10493205].
71 Downs SH, Black N. The feasibility of creating a checklist for the assessment of the methodological quality both of randomized and non-randomised studies of health care interventions. J Epidemiol Community Health. 1998;52(6):377-84. [pmid: 9764259]. [pmcid: 1756728].
72 Jadad AR, Moore RA, Carroll D, et al. Assessing the quality of reports of randomized clinical trials: is blinding necessary?. Control Clin Trials. 1996;17(1):1-12. [pmid: 8721797].
73 Schulz KF, Chalmers I, Hayes RJ, et al. Empirical evidence of bias. Dimensions of methodological quality associated with estimates of treatment effects in controlled trials. JAMA. 1995;273:408-12. [pmid: 7823387].
74 Chan-Yeung M, Malo JL. Aetiological agents in occupational asthma. Eur Respir J. 1994;7(2):346-71. [pmid: 8162990].
75 Glas AS. The diagnostic odds ratio: a single indicator of test performance. J Clin Epidemiol. 2003;56(11):1129-35. [pmid: 14615004].
76 Irwig L, Macaskill P, Glasziou P, et al. Meta-analytic methods for diagnostic test accuracy. J Clin Epidemiol. 1995;48(1):119-30. [pmid: 7853038].
77 Deeks JJ. Systematic reviews in health care: Systematic reviews of evaluations of diagnostic and screening tests. BMJ. 2001;323(7305):157-62. [pmid: 11463691].
78 Palczynski C, Walusiak J, Ruta U, et al. Occupational asthma and rhinitis due to glutaraldehyde: changes in nasal lavage fluid after specific inhalatory challenge test. Allergy. 2001;56(12):1186-91. [pmid: 11736748].
79 Lemiere C, Chaboilliez S, Trudeau C, et al. Characterization of airway inflammation after repeated exposures to occupational agents. J Allergy Clin Immunol. 2000;106(6):1163-70. [pmid: 11112901].
80 Ucgun I, Ozdemir N, Metintas M, et al. Prevalence of occupational asthma among automobile and furniture painters in the center of Eskisehir (Turkey): the effects of atopy and smoking habits on occupational asthma. Allergy. 1998;53(11):1096-100. [pmid: 9860245].
81 Green RH, Brightling CE, Woltmann G et al. The use of induced sputum in the diagnosis of occupational asthma. ATS meeting 2001.
82 Danks JM, Cromwell O, Buckingham JA, et al. Toluene-diisocyanate induced asthma: evaluation of antibodies in the serum of affected workers against a tolyl mono-isocyanate protein conjugate. Clin Allergy. 1981;11(2):161-8. [pmid: 6263516].
83 Lemiere C, Pizzichini MM, Balkissoon R, et al. Diagnosing occupational asthma: use of induced sputum. Eur Respir J. 1999;13(3):482-8. [pmid: 10232413].
84 Ulrik CS, Backer V, Skov PG. Usefulness of repeated measurements of bronchial hyperresponsiveness for the diagnosis of occupational asthma. J Asthma. 1994;31(1):35-42. [pmid: 8175623].
85 Jager D, Engelke T, Rennert S, et al. [Stepwise diagnosis of respiratory latex allergy]. Pneumologie. 1993;47(8):491-6. [pmid: 8378296].
86 Park HS, Nahm DH, Suh CH, et al. Occupational asthma and IgE sensitization to grain dust. J Korean Med Sci. 1998;13(3):275-80. [pmid: 9681805].
87 Alvarez MJ, Estrada JL, Gozalo F, et al. Oilseed rape flour: another allergen causing occupational asthma among farmers. Allergy. 2001;56(2):185-8. [pmid: 11167382].
88 Alvarez MJ, Tabar AI, Quirce S, et al. Diversity of allergens causing occupational asthma among cereal workers as demonstrated by exposure procedures. Clin Exp Allergy. 1996;26(2):147-53. [pmid: 8835121].
89 Shirai T, Reshad K, Yoshitomi A, et al. Green tea-induced asthma: relationship between immunological reactivity, specific and non-specific bronchial responsiveness. Clin Exp Allergy. 2003;33(9):1252-5. [pmid: 12956747].
90 Sastre J, Fernandez-Nieto M, Novalbos A, et al. Need for monitoring nonspecific bronchial hyperresponsiveness before and after isocyanate inhalation challenge. Chest. 2003;123(4):1276-9. [pmid: 12684321].
91 Di Stefano F, Siriruttanapruk S, McCoach J, et al. Glutaraldehyde: an occupational hazard in the hospital setting. Allergy. 1999;54(10):1105-9. [pmid: 10536890].
92 Perrin B, Lagier F, L'Archeveque J et al. Occupational asthma: validity of monitoring of peak expiratory flow rates and non-allergic bronchial responsiveness as compared to specific inhalation challenge. Eur Respir J 5, 40–8. 1992.
93 Malo JL, Cote J, Cartier A, et al. How many times per day should peak expiratory flow rates be assessed when investigating occupational asthma. Thorax. 1993;48:1211-7. [pmid: 8303625]. [pmcid: 464971].
94 Girard F, Chaboillez S, Cartier A et al. An Effective Strategy for Diagnosing Occupational Asthma: Use of Induced Sputum. Am J Respir Crit Care Med 2004..
95 Perrin B, Malo JL, L'Archeveque J et al. Comparison of peak expiratory flow rates and bronchial responsiveness with specific inhalation challenges in occupational asthma. Am Rev Respir Dis 1990;141.
96 Cote J, Kennedy S, Chan-Yeung M. Quantitative versus qualitative analysis of peak expiratory flow in occupational asthma. Thorax. 1993;48(1):48-51. [pmid: 8434353]. [pmcid: 464241].
97 Munoz X. Validation of specific inhalation challenge for the diagnosis of occupational asthma due to persulphate salts. Occup Environ Med. 2004;61(10):861-6. [pmid: 15377773]. [pmcid: 1740674].
98 Huggins V, Hole A, Burge PS et al. Peak expiratory flow responses analysed with OASYS in workers exposed to detergent enzymes. Eur Respir Soc 2003.
99 Burge PS, O'Brien IM, Harries MG. Peak flow rate records in the diagnosis of occupational asthma due to isocyanates. Thorax. 1979;34(3):317-23. [pmid: 225841]. [pmcid: 471067].
100 Cote J, Kennedy S, Chan-Yeung M. Outcome of patients with cedar asthma with continuous exposure. Am Rev Respir Dis 141, 373–6. 1990.
101 Burge PS, O'Brien IM, Harries MG. Peak flow rate records in the diagnosis of occupational asthma due to colophony. Thorax. 1979;34:308-16. [pmid: 483205]. [pmcid: 471066].
102 Curran AD, Burge PS, Wiley K. Clinical and immunologic evaluation of workers exposed to glutaraldehyde. Allergy. 1996;51(11):826-32. [pmid: 8947341].
103 Behr J, Baur X, Rommelt H, et al. [Diagnosis of irritative-toxic isocyanate asthma with the isocyanate exposure test]. Pneumologie. 1990;44 Suppl 1:229-31. [pmid: 2367373].
104 Taivainen A, Iivonen E, Kokkarinen J, et al. [The diagnosis of asthma caused by cow hair epithelium]. Duodecim. 1994;110(21):1999-2003. [pmid: 8654225].
105 Vandenplas O, Van Cangh FB, Brumagne A, et al. Occupational asthma in symptomatic workers exposed to natural rubber latex: evaluation of diagnostic procedures. J Allergy Clin Immunol. 2001;107(3):542-7. [pmid: 11240958].
106 Baur X, Huber H, Degens PO, et al. Relation between occupational asthma case history, bronchial methacholine challenge, and specific challenge test in patients with suspected occupational asthma. Am J Ind Med. 1998;33(2):114-22. [pmid: 9438044].
107 La Paglia G, Ruvolo M, Scancarello D, et al. [Usefulness of specific bronchial provocation tests in the diagnosis of compensable occupational allergic pneumopathies]. G Ital Med Lav. 1986;8(34):139-44. [pmid: 2968292].
108 Tarlo SM, Broder I. Outcome of assessments for occupational asthma. Chest 100, 329–35. 1991.
109 Cote J, Kennedy S, Chan-Yeung M. Sensitivity and specificity of PC20 and peak expiratory flow rate in cedar asthma. J Allergy Clin Immunol. 1990;85(3):592-8. [pmid: 2179365].
110 Malo JL, Cartier A. Occupational asthma in workers of a pharmaceutical company processing spiramycin. Thorax. 1988;43:371-7. [pmid: 3194865]. [pmcid: 461250].
111 Lemiere C, Chaboillez S, Malo JL, et al. Changes in sputum cell counts after exposure to occupational agents: what do they mean?. J Allergy Clin Immunol. 2001;107(6):1063-8. [pmid: 11398086].
112 Obtulowicz K, Laczkowska T, Kolarzyk E, et al. Obstruction of the small airways in the spirometric diagnosis of occupational bronchial asthma. J Investig Allergol Clinl Immunol. 1998;8(5):300-3.
113 Di Franco A, Vagaggini B, Bacci E, et al. Leukocyte counts in hypertonic saline-induced sputum in subjects with occupational asthma. Respir Med. 1998;92(3):550-7. [pmid: 9692121].
114 Redlich CA, Homer RJ, Smith BR, et al. Immunologic responses to isocyanates in sensitized asthmatic subjects. Clin Exp Immunol. 1996;109(3 Suppl):6S-8S.
115 Kern DG. Outbreak of the reactive airways dysfunction syndrome after a spill of glacial acetic acid. Am Rev Respir Dis. 1991;144(5):1058-64. [pmid: 1952431].
116 Piirila PL, Nordman H, Korhonen OS, et al. A thirteen-year follow-up of respiratory effects of acute exposure to sulfur dioxide. Scand J Work Environ Health. 1996;22(3):191-6. [pmid: 8837264].
117 Malo JL, Cartier A, Cote J, et al. Influence of inhaled steroids on recovery from occupational asthma after cessation of exposure: an 18-month double-blind crossover study. Am J Respir Crit Care Med. 1996;153(3):953-60. [pmid: 8630579].
118 Malo JL, Perrin B, L'Archeveque J, et al. Effect on an inhaled beta-2 adrenergic agent on late asthmatic reactions due to occupational agents. Rev Mal Resp. 1994;11:479-84.
119 Mueller-Wening D, Neuhauss M. Protective effect of respiratory devices in farmers with occupational asthma. Eur Respir J. 1998;12(3):569-72. [pmid: 9762781].
120 Paggiaro PL, Bacci E, Talini D, et al. Atropin does not inhibit late asthmatic responses induced by Toluene diisocyanate in sensitized subjects. Am Rev Respir Dis. 1987;136(5):1237-41. [pmid: 2823652].
121 Armentia A, Martin-Santos JM, Quintero A, et al. Baker's asthma: prevalence and evaluation of immunotherapy with wheat flour extract. Ann Allergy. 1990;65(4):265-72. [pmid: 2221484].
122 Fabbri LM, Di Giacomo GR, Dal Vecchio L, et al. Prednisone, indomethacin and airway responsiveness in toluene diisocyanate sensitized subjects. Bull Eur Physiopathol Respir. 1985;21:421-26. [pmid: 2998519].
123 Vandenplas O, Delwiche JP, Depelchin S, et al. Latex gloves with a lower protein content reduce bronchial reactions in subjects with occupational asthma caused by latex. Am J Respir Crit Care Med. 1995;151(3 Pt 1):887-91. [pmid: 7881687].
124 Crescioli S, De Marzo N, Boschetto P, et al. Theophylline inhibits late asthmatic reactions induced by toluene diisocyanate in sensitized subjects. Eur J Pharmacol - Environ Toxicol Pharmacol Sect. 1992;1(1):45-50.
125 De Marzo N, Fabbri LM, Crescioli S, et al. Dose-dependent inhibitory effect of inhaled beclomethasone on late asthmatic reactions and increased responsiveness to methacholine induced by toluene diisocyanate in sensitised subjects. Pulm Pharmacol. 1988;1(1):15-20. [pmid: 2856542].
126 Mapp CE, Boschetto P, Dal Vecchio L, et al. Protective effect of antiasthma drugs on late asthmatic reactions and increased airway responsiveness induced ty toluene diisocyanate in sensitized subjects. Am Rev Respir Dis. 1987;136(6):1403-7. [pmid: 2825567].
127 Moscato G, Gherson G, Biscaldi G, et al. Protective effect of nifedipine upon specific bronchial responses to isocyanates. G Ital Med Lav. 1985;5(6):247-50. [pmid: 6100488].
128 Maestrelli P, De Marzo N, Saetta M, et al. Effects of inhaled beclomethasone on airway responsiveness in occupational asthma. Placebo-controlled study of subjects sensitized to toluene diisocyanate. Am Rev Respir Dis. 1993;148(2):407-12. [pmid: 8393638].
129 Woitowitz HJ, Woitowitz RH. Clinical experiences with a new sympathicomimetic substance in the provoked attack in occupational asthma. Respir. 1972;29(5):549-55.
130 Paggiaro PL, Bacci E, Paoletti P, et al. Bronchoalveolar lavage and morphology of the airways after cessation of exposure in asthmatic subjects sensitized to toluene diisocyanate. Chest. 1990;98(3):536-42. [pmid: 2168308].
131 Burge PS. Occupational asthma in electronic workers caused by colophony fumes: follow-up of affected workers. Thorax. 1982;37:348-53. [pmid: 7112471]. [pmcid: 459315].
132 Malo JL, Cartier A, Ghezzo H, et al. Patterns of improvement in spirometry, bronchial hyperresponsiveness, and specific IgE antibody levels after cessation of exposure in occupational asthma caused by snow-crab processing. Am Rev Respir Dis. 1988;138(4):807-12. [pmid: 3202454].
133 Mapp CE, Corona PC, De Marzo N, et al. Persistent asthma due to isocyanates. A follow-up study of subjects with occupational asthma due to toluene diisocyanate (TDI). Am Rev Respir Dis. 1988;137(6):1326-9. [pmid: 2849330].
134 Allard C, Cartier A, Ghezzo H, et al. Occupational asthma due to various agents: absence of clinical and functional improvement at an interval of four or more years after cessation of exposure. Chest. 1989;96(5):1046-9. [pmid: 2805834].
135 Perfetti L, Cartier A, Ghezzo H, et al. Follow-up of occupational asthma after removal from or diminution of exposure to the responsible agent: relevance of the length of the interval from cessation of exposure. Chest. 1998;114(2):398-403. [pmid: 9726721].
136 Lemiere C, Cartier A, Dolovich J, et al. Outcome of specific bronchial responsiveness to occupational agents after removal from exposure. Am J Respir Crit Care Med. 1996;154(2 Pt 1):329-33. [pmid: 8756802].
137 Pisati G, Baruffini A, Zedda S. Toluene diisocyanate induced asthma: Outcome according to persistence or cessation of exposure. Br J Ind Med. 1993;50(1):60-4. [pmid: 8381658]. [pmcid: 1061235].
138 Vandenplas O, Jamart J, Delwiche JP, et al. Occupational asthma caused by natural rubber latex: outcome according to cessation or reduction of exposure. J Allergy Clin Immunol. 2002;109(1):125-30. [pmid: 11799378].
139 Rosenberg N, Garnier R, Rousselin X, et al. Clinical and socio-professional fate of isocyanate-induced asthma. Clin Allergy. 1987;17(1):55-61. [pmid: 3829371].
140 Sulotto F, Romano C, Piolatto G, et al. [Effects of long-term use of inhaled steroids (beclomethasone dipropionate) in patients with occupational asthma no longer exposed]. Med Lav. 1989;80(6):498-505. [pmid: 2630896].
141 Lozewicz S, Assoufi BK, Hawkins R, et al. Outcome of asthma induced by isocyanates. Br J Dis Chest. 1987;81(1):14-22. [pmid: 3663485].
142 Banks DE, Rando RJ, Barkman HW Jr. Persistence of toluene diisocyanate-induced asthma despite negligible workplace exposures. Chest. 1990;97(1):121-5. [pmid: 2153064].
143 Lemiere C, Cartier A, Malo JL, et al. Persistent specific bronchial reactivity to occupational agents in workers with normal nonspecific bronchial reactivity. Am J Resp Crit Care Med. 2000;162(3 Pt 1):976-80. [pmid: 10988116].
144 Paggiaro PL, Loi AM, Rossi O, et al. Follow-up study of patients with respiratory disease due to toluene diisocyanate. Clin Allergy. 1984;14(5):463-9. [pmid: 6091946].
145 Marabini A, Siracusa A, Stopponi R, et al. Outcome of occupational asthma in patients with continuous exposure - a 3-year longitudinal study during pharmacologic treatment. Chest. 2003;124(6):2372-6. [pmid: 14665523].
146 Malo JL, Ghezzo H, L'Archeveque J, et al. Late asthmatic reactions to occupational sensitizing agents: frequency of changes in nonspecific bronchial responsiveness and of response to inhaled beta-2 adrenergic agent. J Allergy Clin Immunol. 1990;85:834-42. [pmid: 2332563].
147 Maghni K, Lemiere C, Ghezzo H, et al. Airway inflammation after cessation of exposure to agents causing occupational asthma. Am J Respir Crit Care Med. 2004;169(3):367-72. [pmid: 14578217].
148 Saetta M, Maestrelli P, Turato G, et al. Airway wall remodeling after cessation of exposure to isocyanates in sensitized asthmatic subjects. Am J Respir Crit Care Med. 1995;151(2 Pt 1):489-94. [pmid: 7842211].
149 O'Donnell TV, Welford B, Coleman ED. Potroom asthma: New Zealand experience and follow-up. Am J Ind Med. 1989;15(1):43-9. [pmid: 2929607].
150 Simonsson BG, Sjoberg A, Rolf C, et al. Acute and long-term airway hyperreactivity in aluminum-salt exposed workers with nocturnal asthma. Eur J Respir Dis. 1985;66(2):105-18. [pmid: 3882443].
151 Park HS, Yu HJ, Jung KS. Occupational asthma caused by chromium. Clin Exp Allergy. 1994;24(7):676-81. [pmid: 7953950].
152 Taivainen A, Tukiainen O, Terho O, et al. Powered dust respirator helmets in the prevention of occupational asthma among farmers. Scand J Work Environ Health. 1998;24(6):503-7. [pmid: 9988093].
153 Paggiaro PL, Vagaggini B, Dente FL, et al. Bronchial hyperresponsiveness and toluene diisocyanate. Long-term change in sensitized asthmatic subjects. Chest. 1993;103(4):1123-8. [pmid: 8131451].
154 Gorski P, Kolacinska B, Wittczak T. Analysis of the clinical state of patients with occupational asthma following cessation of exposure to allergens. Occup Med. 1999;49(5):285-9.
155 Park HS, Nahm DH. Prognostic factors for toluene diisocyanate-induced occupational asthma after removal from exposure. Clin Exper Allergy. 1997;27(10):1145-50. [pmid: 9383254].
156 Merget R, Reineke M, Rueckmann A, et al. Nonspecific and specific bronchial responsiveness in occupational asthma caused by platinum salts after allergen avoidance. Am J Respir Crit Care Med. 1994;150(4):1146-9. [pmid: 7921450].
157 Chan-Yeung M, MacLean L, Paggiaro P. Follow-up study of 232 patients with occupational asthma caused by western red cedar (thuja-plicata). J Allergy Clin Immunol. 1987;79(5):792-6. [pmid: 3571771].
158 Barker RD, Harris JM, Welch JA, et al. Occupational asthma caused by tetrachlorophthalic anhydride: a 12-year follow-up. J Allergy Clin Immunol. 1998;101(6 Pt 1):717-9. [pmid: 9648696].
159 Sen D, Wiley K, Williams JG. Occupational asthma in fruit salad processing. Clin Exp Allergy. 1998;28(3):363-7. [pmid: 9543087].
160 Virtanen T, Zeiler T, Rautiainen J, et al. Immune reactivity of cow-asthmatic dairy farmers to the major allergen of cow (BDA20) and to other cow-derived proteins. The use of purified BDA20 increases the performance of diagnostic tests in respiratory cow allergy. Clin Exp Allergy. 1996;26(2):188-96. [pmid: 8835127].
161 Chan-Yeung M, LeRiche J, MacLean L, et al. Comparison of cellular and protein changes in bronchial lavage fluid of symptomatic and asymptomatic patients with red cedar asthma on follow-up examination. Clin Allergy. 1988;18(4):359-66. [pmid: 3046776].
162 Chan-Yeung M, Obata H, Dittrick M, et al. Airway inflammation, exhaled nitric oxide, and severity of asthma in patients with western red cedar asthma. Am J Respir Crit Care Med. 1999;159(5 Pt 1):1434-8. [pmid: 10228107].
163 Harries MG, Burge PS, Samson M, et al. Isocyanate asthma - respiratory symptoms due to 1,5-naphthylene diisocyanate. Thorax. 1979;34(6):762-6. [pmid: 542916]. [pmcid: 471193].
164 Gassert TH, Hu H, Kelsey KT, et al. Long-term health and employment outcomes of occupational asthma and their determinants. J Occup Environ Med. 1998;40(5):481-91. [pmid: 9604186].
165 Munoz X, Cruz MJ, Orriols R, et al. Occupational asthma due to persulfate salts: diagnosis and follow-up. Chest. 2003;123(6):2124-9. [pmid: 12796198].
166 Moscato G, Dellabianca A, Perfetti L, et al. Occupational asthma: A longitudinal study on the clinical and socioeconomic outcome after diagnosis. Chest. 1999;115(1):249-56. [pmid: 9925092].
167 Bernstein DI, Karnani R, Biagini RE, et al. Clinical and occupational outcomes in health care workers with natural rubber latex allergy. Ann Allergy Asthma Immunol. 2003;90(2):209-13. [pmid: 12602668].
168 Chan-Yeung M. Fate of occupational asthma. A follow-up study of patients with occupational asthma due to western red cedar (Thuja-Plicata). Am Rev Respir Dis. 1977;116(6):1023-30. [pmid: 931178].
169 Orriols R, Drobnic ME, Munoz X, et al. [Occupational asthma due to isocyanates: a study of 21 patients]. Med Clin (Barc). 1999;113(17):659-62. [pmid: 10618782].
170 Merget R, Schulte A, Gebler A, et al. Outcome of occupational asthma due to platinum salts after transferral to low-exposure areas. Int Arch Occup Environ Health. 1999;72(1):33-9. [pmid: 10029228].
171 Park HS, Lee SK, Kim HY, et al. Specific immunoglobulin E and immunoglobulin G antibodies to toluene diisocyanate-human serum albumin conjugate: Useful markers for predicting long-term prognosis in toluene diisocyanate-induced asthma. Clin Exp Allergy. 2002;32(4):551-5. [pmid: 11972601].
172 Meyer WC. [Prognosis of occupational bronchial asthma after change of occupation and elimination of antigen (author's transl)]. MMW Munch Med Wochenschr. 1977;119(11):363-6. [pmid: 403419].
173 Venables KM, Topping MD, Nunn AJ, et al. Immunologic and functional consequences of chemical (tetrachlorophthalic anhydride)-induced asthma after four years of avoidance of exposure. J Allergy Clin Immunol. 1987;80(2):212-8. [pmid: 3611542].
174 Grammer L C,, Shaughnessy MA. Study of employees with anhydride-induced respiratory disease after removal from exposure. J Occup Environ Med. 1996;38(8):771-4. [pmid: 8863202].
175 Grammer LC, Shaughnessy MA, Kenamore BD. Clinical and immunologic outcome of 42 individuals with trimellitic anhydride-induced immunologic lung disease after transfer to low exposure. Allergy Asthma Proc. 2000;21(6):355-9. [pmid: 11191101].
176 Smith TA, Patton J. Health surveillance in milling, baking and other food manufacturing operations - five years' experience. Occup Med (Oxf). 1999;49(3):147-53. [pmid: 10451595].
177 Slovak AJ, Orr RG, Teasdale EL. Efficacy of the helmet respirator in occupational asthma due to laboratory animal allergy. Am Ind Hygiene Assoc J. 1985;46(8):411-5.
178 Laoprasert N, Swanson MC, Jones RT, et al. Inhalation challenge testing of latex-sensitive health care workers and the effectiveness of laminar flow HEPA-filtered helmets in reducing rhinoconjunctival and asthmatic reactions. J Allergy Clin Immunol. 1998;102(6 Pt 1):998-1004. [pmid: 9847441].
179 Malo JL, Boulet LP, Dewitte JD, et al. Quality of life of subjects with occupational asthma. J Allergy Clin Immunol. 1993;91(6):1121-7. [pmid: 8509574].
180 Carletti AM, Talini D, Carrara M, et al. [Specific bronchial provocation tests with flour in the diagnosis of occupational bronchial asthma]. Med Lav. 1997;88(5):406-15. [pmid: 9489304].
181 Cirla AM, Inzoli S, Aresini G, et al. [Evaluation of the diagnostic criteria in occupational asthma caused by isocyanates]. Med Lav. 1975;66(1):5-23. [pmid: 166293].
182 Cortona G, Beretta F, Traina G, et al. [Preliminary investigation in a pharmaceutical industry: bromelin-induced pathology (author's transl)]. Med Lav. 1980;1:70-5. [pmid: 6450319].
183 Mapp CE, Moro G, Fabbri L, et al. [Toluene diisocyanate-induced asthma: specific and non-specific bronchial challenge tests (author's transl)]. Med Lav. 1979;70(3):203-14. [pmid: 224295].
184 Mole R, Balletta A. [The significance of acetylcholine test in occupational allergic asthma (author's transl)]. Lav Um. 1977;29(6):188-95. [pmid: 611362].
185 Paggiaro PL, Pardi F, Amram D, et al. [Validity of a specific bronchial provocation test with proteolytic enzymes in occupational bronchial asthma caused by enzymatic detergents]. G Ital Med Lav. 1984;6(56):201-4. [pmid: 6545209].
186 Paggiaro PL, Loi AM, Campinoti G, et al. Ipereccitabilita bronchiale specifica e aspecifica nell'asma bronchiale da isocianati. Folia Immunol Clin. 1984;31:297-303.
187 Sander I, Degens P, Goldscheid N, et al. Divergente Prickhauttestergebnisse mit verschiedenen Weizen- und Roggenmehlextrakten [German]. Atemw-Lungenkrkh. 2001;27:333-4.
188 Schwarting HH. [Diagnostic significance of the radioallergosorbent test (RAST) in occupational, flour-related asthma. A comparison with previously used methods in allergy diagnosis]. Z Hautkr. 1979;54(7):306-8. [pmid: 442743].
189 Wurzinger G, Gillich E, Kroneis C. Bakers/millers-asthma - Different behaviour in inhalative provocation [German]. Atemw-Lungenkrkh. 1997;23(Suppl 1):S30-7.
190 Balland S, Grosclaude M, Jarsaillon E, et al. Realistic challenge and bronchial hyperreactivity in occupational asthma. [French]. J Toxicol Clin Exp. 1989;9(1 BIS):15-23.
191 Biot N, Grosclaude M, Meyer JL, et al. [Contribution of biological tests in the evaluation of professional asthma (author's transl)]. [French]. Poumon Coeur. 1980;36(4):257-61. [pmid: 6160568].
192 Colas M, Grosclaude M, Balland S, et al. Value of realistic exposure tests in the diagnosis of occupational asthma due to exotic woods [French]. Rev Pneumol Clin. 1985;41(1):39-46. [pmid: 4001745].
193 Grosclaude M, Kofman J, Perrin-Fayolle M. Respiratory functional tests in professional asthma. Value of realistic tests. Poumon Coeur. 1980;36(4):249-54. [pmid: 7443616].
194 Duan YY, Et AL. Occupational toluene diisocyanate (TDI) asthma inhalation challenge test and TDI-HSA skin test and detection of specific IgE. Chinese J Tubercul Respir Dis. 1989;12(3):149-52.
195 Baur X, Fruhmann G. Papain-induced asthma: diagnosis by skin test, RAST and bronchial provocation test. Clin Allergy. 1979;9(1):75-81. [pmid: 421337].
196 Burge PS. Non-specific bronchial hyper-reactivity in workers exposed to toluene di-isocyanate, diphenyl methane di-isocyanate and colophony. Eur J Respir Dis 1982;Suppl 123:91–6.
197 Burge PS, Harries MG, Lam WK, et al. Occupational asthma due to formaldehyde. Thorax. 1985;40:255-60. [pmid: 4023975]. [pmcid: 460042].
198 Coutts IL, Lozewicz S, Dally MB, et al. Respiratory symptoms related to work in a factory manufacturing cimetidine tablets. BMJ (Clin Res Ed). 1984;288(6428):1418.
199 Davison AG, Britton MG, Forrester JA, et al. Asthma in merchant seamen and laboratory workers caused by allergy to castor beans: analysis of allergens. Clin Allergy. 1983;13:553-61. [pmid: 6640891].
200 Gannon PF, Newton DT, Belcher J, et al. Development of OASYS-2: a system for the analysis of serial measurement of peak expiratory flow in workers with suspected occupational asthma. Thorax. 1996;51(5):484-9. [pmid: 8711675]. [pmcid: 473592].
201 Graneek BJ, Durham SR, Newman Taylor AJ. Late asthmatic reactions and changes in histamine responsiveness provoked by occupational agents Bulletin. Eur Physiopathol Respir. 1987;23(6):577-81.
202 Harries MG, Burge PS, O'Brien IM. Occupational type bronchial provocation tests. Testing with soluble antigens by inhalation. Br J Ind Med. 1980;37(3):248-52. [pmid: 7426475]. [pmcid: 1008703].
203 Howe W, Venables KM, Topping MD, et al. Tetrachlorophthalic anhydride asthma: evidence for specific IgE antibody. J Allergy Clin Immunol. 1983;71(1 Pt 1):5-11. [pmid: 6822691].
204 Lozewicz S. Occupational asthma due to methylcrylate and cyanoacrylates. Thorax. 1985;40(11):836-9. [pmid: 4071461]. [pmcid: 1020561].
205 O'Brien IM, Harries MG, Burge PS, et al. Toluene di-isocyanate-induced asthma. I. Reactions to TDI, MDI, HDI and histamine. Clin Allergy. 1979;9:1-6. [pmid: 217556].
206 O'Brien IM, Newman-Taylor AJ, Burge PS, et al. Toluene di-isocyanate-induced asthma. II. Inhalation challenge tests and bronchial reactivity studies. Clin Allergy. 1979;9(1):7-15. [pmid: 217557].
207 Slovak AJ. Occupational asthma caused by a plastics blowing agent AZO dicarbonamide. Thorax. 1981;36(12):906-9. [pmid: 7336369]. [pmcid: 471857].
208 Symington IS, Kerr JW, McLean DA. Type I allergy in mushroom soup processors. Clin Allergy. 1981;11:43-7. [pmid: 7194162].
209 Tee RD, Cullinan P, Welch J, et al. Specific IgE to isocyanates: A useful diagnostic role in occupational asthma. J Allergy Clin Immunol. 1998;101(5):709-15. [pmid: 9600510].
210 Bernstein DI, Cartier A, Cote J, et al. Diisocyanate antigen-stimulated monocyte chemoattractant protein-1 synthesis has greater test efficiency than specific antibodies for identification of diisocyanate asthma.[see comment]. Am J Respir Crit Care Med. 2002;166(4):445-50. [pmid: 12186818].
211 Block G, Tse KS, Kijek K, et al. Baker's asthma. Clinical and immunological studies. Clin Allergy. 1983;13(4):359-70. [pmid: 6349847].
212 Cartier A, Malo JL, Ghezzo H, et al. IgE sensitization in snow crab-processing workers. J Allergy Clin Immunol. 1986;78(2):344-8. [pmid: 3734286].
213 Cartier A, Malo J L,, Dolovich J. Occupational asthma in nurses handling psyllium. Clin Allergy. 1987;17(1):1-6. [pmid: 3829366].
214 Cartier A, Grammer L, Malo JL, et al. Specific serum antibodies against isocyanates: association with occupational asthma. J Allergy Clin Immunol. 1989;84(4 Pt 1):507-14. [pmid: 2794294].
215 Ferguson K, Gallie A, Ahmad D, et al. Asthma in isocyanate workers: How often is it related to occupation?. J Occup Health Safety - Austr New Zeal. 1996;12(1):31-40.
216 Lam S, Wong R, Chan-Yeung M. Nonspecific bronchial reactivity in occupational asthma. J Allergy Clin Immunol. 1979;63:28-34. [pmid: 758339].
217 Malo JL, Ghezzo H, L'Archeveque J, et al. Is the clinical history a satisfactory means of diagnosing occupational asthma?. Am Rev Respir Dis. 1991;143:528-32. [pmid: 2001062].
218 Paggiaro PL, Chan-Yeung M. Pattern of specific airway response in asthma due to western red cedar (Thuja plicata): relationship with length of exposure and lung function measurements. Clin Allergy. 1987;17:333-9. [pmid: 3304709].
219 Tse KS, Chan H, Chan-Yeung M. Specific IgE antibodies in workers with occupational asthma due to western red cedar. Clin Allergy. 1982;3:249-58. [pmid: 6179654].
220 De Zotti R, Gubian F, Negro C. [Changes in blood eosinophils and nonspecific bronchial reactivity after exposure tests to wheat flour and TDI]. Med Lav. 1996;87(2):152-61. [pmid: 8926918].
221 Dellabianca A, Omodeo P, Colli MC, et al. Bronchial responsiveness to ultrasonic “fog” in occupational asthma due to low molecular weight chemicals. Ann Allergy Asthma Immunol. 1996;77(5):378-84. [pmid: 8933776].
222 Dente PL, Rossi O, Talini D, et al. Bronchial hyperresponsiveness and respiratory symptoms in toluene di-isocyanate (TDI) induced asthma. Bull Eur Physiopathol Respir. 1986;22(Suppl 8):A739.
223 Mapp CE, Dal Vecchio L, Boschetto P, et al. Toluene diisocyanate-induced asthma without airway hyperresponsiveness. Eur J Respir Dis. 1986;68(2):89-95. [pmid: 3009212].
224 Moscato G, Dellabianca A, Corsico A, et al. Bronchial responsiveness to ultrasonic fog in occupational asthma due to diisocyanate. Chest. 1993;104(4):1127-32. [pmid: 8404179].
225 Paggiaro PL, Cantalupi R, Filieri M, et al. Bronchial asthma due to inhaled wood dust (Tanganyika aningre). Clin Allergy. 1981;11(6):605-10. [pmid: 7333004].
226 Paggiaro PL, Innocenti A, Bacci E, et al. Specific bronchial reactivity to toluene diisocyanate: relationship with baseline clinical findings. Thorax. 1986;41:279-82. [pmid: 3016938]. [pmcid: 460310].
227 Pezzini A, Riviera A, Paggiaro PL, et al. Specific IgE antibodies in twenty-eight workers with diisocyanate-induced bronchial asthma. Clin Allergy. 1984;14(5):453-61. [pmid: 6091945].
228 Ricciardi L, Fedele R, Saitta S, et al. Occupational asthma due to exposure to iroko wood dust. Ann Allergy Asthma Immunol. 2003;91(4):393-7. [pmid: 14582819].
229 Merget R, Heger M, Globisch A, et al. Quantitative bronchial challenge tests with wheat flour dust administered by Spinhaler: Comparison with aqueous wheat flour extract inhalation. J Allergy Clin Immunol. 1997;100(2):199-207. [pmid: 9275141].
230 Merget R, Dierkes A, Ruckmann A, et al. Absence of relationship between degree of nonspecific and specific bronchial responsiveness in occupational asthma due to platinum salts. [German]. Pneumol. 1997;51(4):345-350.
231 Schwaiblmair M, Vogelmeier C, Fruhmann G. Occupational asthma in hairdressers: results of inhalation tests with bleaching powder. Int Arch Occup Environ Health. 1997;70(6):419-23. [pmid: 9439990].
232 Vogelmeier C, Baur X, Fruhmann G. Isocyanate-induced asthma: results of inhalation tests with TDI, MDI and methacholine. Int Arch Occup Environ Health. 1991;63(1):9-13. [pmid: 1649802].
233 Kim H, Kim YD, Choi J. Serioimmunological characteristics of Korean workers exposed to toluene diisocyanate. Environ Res. 1997;75(1):1-6. [pmid: 9356188].
234 Kim YK, Son JW, Kim HY, et al. New occupational allergen in citrus farmers: citrus red mite (Panonychus citri). Ann Allergy Asthma Immunol. 1999;82(2):223-8. [pmid: 10071529].
235 Park HS, Kim YJ, Lee MK, et al. Occupational asthma and IgE antibodies to reactive dyes. Yonsei Med J. 1989;30(3):298-304. [pmid: 2588667].
236 Park HS, Lee MK, Kim BO, et al. Clinical and immunologic evaluations of reactive dye-exposed workers. J Allergy Clin Immunol. 1991;87(3):639-49. [pmid: 2005316].
237 Park HS, Kim HY, Nahm DH, et al. Specific IgG, but not specific IgE, antibodies to toluene diisocyanate-human serum albumin conjugate are associated with toluene diisocyanate bronchoprovocation test results. J Allergy Clin Immunol. 1999;104(4 Pt 1):847-51. [pmid: 10518831].
238 Park HS, Kim HY, Suh YJ, et al. Alpha amylase is a major allergenic component in occupational asthma patients caused by porcine pancreatic extract. J Asthma. 2002;39(6):511-6. [pmid: 12375710].
239 Hinojosa M, Losada E, Moneo I, et al. Occupational asthma caused by African maple (Obeche) and Ramin: evidence of cross reactivity between these two woods. Clin Allergy. 1986;16(2):145-53. [pmid: 3518985].
240 Quirce S, Cuevas M, Diez-Gomez ML, et al. Respiratory allergy to Aspergillus-derived enzymes in bakers' asthma. J Allergy Clin Immunol. 1992;90(6 I):970-8. [pmid: 1281180].
241 Quirce S, Hinojosa M, Maranon F, et al. Identification of obeche wood (Triplochiton scleroxylon) allergens associated with occupational asthma. J Allergy Clin Immunol. 2000;106(2):400-1. [pmid: 10932087].
242 Tabar AI, Alvarez-Puebla MJ, Gomez B, et al. Diversity of asparagus allergy: clinical and immunological features. Clin Exp Allergy. 2004;34(1):131-6. [pmid: 14720273].
243 Avery SB, Stetson DM, Pan PM, et al. Immunological investigation of individuals with toluene diisocyanate asthma. Clin Exp Immunol. 1969;4(5):585-96. [pmid: 4182406]. [pmcid: 1579066].
244 Butcher BT, O'Neil CE, Reed MA, et al. Radioallergosorbent testing of toluene diisocyanate reactive individuals using ptolyl isocyanate antigen. J Allergy Clin Immunol. 1980;66(3):213-6. [pmid: 6251126].
245 Karol MH, Tollerud DJ, Campbell TP et al. Predictive value of airways hyperresponsiveness and circulating IgE for identifying types of responses to toluene diisocyanate inhalation challenge. Am J Respir Crit Care Med 1994;149(3 Pt 1).
246 Moller DR, Gallagher JS, Bernstein DI, et al. Detection of immunoglobulin E-mediated respiratory sensitization in workers exposed to hexahydrophthalic anhydride. J Allergy Clin Immunol. 1985;75(6):663-72. [pmid: 4008795].
247 Moller DR, Brooks SM, McKay RT, et al. Chronic asthma due to toluene diisocyanate. Chest. 1986;90(4):494-9. [pmid: 3019611].
248 Zeiss CR, Patterson R, Pruzansky JJ, et al. Trimellitic anhydride-induced airway syndromes: clinical and immunologic studies. J Allergy Clin Immunol. 1977;60(2):96-103. [pmid: 68964].
249 Keskinen H, Tupasela O, Tiikkainen U, et al. Experiences of specific IgE in asthma due to diisocyanates. Clin Allergy. 1988;18(6):597-604. [pmid: 2854010].
250 Nordman H, Keskinen H, Tuppurainen M. Formaldehyde asthma. Rare or overlooked. J Allergy Clin Immunol. 1985;75(1 Pt 1):91-9. [pmid: 3968333].
251 Rasanen L, Kuusisto P, Penttila M, et al. Comparison of immunologic tests in the diagnosis of occupational asthma and rhinitis. Allergy. 1994;49(5):342-7. [pmid: 8092431].
252 Vanhanen M, Tuomi T, Tupasela O, et al. Cellulase allergy and challenge tests with cellulase using immunologic assessment. Scand J Work Environ Health. 2000;26(3):250-6. [pmid: 10901118].
253 Zeiler T, Taivainen A, Mantyjarvi R, et al. Threshold levels of purified natural Bos d 2 for inducing bronchial airway response in asthmatic patients. Clin Exp Allergy. 2002;32(10):1454-60. [pmid: 12372125].
254 Choudat D, Fabries JF, Martin JC, et al. Quantification of the dose of inhaled flour: relation with nonspecific bronchial and immunological reactivities. Eur Respir J. 1999;14(2):328-34. [pmid: 10515409].
255 Kopferschmitt-Kubler MC, Frossard N, Rohde G, et al. Increase in non-specific bronchial hyperresponsiveness without specific response to isocyanate in isocyanate-induced asthma: a pilot study. Respir Med. 1998;92(9):1093-8. [pmid: 9926161].
256 Nielsen J, Welinder H, Schütz A, et al. Specific serum antibodies against phthalic anhydride in occupationally exposed subjects. J Allergy Clin Immunol. 1988;82:126-33. [pmid: 3392364].
257 Prichard MG, Ryan G, Musk AW. Wheat flour sensitisation and airways disease in urban bakers. Br J Ind Med. 1984;41(4):450-4. [pmid: 6498109]. [pmcid: 1009368].
258 Kongerud J, Soyseth V, Burge PS. Serial measurements of peak expiratory flow and responsiveness to methacholine in the diagnosis of aluminium potroom asthma. Thorax. 1992;47:292-7. [pmid: 1585295]. [pmcid: 463699].
259 Shirakawa T, Kusaka Y, Fujimura N, et al. The existence of specific antibodies to cobalt in hard metal asthma. Clin Allergy. 1988;18:451-60. [pmid: 3233723].
260 De Zotti R, Gubian F. Asthma and rhinitis in wooding workers. Allergy Asthma Proc. 1996;17(4):199-203. [pmid: 8871738].
261 Koskela H, Taivainen A, Tukiainen H, et al. Inhalation challenge with bovine dander allergens: who needs it?. Chest. 2003;124(1):383-91. [pmid: 12853550].
262 Krakowiak A, Ruta U, Gorski P, et al. Nasal lavage fluid examination and rhinomanometry in the diagnostics of occupational airway allergy to laboratory animals. Int J Occup Med Environ Health. 2003;16(2):125-32. [pmid: 12921381].
263 Schuermans D, Verbanck S, Vincken W. Role of histamine bronchial hyperresponsiveness (BHR) in the diagnosis of occupational asthma (OA) to latex. Eur Respir Soc 2003.
264 Vandenplas O. Prevalence of occupational asthma due to latex among hospital personnel. Am J Respir Crit Care Med. 1995;151(1):54-60. [pmid: 7812572].
265 Burge PS, Harries MG, O'Brien, et al. Bronchial provocation studies in workers exposed to the fumes of electronic soldering fluxes. Clin Allergy. 1980;10:137-49. [pmid: 7389068].
266 Larbanois A, Delwiche JP, Jamart J, et al. Comparison of FEV1 and specific airway conductance in assessing airway response to occupational agents. Allergy. 2003;58(12):1256-60. [pmid: 14616100].
267 Merget R, Stollfuss J, Wiewrodt R, et al. Diagnostic tests in enzyme allergy. J Allergy Clin Immunol. 1993;92(2):264-77. [pmid: 8349937].
268 Palczynski C, Walusiak J, Krakowiak A, et al. Nasal lavage fluid examination in diagnostics of occupational allergy to chloramine. Int J Occup Med Environ Health. 2003;16(3):231-40. [pmid: 14587536].
269 Venables KM, Dally MB, Burge PS, et al. Occupational asthma in a steel coating plant. Br J Ind Med. 1985;42(8):517-524. [pmid: 2990525]. [pmcid: 1007521].
270 Malo J L,, Ghezzo H. Recovery of methacholine responsiveness after end of exposure in occupational asthma. Am J Respir Crit Care Med. 2004;169(12):1304-7. [pmid: 15070824].
271 Jyo T, Kodomari Y, Kodomari N, et al. Therapeutic effect and titers of the specific IgE and IgG antibodies in patients with sea squirt allergy Hoya asthma under a long-term hyposensitization with three sea squirt antigens. J Allergy Clin Immunol. 1989;83(2 Pt 1):386-93. [pmid: 2918184].
272 Perfetti L, Hebert J, Lapalme Y, et al. Changes in IgE-mediated allergy to ubiquitous inhalants after removal from or diminution of exposure to the agent causing occupational asthma. Clin Exp Allergy. 1998;28(1):66-73. [pmid: 9537782].
273 Boulet LP, Roberts RS, Dolovich J, et al. Prediction of late asthmatic responses to inhaled allergen. Clin Allergy. 1984;14:379-95. [pmid: 6467560].
274 O'Byrne PM, Dolovich J, Hargreave FE. Late asthmatic responses. Am Rev Respir Dis. 1987;136:740-51. [pmid: 3115156].
275 Stenton SC, Avery AJ, Walters EH, et al. Statistical approaches to the identification of late asthmatic reactions. Eur Resp J. 1994;7:806-12.
276 Lemiere C. The use of sputum eosinophils in the evaluation of occupational asthma. Curr Opin Allergy Clin Immunol. 2004;4:81-5. [pmid: 15021058].
277 Abramson MJ, Puy RM, Weiner JM. Allergen immunotherapy for asthma (Cochrane Review). In: The Cochrane Library, Issue 2, 2004. Chichester, UK: John Wiley & Sons, Ltd.).