# Acknowledgments

We are grateful to members of the technical expert panel who provided direction to the scope and content of the review, the peer-reviewers who provided valuable input into the draft report, authors of included studies who identified potentially relevant studies, staff members who provided technical assistance, and those who assisted in translating articles not published in English. These individuals are listed in Appendix F. In addition, we appreciate Natasha Weibe for her statistical advice and Marlene Dorgan for providing expertise regarding the literature search strategies, respectively.

Dr. Rowe is supported by the Canadian Institute of Health Research (CIHR) as a Canada Research Chair in Emergency Airway Diseases (Ottawa, Canada). He is also supported by the Faculty of Medicine and Dentistry and the Capital Health Authority, Edmonton, Alberta. Dr. Beach is supported by the Faculty of Medicine and Dentistry at the University of Alberta, Edmonton, Alberta.