# Discussion

## Diagnosis Systematic Review

This report summarizes all of the identified available scientific evidence relating to tests used for the diagnosis of OA. Before considering the usefulness of diagnostic tests in OA, it is important to recognize that perhaps the only unique characteristic of OA is that it is caused by workplace exposure. The symptoms, signs, results of many investigations, and the range of patho-physiologies encountered are similar to those of non-occupational asthma. Consequently, the tests that attempt to specifically diagnose OA must try to identify the causative asthmagen. Given that asthma does, by its very nature, demonstrate variability in symptoms, signs, and airflow limitation, this is unlikely to ever be a straightforward proposition.

Prior to determining the accuracy of diagnostic tests, a referenced standard must be available for comparison. The reference test in OA is SIC, described in detail in a previous section of this report. There are a number of issues that make this test problematic. First, SIC is not readily available in many countries ^23^ , thus, this reference standard diagnostic test is not often employed in diagnostic research. Second, testing with some agents may involve considerable technical challenges, particularly outside of major centers. In addition, workers are often exposed to multiple asthmagens and it may be difficult to determine precisely which asthmagen is causing OA. If the worker is challenged with the incorrect asthmagen, a false negative test result can occur.

Further, the criteria used to signify a positive SIC test varies. A 15–20 percent drop in the measured airflow (FEV_1_) generally signifies a “positive” response; however, other outcomes have also been used. ^273^ – ^275^ It is unclear how this corresponds with some important components in the definition of asthma, including inflammatory changes in the airways. Using outcome measures such as induced sputum may be one way of circumventing this problem but this is not, as yet, widely available. ^276^ Moreover, the reliability of the SIC is hard to determine. It seems likely that operator experience and volume-quality relationships are important in determining the validity of SIC testing but this has not to our knowledge been formally evaluated. Despite these limitations, SIC remains the best test available to use as a reference standard and we have elected to use this as our highest ranked “gold standard”.

Using a comprehensive search strategy and methodologically rigorous approaches to identifying diagnostic studies, there were only sufficient data available for us to meaningfully analyze the following comparisons:

- SIC versus NSBP test;
- SIC versus skin prick testing;
- SIC versus serum specific IgE.

There were other comparisons identified in the search, such as serial PEFR, sputum eosinophilia, and clinical diagnosis. However, the insufficient volume of evidence comparing these diagnostic tests to SIC prevented drawing firm conclusions. From within the available evidence, there are some valuable observations that can be made. First, a single measurement of NSBP demonstrates moderate sensitivity and a somewhat lower specificity in predicting the outcome of SIC. For HMW substances, the pooled estimate of sensitivity was 79.3 percent, while pooled specificity was 51.3 percent (positive likelihood ratio [LR+]=1.6; negative likelihood ratio [LR -]=0.4). It has been suggested that the sensitivity of a single NSBP test can be improved by measuring BHR within hours of exposure to the asthmagen. ^90,^ ^105^ It is important to recognize that these results are primarily derived from highly selected populations (usually either referred to a specialty clinic or seen as part of a workplace survey) and these results effectively represent a population with a high pre-test probability of disease. Presumably, the selection process of referral or participation in a workplace survey identified a relevant workplace exposure while NSBP confirmed asthma. Based on these data, we would suggest that a positive test would assist the clinician to rule-in OA without being completely confirmatory; however, a negative NSBP test would not rule-out OA unlikely, especially in lower-risk groups.

Second, immunological testing may be of importance, depending on the compounds tested. Clearly such testing will be more useful for those sensitizers that are known to work via an immunological response and may be of little use where immunological sensitizers are either unknown or not present. Overall, it appears that when compared to serum specific IgE, SPT shows higher sensitivity in comparison with SIC. It appears the converse is perhaps true for specificity. However, from these data is appears that SPT and serum specific IgE levels alone have limited sensitivity or specificity in at least some settings, and therefore cannot rule-in or rule-out OA with sufficient reliability to reassure the patient, the physician, or the employee of the presence or absence of OA.

Third, combining tests may enhance the specificity of testing and may be a suitable alternative to SIC in the diagnosis of OA in some people. The highest specificity seems to arise from a combination of a single measurement of NSBP test along with SPT or specific IgE in pre-screened patients. In a single study of a LMW asthmagen, combined tests provided a sensitivity of 100 percent and a specificity of 80.0 percent (LR+ = 4.2; LR- = 0.05). For NSBP test and SPT, the pooled sensitivity in HMW asthmagens is 60.6 percent and the specificity is 82.5 percent (LR+ = 3.5; LR- = 0.5). If it is assumed that clinical referral or participation in a workplace survey for suspected OA due to HMW asthmagen produces a high pre-test probability of disease (~50%), a positive combined test would support a diagnosis of OA (78% probability); negative combined testing would provide the clinician with limited certainty that OA was absent (33% probability). Further, in the setting of a lower pre-test probability (such as an un-screened sample of workers), the combined test is less confirmatory and more likely to rule-out OA.

Unfortunately, the body of research identified is insufficient to support other combinations as accurate substitutes for SIC. For example, the combination of a clinic referral, positive NSBP test, positive SPT, and positive serial peak flow monitoring has not been compared to SIC in sufficient detail to draw any conclusions. Moreover, serial testing has not been examined in sufficient detail to draw firm conclusions. While clinical diagnosis versus SIC resulted in high sensitivities among LMW, HMW, and mixed asthmagens, the specificity was lower. Moreover, due to the small number of studies for other relevant comparisons, we would be cautious in interpreting pooled estimates of sensitivity and specificity for some relevant comparisons such as serial peak flow recordings versus SIC.

A large number of different tests have been reported and used in an effort to reliably diagnose OA. In addition to SIC, these include single and serial NSBP test, serial peak flow recording, lung function testing, immunological testing, and inflammatory markers. Unfortunately, there are few comparisons that are repeated with sufficient frequency to allow a meaningful analysis. There has been considerable interest in the use of serial PEFR in the diagnosis of OA. Surprisingly, a low sensitivity (63.6 percent; 95% CI: 43.4 to 79.9 percent) and specificity (77.2 percent; 95% CI: 66.5 to 85.2 percent) was reported for serial PEFR versus SIC among a number of mixed asthmagens. The sensitivity and specificity were higher among the one study that evaluated serial PEFR versus SIC in LMW asthmagens. This may have been related to technical issues in making the recordings, such as the timing of serial measurements and the proximity of these measurements to the on/off work cycle. Further, some combinations of these tests have been suggested as useful methods for diagnosing OA. For example, combining serial PEFR and symptom diaries is recommended as a method to diagnose OA ^8^ ; however, few studies have specifically evaluated this method.

Although we had anticipated that there might be comparisons involving reference standards other than SIC, we were not able to identify sufficient comparisons utilizing these to undertake analyses that we would consider statistically meaningful. In some instances the paucity of comparative data were further compounded by the use of non-standardized methodology and the use of various end points. In addition, these studies related to different putative asthmagens and it is likely that these are associated with different mechanisms in causing OA; the performance of each of the tests may vary depending upon the agents involved in causing the asthma originally.

Further, within diagnostic test comparisons that included many studies, the sensitivity and specificity was inconsistent at predicting the outcome of SIC. Thus, although we have estimated a pooled sensitivity and specificity for some combinations of these tests we recommend caution in their interpretation. The pooled estimates of sensitivity and specificity tend to have wide confidence intervals and often the sensitivities and or specificities from individual tests ranged from 0 to 100 percent. The variation may reflect the wide range of agents that were causing OA, and hence the true reason for the tests' performance may be that the underlying mechanisms of OA are different.

Although the sensitivity and specificity of some of these tests appear to provide some value in assisting in the diagnosis of OA, it must be recognized that these results are generally produced from a very select population, as the majority of the included workers had been screened by either a questionnaire, referral to a specialist, or a medical/occupational history compatible with OA. Essentially, all the subjects who were involved in comparisons of SIC against other diagnostic techniques were pre-screened and therefore, had a high pre-test probability for testing positive to SIC. These data cannot and should not be generalized to an unselected, or unscreened population of workers. However, in a clinical setting where patients are being investigated for OA, most patients have undergone screening that is similar to that of subjects included in the studies. Alternatively, patients seen in specialty clinics by OA experts would require similar screening and that would produce similar high pretest probabilities of disease. Consequently, it may seem reasonable to apply the pooled estimates of sensitivity and specificity derived from these analyses to those groups.

The second question the diagnostic review tried to address was “in what situations would specific inhalation challenge testing provide additional useful diagnostic information?”. Unfortunately we were unable to identify sufficient relevant studies that addressed the comparative usefulness of SIC as a diagnostic tool with different agents and in different settings. Consequently any advice about the situations where SIC should be applied must remain based on expert opinion and consensus until further evidence is available.

## Management Systematic Review

This systematic review examined the best available evidence upon which to base management decisions for OA. From nearly 15,000 references, we identified 52 cohort studies and 13 CCT examining the treatment of OA. In general, the populations studied (etiological agents), study designs and quality, and outcomes reported varied considerably. Moreover, the majority of the interventions were non-randomized, so the rationale for the intervention decision was largely unknown. Overall, the primary questions proved too disparate and the results too heterogeneous to pool. Not withstanding the above concerns, some valuable general information does arise from this review.

### Cohort

First, most OA reports indicate patients have mild-moderate airflow limitation, with most studies reporting >80 percent predicted FEV_1_ at the time of initial assessment. We attempted to compare the different treatment groups using baseline percent predicted FEV_1_ data as it related to exposure status (e.g., removed from exposure, reduced exposure, and remaining exposed) to ensure that selection for the various treatments was not unduly influenced by severity of disease at baseline (time of diagnosis). We had anticipated that patient groups removed from exposure at work might demonstrate the lowest group FEV_1_ and those who continued exposure at work would demonstrate the highest group FEV_1_. It does not appear, however, that a selection bias occurred with respect to subsequent work exposure based on baseline FEV_1_ status. While formal statistical testing cannot be completed on these data, we argue that the display in Figure 10 demonstrates similar FEV_1_ irrespective of subsequent exposure risk. Conclusions based on reduced exposure groups are complicated by the paucity of studies included in this comparison.

Second, given the available data on follow-up, the review team constructed a picture of the outcomes of workers with OA, based on their exposure status and duration of follow-up. Once again, due to the vagaries of reporting we have not been able to produce statistical analyses; however, the graphic display in Figure 11 suggests several important general summary comments. Most importantly, those who remain exposed (either partially or fully) experience continued deterioration in FEV_1_ status compared to baseline and over time. In addition, most of those groups who are removed from their workplace appear to generally report improvement compared to baseline lung function at diagnosis. Despite removal, improvement does not appear to be dramatic nor progressive with time. Moreover, while most studies reported group improvement, some indicated deterioration, suggesting that the impact of OA is long-lived and difficult to “cure”. Finally, in contradistinction to the diagnosis review, no clear trends were identified based on the LMW versus HMW sensitizer agent division with respect to clinical outcomes.

Third, similar results are demonstrated for the small group of studies where NSBP were recorded at baseline and at follow-up. Once again, those groups who remained exposed experienced continued deterioration in NSBP test results compared to baseline and over time. Almost all of those groups who report being removed from their workplace appeared to have improved compared to NSBP test results at the time of diagnosis. Improvement in non-specific BHR appears to be more impressive and progressive with time than FEV_1_ results. Few groups appeared to deteriorate, suggesting that continued exposure may be required for non-specific BHR to continue to decline. Conclusions based on reduced exposure groups are complicated by the paucity of studies included in this comparison. No clear trend was identified based on the LMW versus HMW asthmagen division.

Fourth, while many studies reported symptoms and/or improvement, the definitions and measurements were too variable to analyze quantitatively. Symptoms appeared to persist and potentially worsen among workers who continued exposure. The picture is less certain among workers who were removed; there was evidence that while some workers' symptoms improve after removal from exposure, other workers failed to improve. Among workers who reduced their exposure, symptoms abated in some workers but the overall effect seemed to be persistence of symptoms. Because symptoms were often measured subjectively and using different methods, this outcome is problematic in determining the effect of removal, reduction, and continuation of exposure.

Medication use was a confounder and outcome that was incompletely reported in the majority of studies; however, using available data, we attempted to examine the three exposure status groups based on their medication use at follow-up. The conclusions from these studies are harder to draw, due to small study numbers. Overall, workers with OA, irrespective of subsequent exposure, often require medication treatment long after diagnosis. No clear trend was identified based on the LMW versus HMW asthmagen division.

Finally, the economic consequences of developing OA are impressive. From the published literature, those who leave the workplace clearly suffer economic repercussions of reduced income and/or unemployment. Workers who reduce their exposure or stay employed at the same workplace still appear to lose income over time, and their costs of medication increase. Furthermore, medical insurance coverage among workers, an important consideration in the United States, is reduced after the diagnosis of OA.

### Trials

There were a limited number of clinical trials performed in the OA field. Overall, the 13 included clinical trials were of only moderate methodological quality. For example, while eight (62 percent) were randomized, none reported their method of randomization; seven (54 percent) were double-blinded, yet none described their methods of ensuring double-blinding; and only two (15 percent) demonstrated adequate concealment of allocation. All studies reported losses to follow-up and withdrawals.

From the 13 clinical trials examining OA interventions, the total number of study patients is 210, with the largest trial enrolling only 32 patients. One study involved immunotherapy, two involved reducing exposure via protective measures and the remaining were medication studies. Overall, the immunotherapy results, based on a small overall sample (n=30 patients) examining wheat flour antigen, suggest spirometric, immunological, and symptomatic improvement when workers experiencing OA are treated with immunotherapy. A comprehensive Cochrane Review supports benefit from this therapeutic approach. From 75 trials involving 3,188 patients with asthma, Abramson et al. demonstrated that immunotherapy reduced asthma symptoms and the use of asthma medications and improved bronchial hyper-reactivity. ^277^ While this therapy may be as effective as ICS, it is complicated by its long duration (10–20 months), limited availability, and that many OA patients have a disease for which the relevant antigen for immunotherapy has yet to be identified. Finally, the possibility of adverse effects, such as allergic reactions and anaphylaxis, is a concern for some patients. It is likely most patients either would not qualify or elect to use other forms of therapy.

Trial evidence examining reduction in exposure is limited to only two clinical trials. Evidence does suggest that protective devices can reduce bronchial obstruction; however, they failed to provide complete protection and workers were required to be compliant with their use. In the situation of latex allergy-induced OA, the use of non-latex or low protein, powder-free latex gloves in the work environment appears to be a successful method of improving OA symptoms and outcome measures. ^123^

Finally, medication research in OA is limited and conclusions are difficult to draw. These medication trials suffer from small sample sizes, limited duration of treatment, and various dissimilar comparisons. Consequently, statistical pooling was not possible. In general, there is evidence that corticosteroid agents (both systemic and inhaled) are effective in the treatment of OA, although this was primarily evaluated in patients with di-isocyanate induced OA. Well recognized and parallel evidence is available regarding the effectiveness of corticosteroid treatments for chronic asthma from a variety of resources including guidelines and the Cochrane Library. Theophylline, a weak bronchodilator, reduced the severity of asthma exacerbations after SIC; however, airway responsiveness did not decrease. Other agents such as non-steroidal anti-inflammatories, calcium channel blockers, cromolyn, or placebo demonstrated limited or no benefit in the acute treatment of OA. Once again, these general effectiveness trends appear to be similar for OA and chronic asthma.

## Potential Limitations

There is a possibility of publication bias in this systematic review. For example, by missing unpublished and/or poor performing diagnostic test studies, we may be over-estimating the psychometric properties of diagnostic tests. Also, by missing unpublished negative studies we may be over-estimating the effect of OA treatment. However, a comprehensive search of the published literature for potentially relevant studies was conducted, using a systematic strategy to avoid bias. This was followed by attempts to contact corresponding and first authors. Grey (i.e., unpublished or difficult to find) literature was repeatedly searched; some unpublished studies were identified and several negative studies were uncovered. Despite these efforts, we do recognize that more of these types of studies may exist.

There is also a possibility of study selection bias; however, we employed at least two independent reviewers, and feel confident that the studies excluded were done so for consistent and appropriate reasons. Our search was comprehensive, so it is unlikely that there are many studies in press or publication that were missed.

Overall, OA literature is not indexed well and authors are not consistently using the term “occupational asthma” in article titles or abstracts. Using the subject heading “occupational diseases” will pick up many relevant articles; however, this is a very sensitive heading and includes almost 75,000 references. A second issue is that some of the relevant articles do not mention the word “asthma” or any of the terms used to describe OA in lines 1–18 of the search strategy (see Appendix A ^♦^ ). There are also a huge variety of allergens, such as chemicals, animals, and trees, which can potentially cause OA. It is impossible to account for every variation and term within the search strategy. Knowing this, the strategy was designed to be highly sensitive in order to avoid missing any potentially relevant articles. In addition, 10 databases were searched in order to retrieve as many pertinent studies as possible.

♦ The Appendices and Evidence Tables cited in this report are provided electronically at http://www.ahrq.gov/downloads/pub/evidence/pdf/asthmawork/asthwork.pdf

The classification of agents into HMW and LMW is of relevance because of their likely differing mechanisms and the implications this has for diagnostic tests. While for many agents the relevant allergens are well characterized, this classification was not without problems. For example, while grain dust contains a number of HMW agents, it likely also contains other constituents that may be LMW, or that work by other mechanisms. There was one study included in the diagnosis section of this review that examined grain dust; there is some controversy regarding the classification of grain dust as a HMW or mixed asthmagen. It is noteworthy that when this study is included with other HMW asthmagens for comparisons to SIC with NSBP test and SPT, estimates yielded a pooled sensitivity of 60.6 and specificity of 82.5. When this study is excluded from the comparison, the sensitivity and specificity improve to 83 and 100, respectively. Further combination testing research is needed to resolve this debate.

For other agents, such as platinum, their mechanism of action may be a more important characteristic than their molecular weight, but characterization by molecular weight seemed the best categorization available. Analyses of results by other methods of categorization were not undertaken. The results are presented to allow for the calculation of an individual asthmagen's sensitivity and specificity.

### Diagnosis Review

The evidence concerning the harms (false positive and false negative) of diagnosis of OA is even less developed than the evidence for the benefits. Essentially, these patients have not been followed for the anxiety of an incorrect diagnosis, nor have the consequences been followed in any comprehensive manner. Costs of asthma care are largely borne by the patients, families, and the employers, and the costs of OA care are largely borne by the same groups. Falsely diagnosing respiratory symptoms as OA may force patients to inappropriately change work or become unemployed. Not diagnosing respiratory symptoms as OA when such is the case may lead patients to further asthmagen exposure, worsening health, impaired QOL, and later unemployment without compensation.

While SIC is considered the reference standard test in the diagnosis of OA, some studies did not have this result available for all patients, if at all. Some studies used a clinical “consensus” diagnosis to determine the presence of OA, which may or may not have included SIC in the diagnostic process, and it was usually not clear which patients had undergone SIC and why. In other studies, only data from patients who had a positive SIC result were reported. Two forms of bias may be present as a result of these characteristics: different reference standard bias and partial verification bias. ^70^ For HMW agents, we noted that the sensitivity generated from SIC positive subjects was similar to that generated from workers with suspected OA in two of the three comparison tests we considered in depth (single NSBP testing and specific SPT). Among LMW asthmagens, the sensitivity of SPT was substantially lower in studies when only SIC positive subjects were included in the study.

The studies included in the diagnosis review display considerable heterogeneity. This heterogeneity likely arises because many different asthmagens can cause OA and the diagnostic tests do not behave identically among the various asthmagens. Unfortunately, there were not enough studies to pool sensitivities and specificities by the specific asthmagen; however, in an effort to reduce heterogeneity, the results are presented by HMW and LMW and subgrouped by the specific asthmagen. Because of the heterogeneity between studies, pooled results for sensitivity and specificity are presented separately for each of the comparison tests. A drawback to this approach is that because the calculations are done independently, the pooled results of sensitivity and specificity are not explicitly paired as they are for each of the contributing studies. The plots of sensitivity/specificity pairs in ROC space demonstrate this artifact but do not allow for a link to the detail on specific asthmagen which we believe is valuable to the reader. Controversy exists with respect to pooling of heterogeneous data. Some would argue that the pooling in this setting is unhelpful and potentially misleading, while others believe this approach provides the best estimate of the test property. We have utilized random effects modeling, as appropriate for pooling heterogenous studies. However, we advise the reader to use caution in interpreting the results presented in this report, but believe that the utility of these values should be judged by the reader. We have provided sufficient data to recalculate the sensitivity and specificity for a number of specific asthmagens. This will allow clinicians to calculate the most appropriate pooled result for use in their practice.

Among the included studies, there were various definitions of a positive test result and different protocols were used to conduct the same test. For example, a positive test result for a single NSBP test was frequently reported as PC_20_ or PD_20_ FEV_1_ ≤ 8 or 16 mg. Similarly for SPT, studies reported a positive SPT as ≥ 3 mm or compared the size of the reaction among workers with suspected OA to the size among a control population. For the purpose of this review, we treated one SIC methodology to be equivalent to another; this report does not attempt to evaluate the various methodologies used to conduct SIC.

A further limitation was that not all studies we identified were designed to be diagnostic studies and the data presented were not in a useful form to evaluate the diagnostic accuracy of a comparison test. That is, it had to be possible to generate a 2 × 2 or 2 × 1 table of the reference standard test result with a comparison test result based on one or more cut-offs of the comparison test. It is not possible to use results presented as a difference between mean values of the comparison test when grouped by the reference test result. In other cases, IPD data were available; however, the absence of an established cut-off value to define a “positive” test excluded these results. Resources and/or the long length of time between the publication of the results to the writing of this report precluded contact with most authors to obtain the necessary data in a usable form. This would have increased the number of studies that could be pooled in some of the comparisons.

### Management Review

The main limitation of the management review is that the design of the included studies was weak. For example we found very few RCTs and the methodological quality of these was, at best, moderate. Most importantly, the interventions were generally divided into removal, reduced exposure, or continued exposure; however, the definition of these approaches differed and allocation was non-randomized.

Another limitation of the management studies is that the populations differed considerably. For example, while all groups attempted to confirm the diagnosis of OA, the methods used varied and the types of asthmagens that workers were exposed to differed. We attempted to retain the HMW versus LMW division employed in the diagnostic section of the review to investigate the heterogeneity of the results; however, this was not helpful. Treatment co-interventions were also incompletely reported in these studies.

Finally, the outcome assessments were often not comparable and tended to focus on short-term spirometric results (e.g., pulmonary function tests, NSBP test, SIC, etc.) rather than QOL. There was variability in length of follow-up within and between studies, making pooling difficult. Only four studies had repeated outcome measurements at different follow-up times for the same cohort.

## Conclusions

OA is an important health care problem, particularly in certain work settings: paint use and production (di-isocyanates), the lumber industry (red cedar), bakers (flour), health care workers (latex), and other occupations. Workers with this disease generally present with respiratory symptoms such as cough, wheeze, shortness of breath, and exercise intolerance. Diagnosis and management of OA is designed to reduce morbidity and improve QOL; fortunately, mortality is rare, unless severe sensitivities exist.

Diagnosing OA is a contentious and hotly debated issue, largely because of the social and economic implications of the diagnosis to the employer and the employee. Furthermore, controversy exists because of the relative paucity of high-quality research in this field. Until such time as there is considerable more high quality information on which to base decisions, the findings from this systematic review may be unsatisfying to some.

Following a comprehensive search and selection of the electronic and grey literature using English and foreign language literature, we identified a large number of studies examining diagnostic tests in OA. Based on the evidence, the following conclusions can be made:

- The general weaknesses associated with the quality and quantity of the research evidence suggests that caution should be used in interpreting these results;
- In the diagnosis review, the sensitivities and specificities varied widely for some of the comparison tests. We elected to pool heterogeneous data from individual studies, but would encourage clinicians to interpret these results cautiously and conservatively. Moreover, we have provided sufficient data to allow clinicians to calculate values that would be most useful in their practice.
- Overall, SIC appears to be the main reference standard for the diagnosis of OA; however, its availability is limited where studied;
- If SIC is not available and the population has a high pre-test probability (e.g., screened by history, questionnaire, and/or referral to a specialist), a single NSBP testing is a common test that assists in supporting the diagnosis and is of some use in excluding OA. Its sensitivity and specificity alone are insufficiently discriminative to definitively diagnose OA;
- In isolation, none of the diagnostic tests (NSBP test, SPT, serum specific IgE, serial PEFR, serial NSBP test, etc.) yielded a sufficiently high combination of sensitivity and specificity which would be required for a test to be a used routinely as a substitute for the reference standard used in this report (SIC);
- The specificity of NSBP testing can be enhanced by the addition of other testing, especially SPT or serum specific IgE;
- Many other combination tests (e.g., repeat of the NSBP testing which demonstrates decreases associated with removal from the workplace, serum specific IgE, serial peak flow, etc.) have not be evaluated in sufficient detail to provide recommendations;
- While current clinical recommendations suggest a diagnosis be made by examining the results of a number of sequential tests, we did not find sufficient data to evaluate this option.

Following a similar comprehensive search, we identified a moderate number of studies examining the treatment of OA. Based on the evidence, the following conclusions can be drawn:

- The general, weaknesses associated with the methodological quality of the research evidence suggests that caution should be used in interpreting these results;
- Overall, the baseline FEV_1_ does not appear to predict which worker groups will leave the workplace or remain exposed (either partially or fully);
- Workers with OA who remain exposed to the workplace asthmagens tend to experience decreased FEV_1_ over time, increased non-specific BHR, and will continue to require medications to control their symptoms;
- Most workers with OA who cease being exposed to the workplace sensitizer appear to experience improved FEV_1_ over time and less non-specific BHR; despite these improvements, many workers will continue to require medications to control their symptoms;
- Some workers with OA can be expected to continue to experience a decrease in their FEV_1_ over time despite ceasing sensitizer exposure;
- The evidence of outcome for workers who reduce their exposure is insufficient to draw firm conclusions but from the limited evidence, it seems likely they continue to have ongoing disease;
- In general, the anti-inflammatory agents (i.e., preventers) appear to be effective short-term therapy for OA; however, limited OA-specific research has been performed.

## Future Research Opportunities

Overall, this area is fraught with heterogeneity and methodological problems. It would be helpful if the methodology used in this field could be further standardized. Further, given the small number of patients reported in each study, perhaps a larger (national) agenda for the diagnosis and treatment of OA is needed. Collaborative efforts to resolve the many remaining issues will require sufficient funding, multi-centered collaboration, and innovative thinking.

The following future research priorities are recommended:

- Future OA studies should use common and internationally accepted definitions for asthma severity, other relevant population characteristics, and outcome measures;
- There in an urgent need for clear comparisons between reference standards (preferably SIC) and alternative test approaches, performed independently, and reported using standardized diagnostic test methods (sensitivity, specificity, and likelihood ratios). Combinations of comparison tests should also be assessed;
- Studies comparing diagnostic tests should ideally collect information regarding the cost of diagnosis, time to complete diagnosis, and presence of adverse events;
- SIC is not widely available and the presence of OA is often determined by non-reference standard testing. A prospective cost-benefit analysis of the non-reference standard procedures should be conducted to determine the costs and benefits associated with using tests other than SIC to determine the presence or absence of OA;
- There is an urgent need for prospective long-term outcome studies to further understand the outcomes of OA using standardized reporting;
- Longer-term medication studies are under-represented in the present literature. It is imperative to develop an evidence base that supports clinical decision making on the intensity of treatment, optimization of medication regimens, and utility of disease management interventions for various OA populations;
- There is limited evidence specifically examining work-aggravated asthma and OA without latency. Greater research is needed to determine optimal diagnostic and management techniques of these types of OA;
- Priority should be given to ensuring the highest methodological quality of the research and reporting of research conducted to investigate the diagnosis and treatment of OA;
- Because many workers with OA do not appear to improve, research should also focus on the primary prevention of OA.