# Results

## Literature Search

Using database specific search strategies, the following electronic bibliographic databases were searched: MEDLINE^®^, EMBASE^®^, CINHAL^®^, Web of Science^®^, Biological Abstracts^®^, Agricultural Index^®^, Expanded Academia^®^, Dissertation Abstracts^®^, Clinical Trials Registry^®^, National Agricultural Safety Database^®^, and the Cochrane Airways Group Trials Registry. Contact with the authors (Drs. Alvarez, Burge, Lemiere, Malo, Palczynski, and Park) generated an additional 33 potential studies. Eleven potentially relevant studies were found hand searching pertinent conference proceedings (ACCP, American Thoracic Society, and the European Respiratory Society). Additional studies were found in the reference lists of included studies. In total, 671 unique studies were reviewed. Study retrieval and selection is outlined in the flow diagram.

Studies were excluded for the following reasons: inappropriate study design (n=164); inappropriate topic (n=124); incorrect study population (n=63); inadequate data (n=58); or no tests or treatment (n=13). Upon further examination, seven studies within the diagnosis review did not provide sufficient detail to calculate a sensitivity and/or specificity, and subsequently were excluded. ^78^ – ^84^

The majority of the included studies were of subjects with OA with latency (i.e., immunologically mediated). There are few studies examining the diagnosis or management of OA without latency (i.e., caused by irritants). Therefore, the bulk of the results pertain to diagnosis and management of sensitizer induced OA.

Within the diagnosis and management review, there were several cases where there appeared to be multiple publications involving the same, or a portion of the same, cohort of workers. In such situations, the most complete study was included, and where unique information was presented, additional outcomes were extracted from the other papers. A description of these cohorts and the main outcomes reported in each publication are detailed in Appendix D. ^♦^

♦ The Appendices and Evidence Tables cited in this report are provided electronically at http://www.ahrq.gov/downloads/pub/evidence/pdf/asthmawork/asthwork.pdf

## Diagnosis Review

### Description of Included Studies

One hundred twenty-four unique cohorts were included in the diagnosis review (Appendix E: Evidence Table E-1; Table 6). The median year of publication was 1991 and all but 20 studies were published in English. Twenty-two studies were conducted in the UK, followed by 19 studies in each of Canada and Italy. The baseline characteristics of the patients are outlined in Evidence Table E-2. Excluding studies that only included patients with a confirmed diagnosis of OA, the prevalence of OA among studies including suspected OA cases ranged from 5 to 88 percent; the median prevalence of OA was 54 percent.

Table 6 Description of studies for the diagnosis of OA

| References
Published in language other than English
Italian | ^180,^ ^181,^ ^182,^ ^107,^ ^183,^ ^184,^ ^185,^ ^186^
German | ^103,^ ^85,^ ^187,^ ^188,^ ^189^
French | ^190,^ ^191,^ ^192,^ ^193^
Chinese | ^194^
Finnish | ^104^
Country of study origin
United Kingdom | ^34,^ ^195,^ ^101,^ ^99,^ ^196,^ ^197,^ ^198,^ ^102,^ ^199,^ ^91,^ ^200,^ ^201,^ ^202,^ ^203,^ ^98,^ ^204,^ ^205,^ ^206,^ ^207,^ ^208,^ ^209^
Canada | ^210,^ ^211,^ ^212,^ ^213,^ ^214,^ ^96,^ ^215,^ ^94,^ ^216,^ ^111,^ ^35,^ ^110,^ ^146,^ ^217,^ ^93,^ ^43,^ ^218,^ ^95,^ ^219^
Italy | ^180,^ ^181,^ ^182,^ ^220,^ ^221,^ ^222,^ ^113,^ ^107,^ ^183,^ ^223,^ ^184,^ ^224,^ ^225,^ ^185,^ ^186,^ ^226,^ ^227,^ ^228^
Germany | ^106,^ ^103,^ ^85,^ ^229,^ ^230,^ ^187,^ ^231,^ ^188,^ ^232^
Korea | ^233,^ ^234,^ ^235,^ ^236,^ ^151,^ ^86,^ ^237,^ ^236,^ ^238^
Spain | ^88,^ ^87,^ ^239,^ ^97,^ ^240,^ ^241,^ ^90,^ ^242^
United States | ^243,^ ^244,^ ^245,^ ^115,^ ^246,^ ^247,^ ^114,^ ^248^
Finland | ^249,^ ^250,^ ^251,^ ^104,^ ^252,^ ^160,^ ^253^
France | ^190,^ ^191,^ ^254,^ ^192,^ ^193,^ ^255^
Reference standard other than SIC
Clinical diagnosis | ^34,^ ^243,^ ^182,^ ^91,^ ^200,^ ^98,^ ^233,^ ^184,^ ^256,^ ^257,^ ^241,^ ^209,^ ^160,^ ^248,^ ^102,^ ^115,^ ^246,^ ^207^
Serial PEFR | ^258^
Suspected asthmagen
Low molecular weight
Di-isocyanates | ^243,^ ^103,^ ^210,^ ^99,^ ^196,^ ^244,^ ^214,^ ^181,^ ^222,^ ^194,^ ^215,^ ^245,^ ^249,^ ^233,^ ^255,^ ^183,^ ^223,^ ^247,^ ^224,^ ^205,^ ^206,^ ^186,^ ^226,^ ^237,^ ^227,^ ^114,^ ^90,^ ^209,^ ^232^
Chemical | ^198,^ ^102,^ ^91,^ ^203,^ ^115,^ ^204,^ ^230,^ ^246,^ ^97,^ ^256,^ ^151,^ ^259,^ ^207,^ ^248^
Wood dust | ^192,^ ^96,^ ^260,^ ^239,^ ^216,^ ^43,^ ^225,^ ^218,^ ^241,^ ^228,^ ^219^
High molecular weight
Flour | ^87,^ ^211,^ ^180,^ ^254,^ ^229,^ ^257,^ ^187,^ ^188,^ ^189^
Animal/Bird | ^261,^ ^262,^ ^104,^ ^160,^ ^253^
Latex | ^85,^ ^263,^ ^264,^ ^105^
Mixed | ^34,^ ^190,^ ^106,^ ^191,^ ^265,^ ^220,^ ^221,^ ^113,^ ^200,^ ^94,^ ^201,^ ^193,^ ^202,^ ^107,^ ^266,^ ^111,^ ^35,^ ^146,^ ^217,^ ^93,^ ^184,^ ^112,^ ^95,^ ^251^
Comparison tests
Single NSBPT | ^88,^ ^87,^ ^190,^ ^106,^ ^103,^ ^210,^ ^191,^ ^211,^ ^265,^ ^196,^ ^197,^ ^180,^ ^213,^ ^214,^ ^254,^ ^181,^ ^192,^ ^198,^ ^220,^ ^260,^ ^221,^ ^222,^ ^113,^ ^91,^ ^215,^ ^201,^ ^193,^ ^85,^ ^245,^ ^115,^ ^234,^ ^258,^ ^255,^ ^261,^ ^262,^ ^216,^ ^266,^ ^111,^ ^35,^ ^204,^ ^110,^ ^146,^ ^217,^ ^183,^ ^223,^ ^267,^ ^229,^ ^230,^ ^184,^ ^247,^ ^224,^ ^97,^ ^256,^ ^250,^ ^205,^ ^206,^ ^43,^ ^225,^ ^185,^ ^186,^ ^226,^ ^218,^ ^268,^ ^235,^ ^236,^ ^151,^ ^86,^ ^237,^ ^238,^ ^227,^ ^257,^ ^240,^ ^114,^ ^228,^ ^90,^ ^263,^ ^231,^ ^89,^ ^259,^ ^264,^ ^105,^ ^252,^ ^232,^ ^189,^ ^253^
Specific skin prick test | ^88,^ ^87,^ ^195,^ ^211,^ ^26,^ ^180,^ ^212,^ ^213,^ ^214,^ ^181,^ ^192,^ ^182,^ ^198,^ ^199,^ ^220,^ ^260,^ ^91,^ ^194,^ ^94,^ ^193,^ ^202,^ ^239,^ ^203,^ ^85,^ ^249,^ ^234,^ ^261,^ ^262,^ ^107,^ ^216,^ ^111,^ ^35,^ ^204,^ ^110,^ ^146,^ ^217,^ ^183,^ ^223,^ ^267,^ ^229,^ ^230,^ ^224,^ ^97,^ ^256,^ ^206,^ ^43,^ ^112,^ ^225,^ ^185,^ ^226,^ ^218,^ ^268,^ ^235,^ ^236,^ ^151,^ ^86,^ ^237,^ ^236,^ ^238,^ ^227,^ ^257,^ ^240,^ ^241,^ ^251,^ ^228,^ ^187,^ ^231,^ ^188,^ ^89,^ ^259,^ ^207,^ ^208,^ ^242,^ ^104,^ ^209,^ ^264,^ ^105,^ ^252,^ ^232,^ ^189,^ ^253,^ ^248^
Serum specific IgE | ^88,^ ^87,^ ^190,^ ^195,^ ^210,^ ^211,^ ^244,^ ^212,^ ^213,^ ^214,^ ^254,^ ^102,^ ^199,^ ^220,^ ^194,^ ^215,^ ^239,^ ^203,^ ^85,^ ^245,^ ^249,^ ^233,^ ^234,^ ^261,^ ^262,^ ^267,^ ^229,^ ^246,^ ^256,^ ^225,^ ^185,^ ^218,^ ^268,^ ^235,^ ^236,^ ^86,^ ^237,^ ^236,^ ^238,^ ^227,^ ^240,^ ^241,^ ^251,^ ^228,^ ^90,^ ^188,^ ^259,^ ^242,^ ^104,^ ^209,^ ^219,^ ^252,^ ^160,^ ^232,^ ^189,^ ^253,^ ^248^
Eosinophil counts | ^87,^ ^26,^ ^192,^ ^220,^ ^260,^ ^113,^ ^94,^ ^202,^ ^258,^ ^262,^ ^111,^ ^110,^ ^246,^ ^250,^ ^43,^ ^112,^ ^268,^ ^86,^ ^114,^ ^228,^ ^259^
Serial PFT | ^34,^ ^101,^ ^99,^ ^96,^ ^200,^ ^98,^ ^35,^ ^110,^ ^217,^ ^93,^ ^97,^ ^250,^ ^151,^ ^95,^ ^228,^ ^207,^ ^255,^ ^246^

Evidence Table E-3 describes the reference and comparison tests. SIC was the most commonly identified reference standard; it was performed in 105 of the studies. The next most commonly used reference standard was clinical diagnosis. Over half of the studies (67) included workers exposed to LMW agents; HMW agents were investigated in 33 studies and the probable cause could not be classified in one study. Various chemicals were most often believed to be the agent responsible for OA, of which di-isocyanates were the most represented chemical. The second most commonly identified agent was wood dust. Not all studies had workers with a uniform exposure and/or type of OA: 23 studies included workers from several different occupations with various probable causes of OA. Eighty-five studies reported single NSBP test as one of their outcome measures. Other frequently reported outcomes were: atopy and/or specific SPT, serum specific IgE, eosinophil counts obtained either from serum or sputum, and serial PEFR. Only one study examined workers with RADS.

### Methodological Quality of Included Studies

The methodological quality is described in Appendix E: Evidence Table E-4; Table 7. Workers were infrequently selected consecutively or randomly; 37 studies failed to report the selection method and the remaining studies used alternative methods, such as choosing some workers in a factory or some clinic patients. The majority of the included studies collected data prospectively. Data were collected retrospectively in 14 studies and whether the study was prospective or retrospective could not be established in six other studies. Blinded assessment of either the reference standard or comparison test occurred in 21 trials; however, only three studies reported that both the reference standard and comparison test results were assessed blindly. Partial blinding was inadequate in four trials. The remaining studies did not mention blinding status. The methodology used for the reference standard test, most commonly SIC, was adequately described in approximately 73 percent of the studies; the description was inadequate in the remaining studies.

Table 7 Methodological quality of studies for the diagnosis of OA

| References
Subject selection
Random or consecutive | ^34,^ ^96,^ ^221,^ ^98,^ ^249,^ ^261,^ ^266,^ ^110,^ ^146,^ ^230,^ ^250,^ ^43,^ ^104,^ ^105,^ ^160,^ ^253^
Not reported | ^190,^ ^195,^ ^103,^ ^191,^ ^197,^ ^244,^ ^180,^ ^213,^ ^192,^ ^182,^ ^220,^ ^222,^ ^194,^ ^193,^ ^239,^ ^107,^ ^183,^ ^223,^ ^184,^ ^256,^ ^206,^ ^185,^ ^186,^ ^226,^ ^235,^ ^151,^ ^95,^ ^227,^ ^251,^ ^114,^ ^187,^ ^90,^ ^263,^ ^219,^ ^252,^ ^232,^ ^189^
Data collection
Retrospective | ^34,^ ^99,^ ^244,^ ^213,^ ^249,^ ^35,^ ^217,^ ^93,^ ^224,^ ^250,^ ^225,^ ^240,^ ^242,^ ^209^
Could not be determined | ^201,^ ^85,^ ^107,^ ^266,^ ^188,^ ^189^
Blinded assessment of outcome
Reference standard and comparison test | ^111,^ ^35,^ ^110^
Reference standard or comparison test | ^87,^ ^210,^ ^99,^ ^265,^ ^212,^ ^182,^ ^96,^ ^113,^ ^94,^ ^201,^ ^98,^ ^258,^ ^262,^ ^204,^ ^217,^ ^256,^ ^43,^ ^268,^ ^236,^ ^209,^ ^105^
Inadequate | ^194,^ ^226,^ ^252,^ ^248^
Adequately described reference standard | ^88,^ ^87,^ ^34,^ ^106,^ ^103,^ ^210,^ ^211,^ ^26,^ ^101,^ ^99,^ ^265,^ ^180,^ ^212,^ ^213,^ ^214,^ ^254,^ ^181,^ ^192,^ ^96,^ ^199,^ ^220,^ ^260,^ ^221,^ ^91,^ ^194,^ ^215,^ ^94,^ ^201,^ ^193,^ ^202,^ ^239,^ ^203,^ ^85,^ ^245,^ ^115,^ ^249,^ ^234,^ ^255,^ ^261,^ ^262,^ ^216,^ ^266,^ ^111,^ ^35,^ ^110,^ ^146,^ ^93,^ ^183,^ ^223,^ ^267,^ ^229,^ ^230,^ ^184,^ ^246,^ ^224,^ ^97,^ ^256,^ ^250,^ ^205,^ ^206,^ ^43,^ ^225,^ ^185,^ ^186,^ ^226,^ ^218,^ ^235,^ ^236,^ ^151,^ ^86,^ ^237,^ ^236,^ ^238,^ ^227,^ ^240,^ ^251,^ ^228,^ ^90,^ ^231,^ ^89,^ ^242,^ ^104,^ ^209,^ ^264,^ ^105,^ ^252,^ ^160,^ ^232,^ ^189,^ ^253,^ ^248^
Differential bias | ^88,^ ^195,^ ^211,^ ^212,^ ^113,^ ^200,^ ^201,^ ^203,^ ^234,^ ^261,^ ^107,^ ^35,^ ^146,^ ^93,^ ^246,^ ^205,^ ^236,^ ^86,^ ^236,^ ^228,^ ^90,^ ^208,^ ^242,^ ^219,^ ^264,^ ^160^
Could not be determined | ^190,^ ^103,^ ^26,^ ^180,^ ^214,^ ^181,^ ^199,^ ^91,^ ^194,^ ^98,^ ^216,^ ^250,^ ^186,^ ^218,^ ^227,^ ^241,^ ^187,^ ^263^
Partial verification bias | ^88,^ ^190,^ ^195,^ ^211,^ ^214,^ ^182,^ ^199,^ ^113,^ ^91,^ ^200,^ ^98,^ ^85,^ ^233,^ ^234,^ ^204,^ ^110,^ ^146,^ ^183,^ ^184,^ ^225,^ ^185,^ ^236,^ ^86,^ ^251,^ ^228,^ ^231,^ ^188,^ ^104,^ ^219,^ ^264,^ ^189^
Could not be determined | ^243,^ ^103,^ ^26,^ ^180,^ ^181,^ ^198,^ ^220,^ ^194,^ ^258,^ ^107,^ ^216,^ ^250,^ ^206,^ ^186,^ ^227,^ ^241,^ ^187,^ ^263^
Asthma medication stopped prior to testing | ^88,^ ^87,^ ^265,^ ^254,^ ^96,^ ^220,^ ^221,^ ^113,^ ^91,^ ^215,^ ^94,^ ^202,^ ^245,^ ^115,^ ^255,^ ^261,^ ^216,^ ^35,^ ^146,^ ^223,^ ^267,^ ^229,^ ^230,^ ^247,^ ^224,^ ^97,^ ^250,^ ^43,^ ^226,^ ^218,^ ^268,^ ^237,^ ^227,^ ^240,^ ^251,^ ^90,^ ^231,^ ^89,^ ^242,^ ^104,^ ^253^
Source of funding
Government | ^243,^ ^211,^ ^96,^ ^113,^ ^94,^ ^115,^ ^234,^ ^266,^ ^223,^ ^268,^ ^227,^ ^219^
Foundation | ^195,^ ^216,^ ^111,^ ^256,^ ^43,^ ^240,^ ^160^
Internal | ^261,^ ^235,^ ^86,^ ^236,^ ^114^
Private | ^205,^ ^206,^ ^238,^ ^105^
Other (including multiple sources) | ^34,^ ^210,^ ^244,^ ^212,^ ^214,^ ^200,^ ^245,^ ^247,^ ^253,^ ^248,^ ^88,^ ^254,^ ^203,^ ^229,^ ^237,^ ^257,^ ^264,^ ^232^

Differential bias is likely to have occurred in 26 of the studies and could not be assessed in 18 studies; the other studies did not have this bias. Partial verification bias was present in 31 studies and it was unclear if it had occurred in a further 18 studies. Partial verification bias did not occur in the remaining 75 studies. Forty-one of the studies reported that workers stopped, or attempted to stop, asthma medication prior to diagnostic testing. Funding was not reported in 78 of the 124 studies. Among studies with one source of funding, funding was most commonly provided by a government agency; 10 studies had multiple sources of funding.

### Quantitative Results

One hundred thirty-one publications reporting data on 124 cohorts met the inclusion criteria for the diagnostic component of this review. After selecting the most efficient comparison within a study for each comparison test, and ensuring that a comparison test was only reported once for a cohort, the most frequently reported comparison tests included single NSBP test (n=61), specific SPT (n=47), serum specific IgE antibodies (n=41), clinical diagnoses (n=9), serial pulmonary function tests (generally PEFR) (n=9), eosinophil count (n=6), and serial NSBP test (n=6).

In addition, some studies reported sufficient information to investigate the utility of combining comparison tests. These combinations primarily consisted of single NSBP test with SPT and/or serum specific IgE. For the most frequently reported comparisons, results based on the molecular weight of the suspected agent are summarized below and individual study results have been plotted in figures. In addition, pooled results from less frequently reported comparisons and combinations of comparison tests are reported. However, due to the between-study heterogeneity, which can be seen in the figures, pooled results should be interpreted with caution. Finally, because the majority of the workers included in the individual studies were screened-in, the results presented below are probably best interpreted as the patients also being “positive” for history, questionnaire, and/or referral to a specialist. For example, the comparison should be interpreted as screening and single NSBP test versus screening and SIC.

A summary of sensitivity and specificity of comparison tests that used SIC as the reference test is provided in Appendix H.

Single NSBP test versus SIC. Sixty-one studies reported sensitivity and/or specificity for single readings of NSBP testing compared to SIC. Individual study results for LMW, HMW and mixed agents are shown in Figures 1, 2, and 3 respectively. The sensitivity/specificity pairs are plotted in Figure 4. When we considered the methodological parameters of the studies, no clear patterns emerged (Appendix G).

Figure 1. Sensitivity and specificity extracted from studies comparing single NSBP test to SIC among LMW asthmagens

Figure 2. Sensitivity and specificity extracted from studies comparing single NSBP test to SIC among HMW asthmagens

Figure 3. Sensitivity and specificity extracted from studies comparing single NSBP test to SIC among mixed asthmagens

Figure 4. Sensitivity and specificity pairs from studies comparing NSBP test with SIC

The size of the plotting character is proportional to the number of patients in the group and the color indicates the molecular weight of the suspected asthmagen (white=HMW, black=LMW, grey=mixed).

Among the 37 studies that investigated patients exposed to LMW agents, 24 reported both sensitivity and specificity. The pooled estimate of sensitivity was 66.7 percent (95% confidence interval [CI]: 58.4 to 74.0 percent) and of specificity was 63.9 percent (95% CI: 56.1 to 71.0 percent). Pooled estimates for studies that reported only sensitivity were higher (n=13; 76.6 percent; 95% CI: 59.0 to 88.2 percent).

Of the 13 studies that reported results from investigations of HMW agents, 10 reported sensitivity and specificity. The pooled estimate for sensitivity was 79.3 percent (95% CI: 67.7 to 87.6 percent) and for specificity was 51.3 percent (95% CI: 35.2 to 67.2 percent). The estimated sensitivity in the five studies reporting only this data was similar (75.5 percent; 95% CI: 56.4 to 88.1 percent).

Nine studies reported results for various suspected agents of differing molecular weights and five studies reporting both sensitivity and specificity. For these mixed populations, the pooled estimate of sensitivity was 83.7 percent (95% CI: 66.8 to 92.9 percent) and specificity was 48.4 percent (95% CI: 25.9 to 71.6 percent). Sensitivity was lower in the three studies reporting only this value (43.7 percent; 95% CI: 10.9 to 83.0 percent).

Specific skin prick test versus SIC. Forty-seven studies reported comparisons of specific SPT to SIC.

Sixteen studies reported results of SPT using the following LMW agents: bleaching powder, reactive dyes, wood dust (exotic and western red cedar), chemicals, and di-isocyanates (see Figure 5). Among the five studies reporting both sensitivity and specificity, the pooled estimate of sensitivity was 72.9 percent (95% CI: 59.7 to 83.0 percent) and of specificity was 86.2 percent (95% CI: 77.4 to 91.9 percent). Sensitivity was lower in the 11 studies reporting only this result (51.8 percent; 95% CI: 28.5 to 74.4 percent).

Figure 5. Sensitivity and specificity extracted from studies comparing specific SPT test to SIC among LMW asthmagens

Of the 16 studies that reported both sensitivity and specificity for patients exposed to HMW agents, the pooled estimate of sensitivity was 80.6 percent (95% CI: 69.8 to 88.1- percent) and of specificity was 59.6 percent (95% CI: 41.7 to 75.3 percent). Sensitivity was similar (80.9 percent; 95% CI: 60.5 to 92.1 percent) in the 10 studies reporting only that result. Results are shown in Figure 6.

Figure 6. Sensitivity and specificity extracted from studies comparing specific SPT test to SIC among HMW asthmagens

Among the five studies that included patients exposed to various agents, the pooled estimates for sensitivity and specificity were lower than either high or low molecular weight agents. The pooled estimate of sensitivity was 63.0 percent (95% CI: 41.5 to 80.3 percent) and specificity was 59.2 percent (95% CI: 45.4 to 71.7 percent). Results are shown in Figure 7.

Figure 7. Sensitivity and specificity extracted from studies comparing specific SPT test to SIC among mixed asthmagens

The sensitivity/specificity pairs for each molecular weight group are plotted in Figure 8.

Figure 8. Sensitivity and specificity pairs from studies comparing SPT to SIC

The size of the plotting character is proportional to the number of patients in the group and the color indicates the molecular weight of the suspected asthmagen (white=HMW, black=LMW, grey=mixed).

Serum specific IgE antibodies versus SIC. Forty studies reported sensitivity and 19 reported specificity for serum specific IgE compared to SIC. Of those, 21 studies included patients exposed to LMW substances such as bleaching powder, reactive dyes, wood dust (exotic and western red cedar), chemicals, and, di-isocyanates (see Figure 9); 16 included patients exposed to HMW agents (see Figure 10); and three included patients exposed to substances with variable molecular weights (see Figure 11). The sensitivity/specificity pairs are plotted in Figure 12.

Figure 9. Sensitivity and specificity extracted from studies comparing serum specific IgE test to SIC among LMW asthmagens

Figure 10. Sensitivity and specificity extracted from studies comparing serum specific IgE test to SIC among HMW asthmagens

Figure 11. Sensitivity and specificity extracted from studies comparing serum specific IgE test to SIC among mixed asthmagens

Figure 12. Sensitivity and specificity pairs from studies comparing specific IgE with SIC

The size of the plotting character is proportional to the number of patients in the group and the color indicates the molecular weight of the suspected asthmagen (white=HMW, black=LMW, grey=mixed).

Eleven out of the 21 studies considering LMW agents reported both sensitivity and specificity; the pooled estimate of sensitivity was 31.2 percent (95% CI: 22.9 to 40.8 percent) and of specificity was 88.9 percent (95% CI: 84.7 to 92.1 percent). Of the 10 studies that only reported sensitivity, the pooled estimate was 35.9 percent (95% CI: 23.2 to 50.9 percent).

Sensitivity was higher in the studies where HMW agents were examined; the pooled estimate of sensitivity was 73.7 percent (95% CI: 63.9 to 81.0 percent) for the nine studies reporting sensitivity and specificity and 81.7 percent (95% CI: 57.8 to 93.5 percent) for the nine studies reporting sensitivity alone. The pooled estimate of specificity was 79.0 percent (95% CI: 50.5 to 93.3 percent).

The two studies using a variety of molecular weight agents reported both sensitivity and specificity. The pooled estimate for sensitivity was 85.1 percent (95% CI: 40.3to 98.0 percent) and of specificity was 61.2 percent (95% CI: 7.0 to 97.1 percent).

Combined results with single NSBP test, serum specific IgE, and specific SPT compared to SIC. When possible, results were combined for the most frequently reported comparison tests. In the first assessment, all tests in combination had to be positive for the combined result to be considered positive. If any result was negative, the combination testing was considered negative. We report results from studies reporting sensitivity and specificity for LMW and HMW agents.

When a single NSBP test and specific SPT were considered in combination, four studies investigated patients exposed to HMW agents. ^85^ – ^88^ The pooled estimate of sensitivity was 60.6 percent (95% CI: 21.0 to 89.9 percent) and of specificity was 82.5 percent (95% CI: 54.0 to 95.0 percent) respectively. Sensitivity was 100 percent (95% CI: 74.1 to 100 percent) and specificity was 80 percent (95% CI: 49.0 to 94.3 percent) in the one study that investigated green tea (a LMW agent). ^89^

Single NSBP test and serum specific IgE results could be combined for only three studies reporting both sensitivity and specificity. For two studies of HMW agents, the pooled sensitivity was 35.6 percent (95% CI: 1.2 to 96.1 percent) and 84.6 percent specificity (95% CI: 48.2 to 97.0 percent). ^86,^ ^87^ The third study examined OA caused by isocyanates and resulted in 0 percent sensitivity (95% CI: 0 to 49.0 percent) and 100 percent specificity (95% CI: 61.0 to 100 percent). ^90^

In a second analysis, the combination of a positive single NSBP test and either a positive specific SPT or positive serum specific IgE was considered positive. Three studies of HMW agents yielded results which could be combined in this manner ^86^ – ^87^ The pooled estimate of sensitivity was 60.4 percent (95% CI: 11.8 to 94.5 percent) and specificity 81.5 percent (95% CI: 47.8 to 95.5 percent).

Other comparisons. Nine studies reported serial pulmonary function tests versus SIC; all but one study ^91^ recorded PEFR. Of these, five studies investigated mixed agents and reported both sensitivity and specificity. ^35,^ ^92^ – ^95^ The pooled estimate of sensitivity was 63.6 percent (95% CI: 43.4 to 79.9 percent) and of specificity was 77.2 percent (95% CI: 66.5 to 85.2 percent). One study of a LMW agent reported 86.7 percent (95% CI: 59.5 to 96.6 percent) sensitivity and 90 percent (95% CI: 53.3 to 98.6 percent) specificity. ^96^ Two other studies only reported sensitivity resulting in a pooled estimate of 56.2 percent (95% CI: 17.2 to 88.8 percent). ^91,^ ^97^ Finally, one study of a HMW agent reported 100 percent (95% CI: 56.6 to 100 percent) sensitivity and no results for specificity. ^98^

All nine studies that compared clinical diagnosis to SIC reported both sensitivity and specificity. Clinical diagnosis ranged from physician assessment to a combination of tests, which may have included pulmonary function tests, NSBP test, symptom questionnaires, etc. Five studies investigated LMW agents and the pooled estimate of sensitivity was 93.6 percent (95% CI: 85.0 to 97.5 percent) and of specificity was 68.9 percent (95% CI: 54.7 to 80.3 percent). ^99^ – ^103^ The pooled estimates of sensitivity and specificity were 93.7 percent (95% CI: 69.3 to 99.0 percent) and 32.3 percent (95% CI: 7.5 to 73.8 percent) respectively in the two studies reporting results for HMW agents. ^104,^ ^105^ Combined results of the two studies considering agents of various molecular weight yielded a sensitivity of 95.1 percent (95% CI: 86.8 to 98.3 percent) and specificity of 47.7 percent (95% CI: 26.7 to 69.7 percent). ^106,^ ^107^

Six studies reported serial NSBP tests compared to SIC and all reported sensitivity and specificity. Pooled results from the three studies investigating mixed agents yielded 50 percent sensitivity (95% CI: 35.5 to 64.5 percent) and 66.8 percent specificity (95% CI: 53.3 to 78.0 percent). ^92,^ ^95,^ ^108^ Two studies involved only patients exposed to LMW agents; pooled sensitivity was 67.5 percent (95% CI: 42.6 to 85.3 percent) and specificity was 65.6 percent (95% CI: 41.1 to 84.0 percent). ^109,^ ^110^ A study of OA caused by oil seed rape flour (a HMW agent) yielded 100 percent sensitivity and specificity. ^87^

Six studies reported eosinophil counts from sputum, blood, or broncho-alveolar lavage versus SIC of which four considered various agents causing OA. Of these, three ^94,^ ^111,^ ^112^ reported sensitivity and specificity. The pooled estimate of sensitivity was 54.9 percent (95% CI: 23.7 to 82.7 percent) and of specificity was 72.3 percent (95% CI: 54.1 to 85.3 percent); one study reported 100 percent sensitivity only. ^113^ Two studies of LMW agents reported sensitivity only. ^26,^ ^114^ The pooled estimate of sensitivity was 53.1 percent (95% CI: 10.3 to 91.8 percent).

RADS. Only one study examined workers with RADS. ^115^ Fifty-six hospital workers were exposed to 100 percent acetic acid; within 24 hours eight workers met the RADS criteria. Eight months later, a questionnaire was administered to determine the degree to which workers experienced respiratory symptoms after the chemical spill. Fifty-one workers completed the survey. Approximately 9 months after the spill, a NSBP test was performed among 24 of the exposed workers, including seven of the eight workers who met the criteria for RADS (persistent respiratory symptoms). Four of the seven workers had a positive methacholine challenge, defined as provocative dose causing a 20 percent drop in FEV_1_ [(PD_20_) FEV_1_] >20 percent (no dose cut-off was reported).

None of the included studies reported cost of diagnosis, time to complete diagnosis, or the presence of adverse events.

## Management Review

### Description of Included Studies

Cohort. There were 67 publications referring to 52 cohorts included in the review (Appendix E: Evidence Table E-5; Table 8). The median year of publication was 1996. Eleven studies were conducted in the UK, followed in decreasing order by Italy, Canada, and the United States. Two studies examined workers with RADS; the workers were exposed to sulfur dioxide in a pyrite mine explosion in one study ^116^ and pipefitters were exposed to chlorine at a paper mill over a 3 month period. ^4^ The baseline characteristics of the included workers are described in Evidence Table E-6.

Table 8 Description of studies for the management of OA

| References
Published in language other than English
German | ^172^
Italian | ^140^
Spanish | ^169^
Country of study origin
United Kingdom | ^158,^ ^131,^ ^58,^ ^163,^ ^141,^ ^22,^ ^159,^ ^177,^ ^176,^ ^269,^ ^173^
Canada | ^134,^ ^136,^ ^143,^ ^55,^ ^147,^ ^132,^ ^179,^ ^4,^ ^270,^ ^135^
Italy | ^133,^ ^145,^ ^166,^ ^144,^ ^130,^ ^153,^ ^137,^ ^56,^ ^148,^ ^140^
United States | ^142,^ ^167,^ ^164,^ ^174,^ ^175,^ ^178^
Finland | ^116,^ ^152^
France | ^57,^ ^139^
Germany | ^170,^ ^172^
Korea | ^151,^ ^171^
Spain | ^165,^ ^169^
Other | ^271,^ ^149,^ ^154,^ ^150^
Suspected asthmagen
Low molecular weight
Di-isocyanates | ^142,^ ^163,^ ^143,^ ^141,^ ^133,^ ^169,^ ^144,^ ^130,^ ^153,^ ^171,^ ^137,^ ^139,^ ^148,^ ^269^
Chemical | ^158,^ ^174,^ ^175,^ ^4,^ ^170,^ ^165,^ ^151,^ ^116,^ ^56,^ ^173^
Other | ^131,^ ^150,^ ^172,^ ^149,^ ^55^
High molecular weight
Latex | ^167,^ ^178,^ ^138^
Animal/Bird | ^177,^ ^152^
Flour | ^154,^ ^176^
Other | ^271,^ ^132,^ ^159^
Mixed | ^134,^ ^57,^ ^58,^ ^164,^ ^136,^ ^147,^ ^179,^ ^270,^ ^145,^ ^166,^ ^135,^ ^22,^ ^140^
Subject source
Clinic | ^134,^ ^57,^ ^158,^ ^131,^ ^58,^ ^164,^ ^154,^ ^178,^ ^136,^ ^143,^ ^55,^ ^141,^ ^147,^ ^179,^ ^4,^ ^145,^ ^166,^ ^165,^ ^169,^ ^151,^ ^171,^ ^135,^ ^137,^ ^56,^ ^139,^ ^150,^ ^140,^ ^152,^ ^138^
Workplace | ^142,^ ^175,^ ^163,^ ^170,^ ^172,^ ^149,^ ^153,^ ^116,^ ^159,^ ^177,^ ^269,^ ^173^
Not reported | ^167,^ ^174,^ ^271,^ ^132,^ ^270,^ ^133,^ ^144,^ ^130,^ ^22,^ ^148,^ ^176^
Exposure Status
Removed | ^134,^ ^57,^ ^158,^ ^167,^ ^131,^ ^58,^ ^164,^ ^154,^ ^174,^ ^175,^ ^163,^ ^136,^ ^143,^ ^55,^ ^141,^ ^147,^ ^132,^ ^179,^ ^4,^ ^270,^ ^133,^ ^170,^ ^172,^ ^166,^ ^165,^ ^169,^ ^144,^ ^130,^ ^153,^ ^151,^ ^171,^ ^135,^ ^116,^ ^137,^ ^56,^ ^139,^ ^22,^ ^148,^ ^159,^ ^150,^ ^138,^ ^173^
Reduced | ^57,^ ^142,^ ^167,^ ^131,^ ^218,^ ^175,^ ^163,^ ^141,^ ^170,^ ^166,^ ^153,^ ^272,^ ^116,^ ^137,^ ^139,^ ^176,^ ^138,^ ^269^
Continued exposure | ^57,^ ^167,^ ^58,^ ^55,^ ^133,^ ^145,^ ^170,^ ^166,^ ^149,^ ^144,^ ^56,^ ^139,^ ^150,^ ^176^
Used PPEs | ^57,^ ^167,^ ^178,^ ^165,^ ^169,^ ^139,^ ^177,^ ^152^
Medications (+/- removal) | ^271,^ ^140^
Outcomes
NSBP tests | ^134,^ ^142,^ ^158,^ ^131,^ ^43,^ ^59,^ ^154,^ ^141,^ ^147,^ ^132,^ ^4,^ ^270,^ ^133,^ ^145,^ ^170,^ ^172,^ ^166,^ ^165,^ ^149,^ ^144,^ ^130,^ ^153,^ ^151,^ ^155,^ ^135,^ ^116,^ ^137,^ ^56,^ ^139,^ ^148,^ ^150,^ ^140,^ ^138,^ ^173^
Pulmonary function tests | ^134,^ ^142,^ ^158,^ ^131,^ ^59,^ ^154,^ ^174,^ ^175,^ ^163,^ ^55,^ ^141,^ ^147,^ ^132,^ ^4,^ ^133,^ ^145,^ ^170,^ ^166,^ ^165,^ ^144,^ ^135,^ ^116,^ ^137,^ ^56,^ ^139,^ ^150,^ ^177,^ ^140,^ ^152,^ ^138,^ ^269,^ ^173^
Questionnaires | ^134,^ ^57,^ ^142,^ ^158,^ ^131,^ ^43,^ ^59,^ ^58,^ ^164,^ ^154,^ ^174,^ ^175,^ ^136,^ ^143,^ ^141,^ ^147,^ ^132,^ ^170,^ ^166,^ ^135,^ ^56,^ ^139,^ ^22,^ ^138,^ ^269,^ ^173^
Specific skin prick test | ^158,^ ^167,^ ^168,^ ^154,^ ^136,^ ^143,^ ^141,^ ^170,^ ^165,^ ^144,^ ^135,^ ^137,^ ^56,^ ^177,^ ^173^
SIC | ^178,^ ^136,^ ^143,^ ^141^
| ^133,^ ^156,^ ^165,^ ^144,^ ^153,^ ^56,^ ^148,^ ^150,^ ^138^
Serum specific IgE | ^158,^ ^154,^ ^174,^ ^175,^ ^271,^ ^136,^ ^143,^ ^132,^ ^171,^ ^272,^ ^159,^ ^173^

The most commonly identified asthmagens in these studies were chemicals, of which 14 of the studies examined di-isocyanates. Thirteen studies included workers with OA caused by various agents. Workers were most often recruited from an OA clinic or the workplace. The median sample size of the included studies was 26 workers (range: 3–1011). Length of follow-up was variable within and between studies.

The interventions and outcomes are outlined in Evidence Table E-7. Twenty-nine cohorts reported results on one group of workers who all received the same intervention. Seventeen cohorts reported results from two intervention groups; three cohort studies reported on three intervention groups; and three cohorts reported on four intervention groups. The most common intervention was removal from the workplace (n=42 [81%]). Fourteen studies reported results for subjects who continued exposure and, reduced exposure was assessed in 18 studies. Eight studies examined the effectiveness of PPE, while two studies compared the use of medication. The most commonly reported outcomes were NSBP tests and pulmonary function tests. Other tests reportedly completed at follow-up visits included: questionnaires, SPT, SIC, and serum specific IgE.

Trials. Thirteen trials were included in this review (Appendix E: Evidence Table E-8). The median year of publication was 1990 and all but two trials ^117,^ ^118^ were conducted in Europe. Patients were not randomized to the treatment groups in four of the trials ^119^ – ^122^ and eight employed a crossover design. ^117,^ ^119,^ ^120,^ ^123^ – ^127^ The most common asthmagen studied was di-isocyanates ^120,^ ^122,^ ^124^ – ^128^ , followed by flour ^121,^ ^129^ . Evidence Table E-9 describes the baseline characteristics of workers.

Evidence Table E-10 depicts the interventions and outcomes examined in the trials. Two trials assessed methods to reduce the level of asthmagen exposure ^119,^ ^123^ , including using a respirator and using hypo-allergenic latex gloves. The remaining studies examined the efficacy of various drugs, including anti-inflammatory agents, bronchochodilators, and immunotherapy. Specifically, the types of drugs tested included: beclomethasone (four trials ^117,^ ^125,^ ^126,^ ^128^ ), theophylline (two trials ^124,^ ^126^ ), salbutamol (one trial ^118^ ), indomethacin (one trial ^122^ ), atropine (one trial ^120^ ), nifedipine (one trial ^127^ ), verapamil (one trial ^126^ ), cromolyn (one trial ^126^ ), fenoterol (one trial ^129^ ), prednisone (one trial ^122^ ), and immunotherapy (one trial ^121^ ). All but one of the pharmacological trials was placebo controlled. ^122^ The length of study intervention and follow-up varied; three studies followed patients for at least 6 months ^117,^ ^121,^ ^128^ and the remaining studies were shorter. Response to SIC was a commonly assessed outcome and was measured in ten (77 percent) trials. ^118,^ ^119,^ ^122^ – ^127,^ ^129,^ ^130^

### Methodological Quality of Included Studies

Cohort. The mean Downs and Black score of the 52 included studies was 16.4 (SD 4.0) (Appendix E: Evidence Table E-11; Table 9) of a total possible score of 29. Table 4 depicts the mean scores within each component of the quality assessment tool.

Table 4 Summary of components of Downs and Black score

| Reporting | External Validity | Bias | Confounding | Power | Overall
Maximum Score | 11 | 3 | 7 | 6 | 2 | 29
Actual Score Mean (SD) | 8.2 (1.8) | 1.6 (1.0) | 3.9 (1.1) | 2.3 (1.1) | 0.5 (0.5) | 16.4 (4.0)

Abbreviations: SD = standard deviation

Table 9 Methodological quality of studies for the management of OA

| References
Report IPD | ^142,^ ^158,^ ^174,^ ^163,^ ^271,^ ^178,^ ^136,^ ^143,^ ^132,^ ^4,^ ^133,^ ^165,^ ^144,^ ^130,^ ^153,^ ^151,^ ^171,^ ^135,^ ^116,^ ^56,^ ^139,^ ^148,^ ^159,^ ^150,^ ^177,^ ^152,^ ^173^
Data collection
Prospective | ^134,^ ^57,^ ^142,^ ^158,^ ^167,^ ^131,^ ^55,^ ^58,^ ^164,^ ^154,^ ^174,^ ^175,^ ^163,^ ^271,^ ^178,^ ^136,^ ^143,^ ^141,^ ^147,^ ^132,^ ^179,^ ^4,^ ^270,^ ^133,^ ^145,^ ^170,^ ^172,^ ^166,^ ^165,^ ^149,^ ^169,^ ^144,^ ^130,^ ^153,^ ^151,^ ^171,^ ^135,^ ^116,^ ^137,^ ^56,^ ^139,^ ^148,^ ^159,^ ^150,^ ^177,^ ^176,^ ^140,^ ^152,^ ^138,^ ^269,^ ^173^
Retrospective | ^22^
Source of funding
Government | ^142,^ ^158,^ ^167,^ ^164,^ ^271,^ ^166,^ ^130,^ ^153,^ ^22,^ ^148^
Other | ^174,^ ^175,^ ^178,^ ^136,^ ^143,^ ^4,^ ^133,^ ^145,^ ^171,^ ^135,^ ^138^
Not reported | ^134,^ ^57,^ ^131,^ ^55,^ ^58,^ ^154,^ ^163,^ ^141,^ ^147,^ ^132,^ ^179,^ ^270,^ ^170,^ ^172,^ ^165,^ ^149,^ ^169,^ ^144,^ ^151,^ ^116,^ ^137,^ ^56,^ ^139,^ ^159,^ ^150,^ ^177,^ ^176,^ ^140,^ ^152,^ ^269,^ ^173^

Apart from one study, data were collected prospectively. Approximately half (27/52) of the studies provided some IPD. When reported, the most common funding source was provided by a government agency; 31 of the studies did not disclose their funding source and few were industry sponsored.

Trials. Of the thirteen clinical trials, the median Jadad score was 2 (IQR: 2, 3) (Appendix E: Evidence Table E-12). Concealment of allocation was adequately reported in two of the trials ^117,^ ^129^ , and inadequately in four trials ^119^ – ^122^ . The method of concealing allocation was unclear in the remaining seven trials. ^118,^ ^123^– ^128^ Six trials did not report their source of funding ^118,^ ^119,^ ^121,^ ^123,^ ^127,^ ^129^ and two trials were supported solely by government grants. ^126,^ ^128^ The remaining trials received grants from at least two different types of sources, including private industry, government bodies, foundations, or other sources. Eight of the studies reported that workers stopped medication prior to the beginning of the trial. ^118^ – ^120,^ ^122,^ ^124^ – ^126,^ ^128^

### Qualitative Results

#### Cohort Studies

Lung function. Twenty-seven studies reported FEV_1_ at diagnosis (see Appendix E: Evidence Table E-7) and we attempted to synthesize the change in lung function over time. In order to assess this outcome, we examined the difference between the mean percent predicted FEV_1_ at follow-up and baseline in relation to average length of follow-up. Baseline mean percent predicted FEV_1_ of the included studies is shown in Figure 13. ^55,^ ^58,^ ^130^ – ^147^

Figure 13. Average percent predicted FEV_1_ at baseline for groups of patients who remained exposed, were removed from contact, or reduced exposure to the suspected asthmagen

The size of the plotting character is proportional to the number of patients in the group and the color indicates the molecular weight of the suspected asthmagen (white=HMW, black=LMW, grey=mixed).

Severity at diagnosis. Of the 17 studies (n=666 patients) where patients were completely removed from exposure to the offending asthmagen, 16 reported a mean baseline percent predicted FEV_1_ >80 percent, indicating primarily mild impairment to normal pulmonary function. Among the studies examining patients who remained fully exposed, six of seven studies reported mean baseline percent predicted FEV_1_ >80 percent. Four of the five studies describing subjects with reduced exposure reported mean baseline percent predicted FEV_1_ >80 percent. Based on these findings, it does not appear that lung function at diagnosis was associated with exposure status during follow-up. No specific pattern emerged when we considered the molecular weight of the asthmagen studied.

Follow-up. Less than half of the studies where patients were removed from exposure ^58,^ ^132,^ ^138^ – ^140,^ ^144,^ ^146^ or had reduced their exposure ^131,^ ^138,^ ^139^ , had improved FEV_1_ over time (change >0) (Figure 14). Only one study where patients remained exposed to the work environment had a positive change in mean percent predicted FEV_1_. ^144^ No specific pattern emerged when we considered the molecular weight of the asthmagen studied.

Figure 14. Difference between average percent predicted FEV_1_ in follow-up and average percent predicted FEV_1_ at baseline plotted against average length of follow-up by exposure status in follow-up

Improved percent predicted FEV_1_ over time is indicated by values greater than zero (0). No change in percent predicted FEV_1_ in indicated by a dashed line at percent predicted FEV_1_=0. Observations from cohorts with multiple follow-up visits are joined by a dotted line. The size of the plotting character is proportional to the number of patients in the group and the color indicates the molecular weight of the suspected asthmagen (white=HMW, black=LMW, grey=mixed).

NSBP test. A variety of test characteristics were used to describe non-specific BHR. Generally, hyper-responsiveness was defined as the provocative concentration or dose of histamine or methacholine required to elicit a pre-determined change in FEV_1_, usually a 15 or 20 percent decline (PC_15/20_ and PD_15/20_, respectively). In most cases, PC_20_ values <16 mg/mL were considered to reflect significant BHR; however, cutoff levels of <8 mg/mL and <32 mg/mL were also reported. These results were eventually reported as either the number of patients who were hyper-responsive at a specified concentration cut-off value (e.g., <8 mg/mL, <16 mg/mL, <32 mg/mL) or as the mean or geometric mean of the concentrations that produced the required FEV_1_ drop. Of the 13 studies that reported the presence of hyper-responsiveness at diagnosis, between 36 percent and 100 percent of patients with OA were classified as hyper-responsive. ^56,^ ^130,^ ^132,^ ^134,^ ^135,^ ^141,^ ^144,^ ^148^ – ^152^

Follow-up. The change in hyper-responsiveness over time (i.e., from baseline) was investigated by calculating the ratio of average hyper-responsive concentration at follow-up to the average baseline concentration. This measure was chosen because it is independent of the measurement unit and because the baseline measures of NSBP test varied. Therefore, all studies that reported or provided sufficient information to calculate a mean or geometric mean of a hyper-responsiveness measure at baseline and at follow-up were included. A ratio greater than 1.0 indicates improved hyper-responsiveness (follow-up/baseline) because the average concentration to achieve the specified bronchial response was greater at follow-up than at diagnosis. Conversely, a ratio less than 1.0 indicates worsening hyper-responsiveness because the average concentration to elicit a bronchial response was lower at the follow-up visit, signifying that the airways of patients were more hyper-responsive.

Figure 15 demonstrates that 14 of 15 studies of individuals who were removed from exposure had decreased hyper-responsiveness at follow-up. ^130^ – ^133,^ ^135^ – ^137,^ ^143,^ ^148,^ ^153^ – ^157^ Conversely, patients who remained exposed were overall more hyper-responsive at follow-up testing, although two of the five studies showed improved hyper-responsiveness at follow-up. ^133,^ ^150^ There were insufficient data (three studies) to draw conclusions about change in hyper-responsiveness among patients with reduced exposure. No specific pattern emerged when we considered the molecular weight of the asthmagen studied.

Figure 15. Ratio of mean NSBP test at follow-up visit to mean NSBP test at baseline plotted against average length of follow-up by exposure status in follow-up

Improved hyper-responsiveness is indicated by values greater than 1. No change in responsiveness is indicated by a dashed line where the ratio=1. Observations from cohorts with multiple follow-up visits are joined by a dotted line. The size of the plotting character is proportional to the number of patients in the group and the color indicates the molecular weight of the suspected asthmagen (white=HMW, black=LMW, grey=mixed).

Medications. Medication needs were used as a proxy measure for disease severity and continued asthma symptoms. Twenty-two studies reported some medication data at baseline or diagnosis. The number of patients taking specific types of medications (bronchodilators, corticosteroids, etc.) was most frequently reported in insufficient detail to form an analytic approach. ^58,^ ^134,^ ^136,^ ^146,^ ^158^ – ^162^ Eight studies reported the percent of patients using asthma medications at baseline; however, did not specify type. ^49,^ ^123,^ ^131,^ ^132,^ ^141^ – ^143,^ ^163^ Two studies categorized patients by frequency of medication use ^130,^ ^138^ and three studies reported a mean score based on the frequency of medication use. ^56,^ ^100,^ ^137^ Follow-up data were reported in a similar manner.

There was no clinically meaningful way to combine the continuous measure outcomes with the frequency data. In addition, not all studies reported medication use at baseline and follow-up, thus we explored the percent of patients taking medications at follow-up. When the usage level was specified, only those that reported daily or frequent use of medications were counted. ^138,^ ^141,^ ^142,^ ^147,^ ^158,^ ^164^

Follow-up. Of the patients removed from exposure, the percentage of patients using medication at follow-up ranged from 17 to 100 percent (Figure 16). ^56,^ ^98,^ ^116,^ ^130^ – ^132,^ ^134^ – ^136,^ ^138,^ ^141,^ ^147,^ ^154,^ ^158,^ ^162,^ ^165^ – ^168^ Within this group of 17 studies, there was no indication that fewer patients were using medication as time from removal increased. Only nine studies reported medication use among patients who remained exposed ^131,^ ^139,^ ^141,^ ^157,^ ^162^ or had reduced exposure to the asthmagen ^131,^ ^138,^ ^139,^ ^142,^ ^165^ ; no clear pattern of changes in medication use emerged.

Figure 16. Percentage of patients taking asthma medications in follow-up plotted against average length of follow-up by exposure status in follow-up

Using medication need as a surrogate for disease severity, decreasing percentages of subjects on medication over time may indicate decreasing disease severity. Observations from cohorts with multiple follow-up visits are joined by a dotted line. The size of the plotting character is proportional to the number of patients in the group and the color indicates the molecular weight of the suspected asthmagen (white=HMW, black=LMW, grey=mixed).

Symptoms/improvement. Thirty publications reported a variety of symptom outcomes by intervention status of continued exposure, reduced exposure, and cessation of exposure. Outcome measures included mean symptom scores ^137,^ ^138,^ ^145^ , categorical symptom scores ^164,^ ^166^ , and the number of subjects who were asymptomatic or recovered, remained symptomatic, or had specific symptoms. ^50,^ ^56,^ ^58,^ ^131^ – ^133,^ ^139,^ ^142,^ ^144,^ ^148,^ ^157^ – ^159,^ ^169^ – ^176^ Four studies included statements regarding non-quantified “improvement”. ^136,^ ^149,^ ^154,^ ^163^ Due to the disparity of outcomes, only a qualitative assessment was possible.

Among the studies that examined workers removed from exposure the majority reported some improvement in workers' symptoms following removal. ^50,^ ^56,^ ^58,^ ^131^ – ^133,^ ^136^ – ^138,^ ^144,^ ^148,^ ^154,^ ^157^ – ^159,^ ^163,^ ^164,^ ^166,^ ^169^ – ^174^ This was measured by either a symptom score or reporting that the majority of patients had improved symptoms or were considered “asymptomatic”. The same pattern emerged in the nine studies describing symptoms for subjects whose exposure had been reduced by a workplace intervention. ^131,^ ^138,^ ^139,^ ^142,^ ^149,^ ^163,^ ^170,^ ^175,^ ^176^ Very few studies reported a complete resolution of symptoms among the majority of workers. ^148,^ ^159,^ ^174^

Three groups examined the effectiveness of respiratory protective equipment in reducing symptoms caused by workplace exposures. In general, these papers reported that while respiratory protective equipment did reduce the severity of acute symptoms, they did not eliminate symptoms altogether. ^152,^ ^169,^ ^177,^ ^178^

Finally, most of the studies of workers who remained exposed to the asthmagen at work showed that symptoms either remained stable or deteriorated with continued exposure. ^50,^ ^58,^ ^133,^ ^137,^ ^139,^ ^144,^ ^145,^ ^157,^ ^163^ Only two studies reported improved symptoms among those who remained exposed to the asthmagen. ^166,^ ^176^

Socioeconomic consequences. Seven studies examined socioeconomic outcomes among workers with OA (Table 5). In all but three studies ^138,^ ^164,^ ^179^ , the subjects were comprised of a group primarily removed from workplace exposure and a continued exposure group. Vandenplas et al. ^138^ compared two groups of workers: reduced or removed from exposure. In two instances, all of the workers were removed from the offending workplace. ^164,^ ^179^ Five of the studies included mixed causes of OA, while one study examined latex-induced OA ^138^ , and the other included patients with red cedar asthma. ^50^ Time since OA diagnosis ranged from 1 year to 5.5 years.

Table 5 Economic consequences of occupational asthma

Citation | Removed/Unemployed | Exposed or Reduced
Employment
Gassert et al. ^164^ | 38*/55 | 17+/55
Dewitte et al. ^59^ | 33*/134
Income
Ameille et al. ^57^ | -50 percent (69/82^) | -19 percent (20/104^)
Moscato et al. ^166^ | -$4,203.72 USD/year | -$268.71 USD/year
Gannon et al. ^58^ | -$5,863.88 USD/year | -$3,820.27 USD/year
Gannon et al. ^58^ | -54 percent (56/78^) | -35 percent (14/34^)
Marabini et al. ^50^ | -$368.14 USD/month | -$256.38 USD/month
Marabini et al ^50^ | -$609.96 USD/month*
| -20 percent (10/16^) | 0 percent (6/20^+)
Insured
Gassert et al. ^164^ | 49/55
WCB Claim Acceptance
Vandenplas et al. ^138^ | 3/7 | 1/5
Marabini et al. ^50^ | 17/20 / 42/45 | 31/33
Pharmaceutical Costs/Month
Moscato et al. ^166^ | -$12.46 USD | +$13.17 USD

Abbreviations: USD = United States dollars

WCB = Workers' Compensation Board

Note: * = unemployed

+ = reduced exposure

^ = perception of reduced income

Of the four studies that measured financial situation after OA diagnosis, all found that workers who were removed from the workplace causing their OA suffered a loss in income. In one study conducted, 85 workers who were removed from exposure were compared to 117 workers who continued to work for the same employer (46 used PPE, 20 had the same job, 38 workers were relocated, and 13 were on chronic sick leave). ^57^ The response rate to economic questions was high (89 percent). When compared to workers who were completely removed from the causative workplace, exposed workers were less likely to have suffered diminished earnings; the mean loss of annual income was significantly less among the exposed workers. Another study examined 25 workers with SIC-confirmed OA; 13 workers were removed from exposure and 12 workers continued their exposure. ^166^ After one year, a significantly greater number of removed workers reported deterioration in their economic situation. Compared to 1 year earlier, both monthly and annual income significantly decreased among the removed workers. Earnings also decreased in the workers with continued exposure; however, this difference was not significant. Interestingly, this study also reported that pharmaceutical expenses significantly decreased for those removed from exposure, while they increased among workers with continued exposure. A third study compared 78 workers with OA removed from the workplace to 34 workers with OA who continued to be exposed. ^58^ While 140 participants were identified, 112 completed the follow-up questionnaire. Fewer workers who were still exposed felt they had lost money than workers who were removed. The perceived median annual loss of income and the perceived percentage loss of annual income were higher among the workers who ceased workplace exposure. The authors did not perform any tests of statistical significance. The final study examined red cedar asthma workers who were exposed workers (48), non-exposed workers (27), and unemployed workers (53). ^50^ Monthly income among the unemployed cohort was significantly less than the working exposed and working non-exposed groups.

Vandenplas et al. compared 20 workers who had reduced levels of latex exposure to 16 workers who were removed from latex. ^138^ Among the reduced exposure group, 7/20 workers reported work disability, defined as changed or left work, while 11/16 of workers removed from latex exposure reported work disability and the remaining five workers were not working because of their latex-induced OA. More workers who were removed from latex reported a decrease in income compared with workers with reduced latex exposure. The actual reduction in earning was 20 percent among the non-exposed workers, while there was no reduction in earnings for the workers with reduced exposure.

Two studies assessed the rate of worker's compensation claims and associated acceptance. ^50,^ ^138^ In Vandenplas' et al. study, only 12 of the 36 workers stated they had attempted to seek compensation. The Belgian Workers' Compensation Board (WCB) more frequently approved claims among workers who were removed from the workplace than those who reduced their exposure. In contrast, the Canadian WCB approved more claims than its Belgian equivalent. Among those who filed for compensation, the acceptance rate was similar between workers with continued exposure, workers who ceased exposure, and the unemployed. ^50^

Two studies followed a cohort of workers who were removed from exposure. Gassert et al. conducted a study of 55 patients with “definite/probable” OA of mixed origins. ^164^ Seventy-two patients were identified and 55 were interviewed. At follow-up, approximately one-third of the subjects were employed and their exposure was reduced (17/55). The remaining subjects were unemployed. Prior to a diagnosis of OA, 54 workers had health insurance; at follow-up, 49/55 patients were not insured and had to pay for their asthma medication and care. The final study reported findings on 211 Quebec workers with OA caused by mixed exposures were awarded workers' compensation between 1986 and 1988. One hundred and thirty-four of the 211 eligible workers were followed up 2 years after removal from exposure. The average cost of disability/impairment for each worker was $35,529 USD. A significant portion of the workers were either unemployed (11/134) or took an early retirement (22/134).

Quality of life (QOL). Two studies measured quality of life. Vandenplas et al. examined 36 subjects with SIC confirmed latex induced OA. ^138^ At a median follow-up time of 56 months, 16 subjects were no longer exposed to latex and 20 subjects had reduced their exposure. Two methods to reduce latex exposure were employed: using less than 20 pairs of latex gloves in the room or department each week; and using low allergen sterile and latex-free examination gloves. QOL was measured using a French version of the Asthma Quality of Life Questionnaire (AQOL). AQOL did not significantly differ among those removed from exposure versus those who reduced their exposure.

In the second study, 211 workers with OA, 134 participated in a follow-up survey assessing QOL. ^93^ SIC or serial PEFR was used to diagnose Quebec workers with OA; all the workers were removed from the exposure and received compensation from the WCB. Ninety-one workers with OA were matched to 91 similar patients with non-occupational asthma. This study also utilized the AQOL that considers five components of asthma: self-determined activities that were limited by OA, other activities, symptoms, emotional function, and exposure to environmental stimuli. When compared to the control group, both the total and component scores of the QOL survey were significantly lower among workers with OA than those with non-occupational asthma.

RADS. Piirila et al. followed six men who were exposed to sulfur dioxide during an explosion at a pyrite mine. ^116^ At follow-up, three patients continued to work in the same workplace, two had retrained and no longer worked underground, and one had retired because of respiratory disability sustained after the explosion; 13 years later, chest radiographs, spirometry, and NSBP testing were assessed. All of the workers, except one of the men who was retrained, continued to suffer from non-specific BHR. NSBP testing was not performed in one worker who continued in the same workplace because of dyspnea, wheezing, and moderate obstructive ventilatory impairment. There were no changes in chest radiographs.

A second study reported findings among a group of 29 men who were repeatedly exposed to chlorine over three months and subsequently diagnosed with RADS. ^4^ The men were no longer exposed to chlorine and 20 men were assessed one-year post diagnosis. While percent predicted FEV_1_ was not significantly different between diagnosis and follow-up, some of the workers showed improvement in non-specific BHR. Six workers had a significant improvement in PC_20_ (3.2 fold difference from baseline to follow-up); non-specific BHR significantly deteriorated in one worker. Compared to diagnosis, significantly fewer workers required medication to control their OA symptoms.

#### Trials

Pharmacological outcomes. Ten trials examined the effectiveness of various pharmaceutical interventions for preventing exacerbations of OA.

Prednisone, but not indomethacin, was found to be effective in preventing late asthmatic responses among workers with toluene di-isocyanates (TDI)-induced OA. ^122^ Five workers completed four SIC and NSBP tests in the following order: 1) before treatment to establish baseline airway responsiveness; 2) after prednisone treatment (50 mg/d for 3 days); 3) after indomethacin (50 mg four times a day for 3 days); and 4) no treatment to assess reproducibility of baseline lung function values. After prednisone treatment, there was no significant decrease in FEV_1_ measured 4 and 8 hours post-SIC. There was also no significant change in PD_20_ FEV_1_. Conversely, treatment with indomethacin resulted in FEV_1_ and PD_20_ FEV_1_ significantly decreasing 4 and 8 hours after SIC and NSBP test.

Two trials studied the effect of inhaled beclomethasone versus placebo among workers who had been removed from exposure. ^117,^ ^128^ The first study, conducted by Malo et al., compared beclomethasone (dose: 500 μg twice daily) to placebo; workers were randomized to the first treatment for 1 year and then crossed over to the other for 6 months ^117^ . Forty-four workers exposed to HMW and LMW agents were randomized; however, 12 refused to continue treatment for reasons not related to OA and thus, 32 completed the study. When taking beclomethasone, there was a significant reduction in nocturnal symptoms and cough. FEV_1_ and FVC also significantly decreased during both the beclomethasone and placebo periods. However, when compared to placebo, PEF and global QOL significantly improved when taking beclomethasone; no such difference was observed when taking placebo. Greater improvement was noted among those who were first randomized to beclomethasone. The second trial compared beclomethasone (1000 μg daily for 5 months) to placebo among 15 workers who were SIC positive to TDI; seven workers received the active treatment. ^128^ Outcomes were measured at diagnosis, 2, 4, and 6 months. At 6 months, both groups still exhibited a significant late fall in FEV_1_ during SIC; workers randomized to beclomethasone no longer had an early fall in FEV_1_. Among workers receiving beclomethasone, PD_20_ measured using FEV_1_ significantly improved at 2 months and continued to improve at 6 months. PD_20_ measured using FEV_1_ did not change among those receiving placebo.

De Marzo et al. conducted a three-way randomized crossover trial of TDI-sensitive workers who had had not been exposed for 2 weeks prior to the trial beginning. ^125^ The treatment arms consisted of high dose (2000 μg) beclomethasone, low dose (400 μg) beclomethasone, and placebo; the washout period was at least 1 week. SIC and NSBP tests were performed on the seventh day. When receiving placebo and low dose beclomethasone, FEV_1_ was significantly lower after SIC; FEV_1_ did not change among the workers when they were taking high dose beclomethasone. Neither high-dose nor low-dose beclomethasone improved BHR and the hyper-responsiveness decreased over time among all three groups.

Mapp et al. examined the effectiveness of four drugs for the treatment of TDI-induced OA. ^126^ Twenty-four workers received one of the following drugs for 7 days: aerosolized beclomethasone (1 mg/kg twice a day), oral theophylline (6.5 mg/kg twice a day), verapamil (120 mg twice a day), or aerosolized cromolyn (20 mg/kg four times a day). Each worker was also crossed-over to placebo; placebo and active treatment ordering were assigned randomly. NSBP test was performed on the sixth day and 8 hours post-SIC, which was conducted on the seventh day. Workers randomized to beclomethasone experienced less airway responsiveness and did not suffer an asthma exacerbation after SIC. Theophylline reduced the severity of asthma exacerbations after SIC; however, airway responsiveness did not decrease. FEV_1_ decreased and airway responsiveness increased among workers receiving verapamil, cromolyn, or placebo.

Crescioli et al. compared theophylline to placebo in a randomized crossover trial of six male workers with TDI-induced OA. ^124^ In random order, workers received theophylline (5 +/- 1 mg/kg twice daily) or placebo for 7 days; the washout period was 1 week. SIC was performed on the seventh day and airway hyper-responsiveness was measured on day 6 and 8 hours after SIC. Theophylline had no effect on airway hyper-responsiveness; however, it did significantly reduce the severity of late asthmatic reactions. After placebo, three of the six workers required salbutamol after SIC; when treated with theophylline, none of the workers needed salbutamol after SIC.

To determine if atropine was effective in reducing asthmatic reactions, Paggiaro et al. performed SIC before and after administering atropine to 10 workers with TDI-induced OA. ^120^ Workers with hyper-responsive airways (PD_15_ FEV_1_<0.200 mg) received 0.012 mg/kg of subcutaneous atropine; the remaining workers received 0.008 mg/kg. Atropine was delivered 30 minutes prior to SIC and in 90-minute intervals for 6.5 hours. While atropine did inhibit an immediate asthma reaction in one worker, the severity of late asthma reactions was unchanged in the other nine workers. All workers suffered side effects commonly associated with atropine, such as dry mouth, cycloplegia, and increased heart rate.

Eighteen male workers suffering from flour-induced OA were randomized to two 0.4 mg aerosol doses of Fenoterol®. ^129^ Body plethysmography was used to measure airway resistance and end expiratory thoracic gas volume. Woitowitz et al. found that workers randomized to Fenoterol® experienced a significantly normalized airway resistance within 5 minutes. End expiratory thoracic gas volume also improved with the use of Fenoterol®, however this difference was not significant. The drug remained effective for 4 hours and the maximum effect was achieved within 30–120 minutes. There was no significant change in pulse rate or blood pressure.

Moscato et al. compared the effects of nifedipine and placebo on bronchial responsiveness to TDI among five workers with TDI-induced OA. ^127^ In a crossover trial, five patients received two capsules of nifedipine (20 mg sublingually) or placebo 45 minutes before SIC. The test was repeated with alternate treatment 1 week later. Placebo did not prevent asthmatic exacerbations. Immediate asthmatic reactions and reactions within 1 hour were prevented by nifedipine. Two patients required a second dose of 10 mg of nifedipine at 2 hours to prevent a late response.

Malo et al. examined 25 workers who had SIC confirmed OA and displayed late asthmatic reactions; three workers refused to continue and were excluded from the analysis. ^118^ Post SIC, workers were given either salbutamol (200 μg) or placebo and spirometry was measured to determine recovery in FEV_1_. When compared to placebo, workers receiving salbutamol consistently showed greater improvement in FEV_1_, measured by percent FEV_1_ improvement, improvement of ≥20 percent FEV_1_, and return of FEV_1_ as percent of baseline.

Immunotherapy. Armentia et al. conducted a double-blind trial examining the effectiveness of wheat flour extract immunotherapy. ^121^ Thirty workers with bakers' asthma were included, however four withdrew because they left their job and their symptoms improved. Ten workers received injections of placebo, eight received immunotherapy for 10 months, and the remaining eight workers received immunotherapy for 20 months; immunotherapy was administered weekly. Compared to workers in the placebo group, immunotherapy resulted in significantly less skin prick sensitivity and non-specific bronchial reactivity; significant subjective clinical improvement was also noted among the treatment groups. Workers receiving immunotherapy for 20 months experienced a significant decrease in serum specific IgE levels. Overall, the immunotherapy appeared to be safe; a single worker had urticaria after a dose of immunotherapy.

Reducing workplace exposure. Two trials examined the effect of reducing exposure on asthma outcomes in workers with OA. The first study was a crossover trial examining the efficacy of respiratory devices among 26 farmers with SIC-verified OA. ^119^ The farmers wore various respiratory devices with P2 filters (21 Dustmasters®, 4 Airstream®, 1 Airlite®), and SIC was repeated approximately 21 weeks later. Both airway resistance and specific airway resistance were significantly improved when SIC was performed while wearing the respiratory device. During the SIC without respiratory devices, all of the farmers required bronchodilator treatment; only six farmers needed bronchodilator treatment when SIC was performed while wearing a respiratory device. While the respiratory devices did reduce bronchial obstruction, they failed to provide complete protection.

The second study compared healthcare workers' asthmatic reactions to various latex gloves. ^27^ Eight healthcare workers with latex-induced OA were included; all of the workers were SIC positive to the latex powdered gloves (Triflex®) used in their workplace. Each worker had SIC performed in random order while handling at least two of the three types of hypoallergenic latex gloves: low-powdered Triflex®, non-powdered Nutex®, and/or powdered SensiTouch®. Two of the seven workers tested were SIC positive to low-powdered Triflex® gloves. The other two hypoallergenic gloves did not elicit an SIC response. Non-specific BHR to hypoallergenic gloves occurred in two of the eight workers. Among the eight healthcare workers, the use of hypoallergenic gloves reduced the risk of latex asthma exacerbations.