# Methods

## Methods for the Systematic Reviews

### Literature Search

Two medical librarians identified appropriate databases to search and developed search strategies based on the following terms: asthma, lung disease, respiratory disease, occupational disease, occupational exposure, worker, work-related, leave work, reduce exposure, personal protective equipment, pharmacological treatment, inhalation challenge, peak flow, forced expiratory flow rates, bronchial provocation test, medical history taking, diagnostic techniques, sensitivity, specificity, predictive value, and, likelihood function. A filter was applied to the search output to remove studies pertaining to children (defined as those under the age of 18 years).

These search terms were adapted appropriately to search the following electronic resources: MEDLINE^®^, EMBASE^®^, Dissertation Abstracts^®^, Expanded Academic^®^, National Agricultural and Safety Database^®^, CINHAL^®^, Biological Abstracts^®^, Agricola^®^, and trials registries (http://clinicaltrials.gov/; http://www.centerwatch.com/; http://www.cochrane.org/index0.htm; http://www.controlled-trials.com/; http://www.update-software.com/National/; http://www.trialscentral.org/). Web of Science^®^ was searched by tracking the most sentinel articles forward. The Cochrane Airways Review Group has developed an “Asthma and Wheez* RCT” register through a comprehensive search of EMBASE^®^, MEDLINE^®^, and CINAHL^®^. In addition, hand searching of 20 common respiratory care journals has been completed and relevant randomized controlled trials (RCT) have been added to the register. This database was examined for articles pertaining to therapy for OA. The detailed search strategies appear in Appendix A. ^♦^

♦ The Appendices and Evidence Tables cited in this report are provided electronically at http://www.ahrq.gov/downloads/pub/evidence/pdf/asthmawork/asthwork.pdf

Authors of included studies that had published at least two papers were contacted regarding any missing studies. The reference lists of all included articles and an internal report that was recently prepared for the Workplace Safety & Insurance Board of Ontario, Canada entitled “The Diagnosis of Occupational Asthma” were searched for any new studies we might have missed. Conference proceedings from ACCP, American Thoracic Society, and European Respiratory Society scientific meetings were hand searched for the years 2001-2003. In addition, clinical practice guidelines were examined for the following organizations: ACCP, American Thoracic Society, Canadian Asthma Consensus Guidelines, European Respiratory Society, Thoracic Society of Australia and New Zealand, British Thoracic Society, World Health Organization, International Labor Organization, International Commission on Occupational Health, and the Canadian Thoracic Society Guidelines on Occupational Asthma. The search was not limited by language or publication status and is considered current until February 2004. If potentially relevant studies were identified as part of the review process and met the inclusion criteria, they were included.

### Selection and Inclusion

All duplicate references were removed from the initial electronic searches. Each title, and when available, abstract was independently screened by two reviewers. Using general inclusion criteria, that is, primary research describing the diagnosis and/or management of OA, each study was classified as “include”, “exclude”, or “unclear”. An occupational medicine specialist with an interest in occupational asthma and an asthma researcher then screened the references identified as “include” and “unclear” and the full text of the potentially relevant articles were retrieved. Specific inclusion criteria pertaining to the diagnosis and management of OA were developed (Table 3, Appendix B). For example, articles involving workers with respiratory symptoms who were referred for assessment of OA at a pulmonary clinic were included. Similarly, if a group of workers were screened using a survey method, and only those with respiratory symptoms were reported (for diagnostic or treatment studies), the study was eligible. In the event a screening study of workers at a work site was identified and if those with respiratory symptoms could not be ascertained from the publication or author communication, the article was excluded. In this manner, this systematic review excluded studies designed to screen for workplace respiratory symptoms.

Table 3 Inclusion/exclusion criteria for review on diagnosing and managing occupational asthma

Criterion | Diagnosis Review | Management Review
Study Design | Include: RCT, CCT, prospective or retrospective cohort, cross-sectional, case-series (>2 subjects) | Include: RCT, CCT, prospective or retrospective cohort, cross-sectional, case-series (>2 subjects)
| Exclude: case studies | Exclude: case studies
Participants | Include: de-novo asthma or a previous diagnosis of occupational asthma that is exacerbated at work | Include: de-novo asthma or a previous diagnosis of occupational asthma that is exacerbated at work
Intervention / Control | Reference Standard: SIC, supervised workplace challenge, serial lung function tests, serial measurement of non-specific airway reactivity, immunological testing, clinical expert diagnosis and exposure to an “asthmagen”. | Removal from the workplace, relocated to a position with decreased exposure to the “asthmagen” within the same workplace, PPE, engineering controls, or pharmacological treatment.
| Other Comparison: above tests and/or sputum, metabonomics, nitrous oxide.
Outcome Measures | Absolute numbers to construct a 2 × 2 (comparing two diagnostic techniques) or 2 × 1 (assessing one diagnostic technique in workers with a previous diagnoses of occupational asthma) table, sensitivity, specificity, or likelihood ratios, cost, time to complete diagnosis, adverse effects. | Pulmonary function, use of medication, healthcare utilization, frequency of exacerbations, QOL, symptoms, economic consequences, adverse events.

Abbreviation: RCT = randomized controlled trial

CCT = clinical controlled trial

SIC = specific inhalation challenge

PPE = personal protective equipment

QOL = quality of life

Using standard data forms, two reviewers independently applied the inclusion criteria. Disagreements were resolved through discussion and consultation with an occupational and asthma researcher. In situations where the studies were attempting to diagnose or manage workers with OA, respiratory symptoms, and/or rhinitis, studies were included if the results were stratified by specific disease and data for those with OA extractable, or if >90 percent of the included workers suffered from suspected OA, and data for just those subjects with OA could not be identified, all data were included. Case-reports and series involving less than two workers were excluded, as were studies that exclusively examine two different ways of measuring the same diagnostic test (e.g., Occupational Asthma System computer system versus visual assessment of PEFR records).

If needed, the investigators contacted the authors to clarify that individual publications reported on discrete workers. In cases where multiple publications involving the same or a portion of the same workers were identified, the most recent publication of the largest cohort was selected and any additional, unique information from previous publications was incorporated. If a study was published within the last 10 years and relevant health outcomes were not presented by ongoing exposure status, but the authors presented exposure status as an outcome (e.g., number remaining at same workplace), the authors were asked to provide outcome data by exposure status.

### Quality Assessment

Assessment of the methodological quality of included studies was completed independently by two reviewers, using a variety of methods of assessment based on the review topic as follows:

Diagnosis review. The methodological quality of each included diagnostic study was completed using a quality tool developed from Lijmer's empirical research examining biases in diagnostic studies (Appendix B). The quality tool was comprised of 12 questions and pilot tested by the research team prior to employment. Empirically validated questions included study design (case control versus cohort), levels of blinding of measurements, use of appropriate reference or gold standard, an adequate description of the reference standard and test(s), thorough description of the study population, and the occurrence of differential reference bias. ^70^ In addition, information regarding the occurrence of partial verification bias, timing of data collection, method of worker selection, reporting of inter-rater reliability, and the method of reporting results was also captured. Discrepancies were resolved through discussion. Whether or not the authors mentioned that medication was terminated (or attempted) before testing was considered an additional marker of methodological quality.

Management review. The quality of each included cohort therapy study was independently assessed using Downs and Black's partially validated “Checklist of the assessment of methodological quality of both randomized and non-randomized studies of health care interventions” (Appendix B). ^71^ This tool is composed of 28 questions that evaluate reporting (10 questions, total score 11), external validity (three questions, total score three), internal validity-bias (seven questions, total score seven), internal validity-confounding (six questions, total score six), and power (two questions, total score two). The maximum total score was 29 indicating high quality and the lowest possible score was 0 indicating low quality. The reviewers, asthma researchers, and occupational health specialist developed a priori guidelines regarding the application and implementation of the quality tool. In the event that a question was not applicable to the study design, the question was answered “no”. Also, the funding source was recorded for each study. Controlled clinical trials (CCT) were assessed with a second tool, the Jadad scale. ^72^ This validated five-point scale assesses randomization, double-blinding, and the reporting of withdrawals and dropouts. In addition, concealment of allocation was evaluated to be “adequate”, “inadequate”, or “unclear”. ^73^ When there were multiple publications of the same workers, methodological quality was assessed on the most recent or largest study. Discrepancies were resolved through discussion.

### Data Extraction

Two data extraction forms were developed, piloted, and used to extract data from the group of diagnostic or therapy studies (Appendix B). Data were extracted by one reviewer and checked for completeness and accuracy by a second reviewer. When data were presented graphically, the graphs were scanned into CorelDraw® (Version 9; Ottawa, Canada) to facilitate extracting the data points with greater accuracy. Discrepancies were resolved through discussion and input from the task leaders. Whenever possible, a task leader classified the exposures as high and low molecular weight based on published information. ^74^

Diagnosis review. Data were extracted regarding the study population characteristics, diagnostic tests, and results (e.g., sensitivity, specificity, likelihood ratios [LR], etc.). The following patient characteristics were recorded: probable cause of OA, patient source, sex, race, duration of exposure and symptoms, history of atopy/allergy diagnosis, smoking status, history of asthma, medication usage, and baseline pulmonary function. For each diagnostic test, the methodology, timing, inclusion/exclusion criteria, medication use, and definition of a positive test result were extracted.

The reference standard was assigned an ‘evidence grade’ as per our Levels of Evidence (Appendix C) designed in consultation with the technical expert panel (TEP). Additional outcomes included cost of diagnosis, time to complete diagnosis, and presence of adverse events. Where possible, a 2 × 2 diagnostic table was constructed for the reference standard versus the comparison test(s). Where a comparison involved two ‘reference’ tests the highest ranked test for evidence grade (see Appendix C) was used as the reference test. The sensitivity and specificity were extracted or calculated from the 2 × 2 table.

Management review. Details concerning worker characteristics, interventions, tests used to measure outcomes, and outcomes were recorded. Workers were described by their sex, age, race, smoking status, history of asthma, history of atopy, probable cause of OA, diagnostic tests used to determine OA, duration or exposure and symptoms, current medication, and severity of asthma. Where applicable, appropriate workers characteristics, such as smoking status, at follow-up were documented. Interventions were described by change in exposure (decreased or removal from exposure), type of protective equipment employed, or the type, dosage, route, and timing of pharmaceutical treatment. The type of test, method followed, and when appropriate, definition of a positive test (e.g., follow-up NSBP test) was recorded for each of the tests used to measure outcomes. Outcomes extracted included lung function, symptoms and medication scores, and economic status. The length of follow-up was also recorded.

### Data Analysis

All data analyses were performed using SAS® (Version 8.2, Cary, USA). Graphics were produced using S-Plus® (Version 6.0, Seattle, USA).

Diagnosis review. Whenever possible we re-created a standard 2 × 2 table (or 2 × 1 if only reference standard positive or reference standard negative subjects were included) for each comparison test or combination of tests. This was not possible when individual patient data (IPD) was presented without a documented cut-off value indicating the presence (i.e., a positive result) or absence of OA. When sensitivity and specificity could be calculated for more than one cut-off value or definition for the same diagnostic test, we included the table that produced the highest test efficiency defined as the proportion of correctly identified patients (reference standard positive and reference standard negative) by the comparison test. ^75^

Sensitivity and specificity were calculated for each study using standard formulas. Results were pooled using the inverse variance method for random effects to calculate an overall estimate of sensitivity and specificity. ^1^ We pooled data from 2 × 1 tables separately (reference standard positive or reference standard negative only) from studies that presented data from which a 2 × 2 table could be generated (both reference standard positive and negative). Furthermore, results were only pooled for studies of similar molecular weight (HMW or LMW) asthmagens. When sensitivity and specificity could both be calculated, these values were plotted in receiver operator curve (ROC) space. When there were a sufficient number of studies (n>10), a summary ROC (SROC) curve was derived and added to the plot.

1 The following software was used for these calculations: Lau J. Meta-Test version 0.9. Tufts-New England Medical Center, Boston, 2003 and the Meta package for R (http://cran.r-project.org/).

One drawback of pooling sensitivity and specificity is that it does not take between study heterogeneity into account. There are many sources of heterogeneity in any review, and a specific source for diagnostic reviews is that variation in sensitivity and specificity that results from heterogeneous definitions of a positive test result. ^76,^ ^77^ When the information was reported, we recorded the exact definition used to define a positive test and this information is presented in an evidence table (Appendix E). The inclusion of different asthmagens within each molecular weight category was an additional source of heterogeneity in this review. The study specific asthmagen is listed with the results on the test specific plots described later in this report.

Management review. Due to the extreme heterogeneity of the reporting of outcomes in the treatment articles, no meta-analytic techniques were employed and the summaries are descriptive in nature. Nonetheless, some re-organization of the data as reported was required to homogenize the information provided in the descriptive summary.

For continuous outcomes such as FEV_1_ and some measures of BHR, a mean was used as the measure of central tendency when available. In cases where the mean was not reported or could not be obtained from an accompanying graph, the following substitutions (in order of preference) were used: median and midpoint of the range or IQR. When possible, a mean was calculated from IPD when it was available in a tabular format or plotted on a graph.

Similarly, standard deviation (SD) was used as the measure of variation. In cases where the SD was not reported or could not be determined from a graph, the following substitutions were used: (75^th^ percentile - 25^th^ percentile)/1.35 when IQR was reported; (maximum - minimum)/4 when range was reported and sqrt(n)*standard error of the mean (SEM) when SEM was reported. If individual data were available in tabular or graphic form, the SD was directly calculated.

Baseline characteristics and outcomes were grouped in various ways for the studies. When possible the data were grouped according to exposure status in follow-up as follows: continued exposure, reduced exposure, or ceased exposure. We used the following formulas to combine data when necessary:

Exposure Group mean=(n_1_*mean_1_)+(n_2_*mean_2_ )+...(n_k_*mean_k_ )/(n_1_+n_2_...n_k_)

Exposure Group SD=sqrt(((n_1_-1)*(SD_1_)^2^+(n_2_-1)*(SD_2_)^2^+...(n_k_-1)*(SD_k_)^2^)/(n_1_+n_2_...+n_k_-k))

Because it was usually not reported, the mean difference between baseline (diagnosis) and follow-up was calculated as the difference between the mean at follow-up and the mean at baseline. Standard deviation of the difference was estimated assuming a between patient correlation of rho=0.5 between the baseline and follow-up values using the formula:

Var(A-B)=sqrt(VarA+VarB-2*rho*sqrt(VarA*VarB)) where Var(X)=SD(X) ^2^

For economic outcomes, currency measures were converted into US dollar (USD) equivalents based on exchange rates for the reported currency in the year of the studies' publication (http://www.oanda.com/convert/classic).

## Peer Review

Twenty-six occupational asthma and/or methodological experts were approached to peer-review the draft of this report. Twelve experts agreed to do so and 11 provided comments within the allocated time period. We considered their comments and amended this report accordingly. Peer reviewers are listed in Appendix F and will be available on the AHRQ Web site.